# VERSION HISTORY

Date | Description
April 2023 | Final toxicological profile released
April 2022 | Draft for public comment toxicological profile released
July 1992 | Final toxicological profile released