# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding nitrophenols in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for nitrophenols.

Table 7-1 Regulations and Guidelines Applicable to Nitrophenols

Agency | Description | Information | Reference
Air
EPA | RfC
EPA | 4-Nitrophenol | Information reviewed but value not derived | IRIS 2002
EPA | Provisional peer reviewed toxicity values
EPA | 2-Nitrophenol
EPA | Provisional subchronic RfC | 0.0005 mg/m^3^ (0.00009 ppm) | EPA 2007b
WHO | Air quality guidelines | No data | WHO 2010
Water & Food
EPA | Drinking water standards and health advisories | | EPA 2018b
EPA | 4-Nitrophenol
EPA | 1-Day health advisory (10-kg child) | 0.8 mg/L
EPA | 10-Day health advisory (10-kg child) | 0.8 mg/L
EPA | DWEL | 0.3 mg/L
EPA | Lifetime health advisory | 0.06 mg/L
EPA | National primary drinking water regulations | Not listed | EPA 2009b
EPA | RfD | | IRIS 2002
EPA | 4-Nitrophenol | Not assessed
WHO | Drinking water quality guidelines | No data | WHO 2017
FDA | Substances added to food (formerly EAFUS) | Not listed | FDA 2022
Cancer
HHS | Carcinogenicity classification | No data | NTP 2021
EPA | Carcinogenicity classification
| 4-Nitrophenol | Not assessed | IRIS 2002
| 2-Nitrophenol | Inadequate information to assess carcinogenic potential | EPA 2007b
IARC | Carcinogenicity classification | No data | IARC 2022
Occupational
OSHA | PEL (8-hour TWA) for general industry, shipyards, and construction | No data | OSHA 2021a, 2021b, 2021c
NIOSH | REL (up to 10-hour TWA) | No data | NIOSH 2018
Emergency Criteria
EPA | AEGLs-air | No data | EPA 2018a
DOE | PACs-air | | DOE 2018a
DOE | 2-Nitrophenol
DOE | PAC-1^a^ | 2.1 mg/m^3^
DOE | PAC-2^a^ | 23 mg/m^3^
DOE | PAC-3^a^ | 140 mg/m^3^
DOE | 3-Nitrophenol
DOE | PAC-1^a^ | 2.8 mg/m^3^
DOE | PAC-2^a^ | 31 mg/m^3^
DOE | PAC-3^a^ | 180 mg/m^3^
DOE | 4-Nitrophenol
DOE | PAC-1^a^ | 0.69 mg/m^3^
DOE | PAC-2^a^ | 7.6 mg/m^3^
DOE | PAC-3^a^ | 46 mg/m^3^

a Definitions of PAC terminology are available from U.S. Department of Energy (DOE 2018b).

AEGL = acute exposure guideline levels; DOE = Department of Energy; DWEL = drinking water equivalent level; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IRIS = Integrated Risk Information System; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TWA = time-weighted average; WHO = World Health Organization