# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Nitrophenols (also referred to as mononitrophenols) exist in three isomeric forms: 2-nitrophenol (or ortho- or o-), 3-nitrophenol (or meta- or m-), and 4-nitrophenol (or para- or p-). All three of these nitrophenols are manmade. Table 4-1 lists common synonyms, trade names, and other pertinent identification information for 2-nitrophenol, Table 4-2 lists this information for 3-nitrophenol, and Table 4-3 lists this information for 4-nitrophenol.

Table 4-1 Chemical Identity of 2-Nitrophenol

Characteristic | Information
Chemical Name | 2-Nitrophenol
Synonym(s) and Registered trade name(s) | O-Hydroxynitrobenzene; 2-Hydroxynitrobenzene; o-Nitrophenol; Phenol, o-nitro-; Phenol, 2-nitro
Chemical formula | C_6_H_5_NO_3_
Chemical structure | Chemical structure for 2-Nitrophenol
CAS registry number | 88-75-5

CAS = Chemical Abstracts Service

Source: NLM 2022a

Table 4-2 Chemical Identity of 3-Nitrophenol

Characteristic | Information
Chemical Name | 3-Nitrophenol
Synonym(s) and Registered trade name(s) | M-Hydroxynitrobenzene; 3-Hydroxynitrobenzene; m-Nitrophenol; Phenol, m-nitro-; Phenol, 3-nitro-;
Chemical formula | C_6_H_5_NO_3_
Chemical structure | Chemical structure for 3-Nitrophenol
CAS registry number | 554-84-7

CAS = Chemical Abstracts Service

Source: NLM 2022b

Table 4-3 Chemical Identity of 4-Nitrophenol

Characteristic | Information
Chemical Name | 4-Nitrophenol
Synonym(s) and Registered trade name(s) | P-Hydroxynitrobenzene; 4-Hydroxynitrobenzene; Niphen; P-Nitrophenol; Paranitrophenol; Phenol, p-nitro-; Phenol, 4-nitro-; PNP
Chemical formula | C_6_H_5_NO_3_
Chemical structure | Chemical structure for 4-Nitrophenol
CAS registry number | 100-02-7

CAS = Chemical Abstracts Service

Source: NLM 2022c

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

2-Nitrophenol is a light yellow, aromatic solid; 3- and 4-nitrophenol are colorless to pale yellow solids. The nitrophenols are expected to be highly soluble in water. They also have low vapor pressures, and therefore, low potential for long range atmospheric transport (Harrison et al. 2005). Tables 4-4, 4-5, and 4-6. List important physical and chemical properties of 2-, 3-, and 4-nitrophenol, respectively.

Table 4-4 Physical and Chemical Properties of 2-Nitrophenol

Property | Information | Reference
Molecular weight | 139.109 | NLM 2022a
Color | Light yellow | O’Neil 2006
Physical state | Crystalline solid | NLM 2022a
Melting point | 44–45°C | O’Neil 2006
Boiling point | 216°C | Haynes et al. 2015
Density:
| 1.29 g/cm^3^ at 40°C | Haynes et al. 2015
Odor | Aromatic | O’Neil 2006
Odor threshold:
Water | 10 mg/L | Verschueren 1983
Air | 8×10^−11^ moles/m^3^ | Fazzalari 1978
Taste threshold | 0.001 mg/L | Verschueren 1983
Solubility:
Water | 2,100 mg/L at 20°C | Verschueren 1983
Water | 2,500 mg/L at 25°C | Yalkowsky et al. 2010
Water | 10,800 mg/L at 100°C | Verschueren 1983
Organic solvent(s) | Very soluble in ethanol, ether, acetone, benzene, pyridine, chlorine; freely soluble in carbon sulfide, alkali hydroxides | Budavari 1996; Haynes et al. 2015
Partition coefficients:
Log K_ow_ | 1.79 | Hansch et al. 1995
Log K_oc_ | 1.76–2.04 | Gawlik et al. 1998; Tülp et al. 2009
Vapor pressure
At 20°C | 0.113 mm Hg at 25°C | NLM 2022a
Henry’s law constant | 1.3×10^−5^ at 20°C | Tremp et al. 1993
Henry’s law constant | 1.63×10^−5^ at 25°C | Harrison et al. 2002
Disassociation constant (pKa) | 7.23 | NLM 2022a
Autoignition temperature | 550°C | NLM 2022a
Flashpoint | 108°C | NLM 2022a
Flammability limits | No data | NLM 2022a
Conversion factors
ppm (v/v) to mg/m^3^ in air at 20°C | 1 ppm=5.783 mg/m^3^ | NLM 2022a
mg/m^3^to ppm (v/v) in air at 20°C | 1 mg/m^3^=0.173 ppm | NLM 2022a
Explosive limits | No data | NLM 2022a

Table 4-5 Physical and Chemical Properties of 3-Nitrophenol

Property | Information | Reference
Molecular weight | 139.11 g/mol | NLM 2022b
Color | Colorless to pale yellow | NLM 2022b
Physical state | Crystalline solid | NLM 2022b
Melting point | 96.8°C | NLM 2022b
Boiling point | 194°C | NLM 2022b
Density:
At 20°C/4°C | 1.485 | O’Neil 2006
Odor | Aromatic to sweetish | Sittig 1981
Odor threshold:
Water | 0.6 m/L | Verschueren 1983
Air | 3.0 mg/m^3^
Taste threshold | No data
Solubility:
Water Organic solvent(s) | 13,550 mg/L at 25°C | Yalkowsky et al. 2010
Water Organic solvent(s) | 133,000 mg/L at 90°C | Verschueren 1983
Organic solvent(s) | Very soluble in acetone, ether, ethanol, benzene | Haynes et al. 2015
Partition coefficients:
Log K_ow_ | 2.00 | Hansch et al. 1995
Log K_oc_ | 1.68 | Borisover and Graber 1997
Vapor pressure
| 5.85×10^−5^ mm Hg at 25°C | Bannan et al. 2017
Henry’s law constant | 2.00×10^−9^ atm-m^3^/mole at 25°C | NLM 2022b
Dissociation constant | 8.36 | NLM 2022b
Autoignition temperature | 400°C | NLM 2022b
Flashpoint | >100°C | NLM 2022b
Flammability limits | No data | NLM 2022b
Conversion factors
ppm (v/v) to mg/m^3^ in air at 20°C | 1 mg/m^3^=0.18 ppm | NLM 2022b
mg/m^3^ to ppm (v/v) in air at 20°C | 1 ppm=5.69 mg/m^3^ | NLM 2022b
Explosive limits | No data | NLM 2022b

Table 4-6 Physical and Chemical Properties of 4-Nitrophenol

Property | Information | Reference
Molecular weight | 139.11 | O’Neil 2006
Color | Colorless to slightly yellow | O’Neil 2006
Physical state | Solid | NLM 2022c
Melting point | 113–114°C | O’Neil 2006
Boiling point | 279°C | Lewis 2007
Density: At 20°C | 1.479 g/cm^3^ | Lewis 2007
Odor | Odorless | O’Neil 2006
Odor threshold:
Water | 2.5 mg/L | Verschueren 1983
Air | 2.3 mg/m^3^
Taste threshold | 43.4 mg/L | NLM 2022c
Solubility:
Water | 10,000 mg/L at 15°C | Verschueren 1983
Water | 15,600 mg/L at 25°C | Yalkowsky et al. 2010
Organic solvent(s) | Very soluble in ethanol, ether, and acetone; freely soluble in alcohol, chloroform; soluble in solution of fixed alkali hydroxides and carbonates | Haynes et al. 2015; O’Neil 2006
Partition coefficients:
Log K_ow_ | 1.91 | Hansch et al. 1995
Log K_oc_ | 2.37 | Schüürmann et al. 2006
Vapor pressure | 1.2×10^−5^ mm Hg at 25°C | Bannan et al. 2017
Henry’s law constant | 1.28×10^−8^ atm-m^3^/mol at 20°C | Tremp et al. 1993
Dissociation constant | 7.15 | NLM 2022c
Autoignition temperature | 490°C | NLM 2022c
Flashpoint | 169°C | NLM 2022c
Flammability limits | No data | NLM 2022c
Conversion factors
ppm (v/v) to mg/m^3^ in air at 20°C | 1 mg/m^3^=0.173 ppm mg/m^3^ | NLM 2022c
mg/m^3^ to ppm (v/v) in air at 20°C | 1 ppm=5.783 mg/m^3^
Explosive limits | No data | NLM 2022c