# APPENDIX C FRAMEWORK FOR ATSDR’S SYSTEMATIC REVIEW OF HEALTH EFFECTS DATA FOR NITROPHENOLS

To increase the transparency of ATSDR’s process of identifying, evaluating, synthesizing, and interpreting the scientific evidence on the health effects associated with exposure to nitrophenols, ATSDR utilized a slight modification of NTP’s Office of Health Assessment and Translation (OHAT) systematic review methodology (NTP 2013, 2015b; Rooney et al. 2014). ATSDR’s framework is an eight-step process for systematic review with the goal of identifying the potential health hazards of exposure to nitrophenols:

- Step 1. Problem Formulation
- Step 2. Literature Search and Screen for Health Effects Studies
- Step 3. Extract Data from Health Effects Studies
- Step 4. Identify Potential Health Effect Outcomes of Concern
- Step 5. Assess the Risk of Bias for Individual Studies
- Step 6. Rate the Confidence in the Body of Evidence for Each Relevant Outcome
- Step 7. Translate Confidence Rating into Level of Evidence of Health Effects
- Step 8. Integrate Evidence to Develop Hazard Identification Conclusions

## C.1 PROBLEM FORMULATION

The objective of the toxicological profile and this systematic review was to identify the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to nitrophenols. The inclusion criteria used to identify relevant studies examining the health effects of nitrophenols are presented in Table C-1.

Data from human and laboratory animal studies were considered relevant for addressing this objective. Human studies were divided into two broad categories: observational epidemiology studies and controlled exposure studies. The observational epidemiology studies were further divided: cohort studies (retrospective and prospective studies), population studies (with individual data or aggregate data), and case-control studies.

Table C-1 Inclusion Criteria for Identifying Health Effects Studies

Species
Human
Laboratory mammals
Route of exposure
Inhalation
Oral
Dermal (or ocular)
Parenteral (these studies will be considered supporting data)
Health outcome
Death
Systemic effects
Body weight effects
Respiratory effects
Cardiovascular effects
Gastrointestinal effects
Hematological effects
Musculoskeletal effects
Hepatic effects
Renal effects
Dermal effects
Ocular effects
Endocrine effects
Immunological effects
Neurological effects
Reproductive effects
Developmental effects
Other noncancer effects
Cancer

## C.2 LITERATURE SEARCH AND SCREEN FOR HEALTH EFFECTS STUDIES

A literature search and screen were conducted to identify studies examining the health effects of nitrophenols. The literature search framework for the toxicological profile is discussed in detail in Appendix B.

### C.2.1 Literature Search

As noted in Appendix B, the current literature search was intended to update the Draft Toxicological Profile for Nitrophenols released for public comment in 2022. See Appendix B for the databases searched and the search strategy.

A total of 1,205 records relevant to all sections of the toxicological profile were identified (after duplicate removal).

### C.2.2 Literature Screening

As described in Appendix B, a two-step process was used to screen the literature search to identify relevant studies examining the health effects of nitrophenols.

Title and Abstract Screen. In the Title and Abstract Screen step, 1,205 records were reviewed; 2 documents were considered to meet the health effects inclusion criteria in Table C-1 and were moved to the next step in the process.

Full Text Screen. In the second step in the literature screening process for the systematic review, a full text review of 23 health effect documents (documents identified in the update literature search and documents cited in older versions of the profile) was performed. From those 23 documents, 34 studies were included in the qualitative review.

## C.3 EXTRACT DATA FROM HEALTH EFFECTS STUDIES

Relevant data extracted from the individual studies selected for inclusion in the systematic review were collected in customized data forms. A summary of the type of data extracted from each study is presented in Table C-2. For references that included more than one experiment or species, data extraction records were created for each experiment or species.

Table C-2 Data Extracted From Individual Studies

Citation
Chemical form
Route of exposure (e.g., inhalation, oral, dermal)
Specific route (e.g., gavage in oil, drinking water)
Species
Strain
Exposure duration category (e.g., acute, intermediate, chronic)
Exposure duration
Frequency of exposure (e.g., 6 hours/day, 5 days/week)
Exposure length
Number of animals or subjects per sex per group
Dose/exposure levels
Parameters monitored
Description of the study design and method
Summary of calculations used to estimate doses (if applicable)
Summary of the study results
Reviewer’s comments on the study
Outcome summary (one entry for each examined outcome)
No-observed-adverse-effect level (NOAEL) value
Lowest-observed-adverse-effect level (LOAEL) value
Effect observed at the LOAEL value

A summary of the extracted data for each study is presented in the Supplemental Document for Nitrophenols and overviews of the results of the inhalation, oral, and dermal exposure studies are presented in Sections 2.2–2.18 of the profile and in the Levels of Significant Exposures tables in Section 2.1 of the profile (Tables 2-1, 2-2, and 2-3, respectively).

## C.4 IDENTIFY POTENTIAL HEALTH EFFECT OUTCOMES OF CONCERN

No relevant human studies that examined the health effects of exposure to nitrophenols were identified. Overviews of the potential health effect outcomes for 2- and 4-nitrophenol identified in animal studies are presented in Tables C-3 and C-4, respectively. Data for 2-nitrophenol are limited to a single inhalation study evaluating a comprehensive set of endpoints and three oral studies evaluating limited endpoints, and data for 3-nitrophenol are limited to two acute lethality studies. Therefore, available data for 2- and 3-nitrophenol are inadequate to support systematic review. For 4-nitrophenol, animal studies examined a comprehensive set of endpoints following inhalation, oral, or dermal exposure. Body weight effects following oral exposure, hematological effects (methemoglobinemia) following inhalation exposure, and ocular effects (irritation, corneal opacity, cataracts) were considered sensitive outcomes (i.e., effects were observed at low concentrations or doses). Studies examining these potential outcomes following 4-nitrophenol were carried through to Steps 4–8 of the systematic review. There were 18 studies (published in 14 documents) examining these potential outcomes carried through to Steps 4–8 of the systematic review for 4-nitrophenol.

Table C-3 Overview of the Health Outcomes for 2-Nitrophenol Evaluated in Experimental Animal Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological^a^ | Neurological^a^ | Reproductive^a^ | Developmental | Other Noncancer | Caner
Inhalation studies
Acute-duration
Intermediate-duration | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | | 1 | 1 | 1
Intermediate-duration | | 1
Chronic-duration
Oral studies
Acute-duration | 1 | | | | | | | | | | | | | 1
Acute-duration | | | | | | | | | | | | | | 1
Intermediate-duration
Chronic-duration
Dermal studies
Acute-duration
Intermediate-duration
Chronic-duration
Number of studies examining endpoint | | | | 0 | 1 | 2 | 3 | 4 | 5-9 | ≥10
Number of studies reporting outcome | | | | 0 | 1 | 2 | 3 | 4 | 5-9 | ≥10

a Number of studies examining endpoint includes study evaluating histopathology, but not evaluating function.

Table C-4 Overview of the Health Outcomes for 4-Nitrophenol Evaluated in Experimental Animal Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological^a^ | Neurological^a^ | Reproductive^a^ | Developmental | Other Noncancer | Caner
Inhalation studies
Acute-duration | 3 | 2 | 2 | 2 | 3 | | 2 | 2 | 2 | 1 | 2 | 2 | 2 | 2
Acute-duration | 1 | 1 | | | 2 | | | | | 1 | | 1 | 1
Intermediate-duration | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1
Intermediate-duration | | | | | | | | | | 1
Chronic-duration
Oral studies
Acute-duration | 8 | 1 | | 2 | 2 | | 2 | 2 | | | 2 | 2 | 2 | 5 | 4
Acute-duration | 3 | 1 | | 2 | | | 2 | | | | | | 1
Intermediate-duration | 2 | 2 | 2 | 2 | 1 | 1 | 2 | 2 | 1 | 1 | 2 | 2 | 3 | 2 | 1
Intermediate-duration | | 2 | | | | | 1 | 1 | | | | | 3
Chronic-duration
Dermal studies
Acute-duration | | | | | | | | | 3 | 2
Acute-duration | | | | | | | | | 3 | 2
Intermediate-duration | 1 | | 1 | | | | 1 | 1 | 1 | | | | 1 | 1 | 1 | | 2
Intermediate-duration | | | | | | | | | 1
Chronic-duration | 1 | 1 | 1 | 1 | | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | | | 1
Number of studies examining endpoint | | | | 0 | 1 | 2 | 3 | 4 | 5-9 | ≥10
Number of studies reporting outcome | | | | 0 | 1 | 2 | 3 | 4 | 5-9 | ≥10

a Number of studies examining endpoint includes study evaluating histopathology, but not evaluating function.

## C.5 ASSESS THE RISK OF BIAS FOR INDIVIDUAL STUDIES

### C.5.1 Risk of Bias Assessment

The risk of bias of individual studies was assessed using OHAT’s Risk of Bias Tool (NTP 2015a). The risk of bias questions for observational epidemiology studies, human-controlled exposure studies, and animal experimental studies are presented in Tables C-5, C-6, and C-7, respectively. Each risk of bias question was answered on a four-point scale:

- Definitely low risk of bias (++)
- Probably low risk of bias (+)
- Probably high risk of bias (−)
- Definitely high risk of bias (− −)

In general, “definitely low risk of bias” or “definitely high risk of bias” were used if the question could be answered with information explicitly stated in the study report. If the response to the question could be inferred, then “probably low risk of bias” or “probably high risk of bias” responses were typically used.

Table C-5 Risk of Bias Questionnaire for Observational Epidemiology Studies

Selection bias; Were the comparison groups appropriate?
Confounding bias; Did the study design or analysis account for important confounding and modifying variables?
Attrition/exclusion bias; Were outcome data complete without attrition or exclusion from analysis?
Detection bias; Is there confidence in the exposure characterization?; Is there confidence in outcome assessment?
Selective reporting bias; Were all measured outcomes reported?

Table C-6 Risk of Bias Questionnaire for Human-Controlled Exposure Studies

Selection bias; Was administered dose or exposure level adequately randomized?; Was the allocation to study groups adequately concealed?
Performance bias; Were the research personnel and human subjects blinded to the study group during the study?
Attrition/exclusion bias; Were outcome data complete without attrition or exclusion from analysis?
Detection bias; Is there confidence in the exposure characterization?; Is there confidence in outcome assessment?
Selective reporting bias; Were all measured outcomes reported?

Table C-7 Risk of Bias Questionnaire for Experimental Animal Studies

Selection bias; Was administered dose or exposure level adequately randomized?; Was the allocation to study groups adequately concealed?
Performance bias; Were experimental conditions identical across study groups?; Were the research personnel blinded to the study group during the study?
Detection bias; Is there confidence in the exposure characterization?; Is there confidence in outcome assessment?
Selective reporting bias; Were all measured outcomes reported?

After the risk of bias questionnaires were completed for the health effects studies, the studies were assigned to one of three risk of bias tiers based on the responses to the key questions listed below and the responses to the remaining questions.

- Is there confidence in the exposure characterization? (only relevant for observational studies)
- Is there confidence in the outcome assessment?
- Does the study design or analysis account for important confounding and modifying variables? (only relevant for observational studies)

First Tier. Studies placed in the first tier received ratings of “definitely low” or “probably low” risk of bias on the key questions AND received a rating of “definitely low” or “probably low” risk of bias on the responses to at least 50% of the other applicable questions.

Second Tier. A study was placed in the second tier if it did not meet the criteria for the first or third tiers.

Third Tier. Studies placed in the third tier received ratings of “definitely high” or “probably high” risk of bias for the key questions AND received a rating of “definitely high” or “probably high” risk of bias on the response to at least 50% of the other applicable questions.

The results of the risk of bias assessment for the animal experimental studies of nitrophenols health effects studies are presented in Table C-8.

Table C-8 Summary of Risk of Bias Assessment for 4-Nitrophenol- Experimental Animal Studies

Reference | Risk of bias criteria and ratings | | | | | | | | Risk of bias tier
Reference | Selection bias | | Performance bias | | Attrition/exclusion bias | | Detection bias | Selective reporting bias | Risk of bias tier
Reference | Was administered dose or exposure level adequately randomized? | Was the allocation to study groups adequately concealed? | Were experimental conditions identical across study groups? | Were the research personnel blinded to the study group during the study? | Were outcome data complete without attrition or exclusion from analysis? | Is there confidence in the exposure characterization? | Is there confidence in the outcome assessment?^*^ | Were all measured outcomes reported? | Risk of bias tier
Outcome: Hematological effects (inhalation only)
Inhalation acute exposure
Smith et al. 1988 (rat, lethal study) | − | − | + | − | + + | − | − | + | Third
Smith et al. 1988 (rat, subacute 1) | − | − | + | + | + + | − | + + | + | Second
Smith et al. 1988 (rat, subacute 2) | − | − | + | + | + + | − | + + | + | Second
Inhalation intermediate exposure
Hazleton 1983 (rat) | + + | + | + | + | + + | + + | + + | + + | First
Outcome: Ocular effects
Inhalation acute exposure
Smith et al. 1988 (rat, lethal study) | − | − | + | − | + + | − | + | + | Second
Smith et al. 1988 (rat, subacute 1) | − | − | + | − | + + | − | + | + | Second
Smith et al. 1988 (rat, subacute 2) | − | − | + | − | + + | − | + | + | Second
Inhalation intermediate exposure
Hazleton 1983 (rat) | + + | + | + | − | + + | + + | + + | + + | First
Oral intermediate exposure
Hazleton 1989 (rat) | + + | + | + + | − | + + | + + | + + | + + | First
Dermal acute exposure (instillation into the eye)
EPA 1992b (rabbit) | + | − − | + | − − | + + | + + | + | + + | Second
Monsanto 1983a (rabbit) | + | − − | + | − − | + + | + + | + | + + | Second
Dermal chronic exposure
NTP 1993 (mouse) | + | + | + | + | − | + + | + | + + | First
Outcome: Body weight effects (oral only)
Oral Acute exposure
Abu-Qare et al. 2000 (maternal rat) | − | + | + | + | + + | + + | + | + + | First
EPA 1992a (maternal rat) | + | + | + | + | + + | + + | + | + + | First
Kavlock 1990 (maternal rat) | − | + | + | + | + + | + | + + | + + | First
Koizumi et al. 2001 (rat, 14-day) | + | + | + | + | + + | + | + + | − | First
Li et al. 2019; Tang et al. 2016 (rat, 1-day) | + | + | + | + | + + | + + | + + | + + | First
Li et al. 2019; Tang et al. 2016 (rat, 3-day) | + | + | + | + | + + | + + | + + | + + | First
Plasterer et al. 1985 (mouse) | − | + + | + | + | + + | + | + | + + | First
Plasterer et al. 1985 (maternal mouse) | + | + + | + | + | + + | + | + | + | First
Oral intermediate exposure
Hazleton 1989 (rat) | + + | + | + + | + | + + | + + | + + | + + | First
Koizumi et al. 2001 (rat, 28-day) | + | + | + | + | + + | + | + + | + + | First

* Key question used to assign risk of bias tier

## C.6 RATE THE CONFIDENCE IN THE BODY OF EVIDENCE FOR EACH RELEVANT OUTCOME

Confidences in the bodies of human and animal evidence were evaluated independently for each potential outcome. ATSDR did not evaluate the confidence in the body of evidence for carcinogenicity; rather, the Agency defaulted to the cancer weight-of-evidence assessment of other agencies including HHS, EPA, and IARC. The confidence in the body of evidence for an association or no association between exposure to nitrophenols and a particular outcome was based on the strengths and weaknesses of individual studies. Four descriptors were used to describe the confidence in the body of evidence for effects or when no effect was found:

- High confidence: the true effect is highly likely to be reflected in the apparent relationship
- Moderate confidence: the true effect may be reflected in the apparent relationship
- Low confidence: the true effect may be different from the apparent relationship
- Very low confidence: the true effect is highly likely to be different from the apparent relationship

Confidence in the body of evidence for a particular outcome was rated for each type of study: case-control, case series, cohort, population, human-controlled exposure, and experimental animal. In the absence of data to the contrary, data for a particular outcome were collapsed across animal species, routes of exposure, and exposure durations. If species (or strain), route, or exposure duration differences were noted, then the data were treated as separate outcomes.

### C.6.1 Initial Confidence Rating

In ATSDR’s modification to the OHAT approach, the body of evidence for an association (or no association) between exposure to nitrophenols and a particular outcome was given an initial confidence rating based on the key features of the individual studies examining that outcome. The presence of these key features of study design was determined for individual studies using four “yes or no” questions, which were customized for epidemiology, human controlled exposure, or experimental animal study designs. Separate questionnaires were completed for each outcome assessed in a study. The key features for observational epidemiology (cohort, population, and case-control) studies, human controlled exposure, and experimental animal studies are presented in Tables C-9, C-10, and C-11, respectively. The initial confidence in the study was determined based on the number of key features present in the study design:

- High Initial Confidence: Studies in which the responses to the four questions were “yes”.
- Moderate Initial Confidence: Studies in which the responses to only three of the questions were “yes”.
- Low Initial Confidence: Studies in which the responses to only two of the questions were “yes”.
- Very Low Initial Confidence: Studies in which the response to one or none of the questions was “yes”.

Table C-9 Key Features of Study Design for Observational Epidemiology Studies

Exposure was experimentally controlled
Exposure occurred prior to the outcome
Outcome was assessed on individual level rather than at the population level
A comparison group was used

Table C-10 Key Features of Study Design for Human-Controlled Exposure Studies

A comparison group was used or the subjects served as their own control
A sufficient number of subjects were tested
Appropriate methods were used to measure outcomes (i.e., clinically-confirmed outcome versus selfreported)
Appropriate statistical analyses were performed and reported or the data were reported in such a way to allow independent statistical analysis

Table C-11 Key Features of Study Design for Experimental Animal Studies

A concurrent control group was used
A sufficient number of animals per group were tested
Appropriate parameters were used to assess a potential adverse effect
Appropriate statistical analyses were performed and reported or the data were reported in such a way to allow independent statistical analysis

The presence or absence of the key features and the initial confidence levels for studies examining hematological, respiratory, and ocular effects observed in the observational animal experimental studies are presented in Table C-12.

A summary of the initial confidence ratings for each outcome is presented in Table C-12. If individual studies for a particular outcome and study type had different study quality ratings, then the highest confidence rating for the group of studies was used to determine the initial confidence rating for the body of evidence; any exceptions were noted in Table C-13.

Table C-12 Presence of Key Features of Study Design for 4-Nitrophenol—Experimental Animal Studies

Reference | Key features | | | | Initial study confidence
Reference | Concurrent Control Group | Sufficient number of animals per group | Appropriate parameters to assess potential effect | Adequate data for statistical analysis | Initial study confidence
Outcome: Hematological effects (inhalation only)
Inhalation acute exposure
Smith et al. 1988 (rat, lethal study) | No | No | Yes | No | Very Low
Smith et al. 1988 (rat, subacute 1) | Yes | Yes | Yes | No | Moderate
Smith et al. 1988 (rat, subacute 2) | Yes | Yes | Yes | No | Moderate
Inhalation intermediate exposure
Hazleton 1983 (rat) | Yes | No | Yes | Yes | Moderate
Outcome: Ocular effects
Inhalation acute exposure
Smith et al. 1988 (rat, lethal study) | No | Yes | Yes | Yes | Moderate
Smith et al. 1988 (rat, subacute 1) | Yes | Yes | Yes | No | Moderate
Smith et al. 1988 (rat, subacute 2) | Yes | Yes | Yes | No | Moderate
Inhalation intermediate exposure
Hazleton 1983 (rat) | Yes | Yes | Yes | Yes | High
Oral intermediate exposure
Hazleton 1989 (rat) | Yes | Yes | Yes | Yes | High
Dermal acute exposure (instillation into the eye)
EPA 1992b (rabbit) | Yes | Yes | Yes | No | Moderate
Monsanto 1983a (rabbit) | Yes | Yes | Yes | No | Moderate
Dermal chronic exposure
NTP 1993 (mouse) | Yes | Yes | Yes | Yes | High
Outcome: Body weight effects (oral only)
Oral acute exposure
Abu-Qare et al. 2000 (maternal rat) | Yes | No | Yes | No | Low
EPA 1992a (maternal rat) | Yes | Yes | Yes | No | Moderate
Kavlock 1990 (maternal rat) | Yes | Yes | Yes | Yes | High
Koizumi et al. 2001 (rat, 14-day) | Yes | Yes | Yes | No | Moderate
Li et al. 2019; Tang et al. 2016 (rat, 1-day) | Yes | Yes | Yes | Yes | High
Li et al. 2019; Tang et al. 2016 (rat, 3-day) | Yes | Yes | Yes | Yes | High
Plasterer et al. 1985 (mouse) | Yes | Yes | Yes | Yes | High
Plasterer et al. 1985 (maternal mouse) | Yes | Yes | Yes | Yes | High
Oral intermediate exposure
Hazleton 1989 (rat) | Yes | Yes | Yes | Yes | High
Koizumi et al. 2001 (rat, 28-day) | Yes | No | Yes | Yes | Moderate

Table C-13 Initial Confidence Rating for 4-Nitrophenol Health Effects Studies

| Initial study confidence | Initial confidence rating
Outcome: Hematological effects
Inhalation acute exposure
Smith et al. 1988 (rat, lethal study) | Very Low | Moderate
Smith et al. 1988 (rat, subacute 1) | Moderate | Moderate
Smith et al. 1988 (rat, subacute 2) | Moderate | Moderate
Inhalation intermediate exposure
Hazleton 1983 (rat) | Moderate | Moderate
Outcome: Ocular effects
Inhalation acute exposure
Smith et al. 1988 (rat, lethal study) | Moderate | Moderate
Smith et al. 1988 (rat, subacute 1) | Moderate | Moderate
Smith et al. 1988 (rat, subacute 2) | Moderate | Moderate
Inhalation intermediate exposure
Hazleton 1983 (rat) | High | High
Oral intermediate exposure
Hazleton 1989 (rat) | High | High
Dermal acute exposure (instillation into the eye)
EPA 1992b (rabbit) | Moderate | Moderate
Monsanto 1983a | Moderate | Moderate
Dermal chronic exposure
NTP 1993 (mouse) | High | High
Outcome: Body weight effects (oral only)
Oral acute exposure
Abu-Qare et al. 2000 (maternal rat) | Low | High
EPA 1992a (maternal rat) | Moderate | High
Kavlock 1990 (maternal rat) | High | High
Koizumi et al. 2001 (rat, 14-day) | Moderate | High
Li et al. 2019; Tang et al. 2016 (rat, 1-day) | High | High
Li et al. 2019; Tang et al. 2016 (rat, 3-day) | High | High
Plasterer et al. 1985 (mouse) | High | High
Plasterer et al. 1985 (maternal mouse) | High | High
Oral intermediate exposure
Hazleton 1989 (rat) | High | High
Koizumi et al. 2001 (rat, 28-day) | Moderate | High

### C.6.2 Adjustment of the Confidence Rating

The initial confidence rating was then downgraded or upgraded depending on whether there were substantial issues that would decrease or increase confidence in the body of evidence. The nine properties of the body of evidence that were considered are listed below. The summaries of the assessment of the confidence in the body of evidence for hematological, ocular, and respiratory effects are presented in Table C-14. If the confidence ratings for a particular outcome were based on more than one type of human study, then the highest confidence rating was used for subsequent analyses. An overview of the confidence in the body of evidence for all health effects associated with nitrophenols exposure is presented in Table C-15.

Table C-14 Adjustments to the Initial Confidence in the Body of Evidence in Experimental Studies

| Initial confidence | Adjustments to the initial confidence rating | Final confidence rating
Outcome: Hematological Effects (inhalation only)
Animal studies | Moderate | -1 risk of bias | Low
Outcome: Ocular Effects
Animal studies | High | -1 risk of bias | Moderate
Outcome: Body weight Effects
Animal studies | High | -1 unexplained inconsistency, -1 publication bias | Low

Table C-15 Confidence in the Body of Evidence for 4 -Nitrophenol

Outcome | Confidence in body of evidence
Outcome | Human studies | Animal studies
Hematological effects | No data | Low
Ocular effects | No data | Moderate
Body weight effects | No data | Low

Five properties of the body of evidence were considered to determine whether the confidence rating should be downgraded:

- Risk of bias. Evaluation of whether there is substantial risk of bias across most of the studies examining the outcome. This evaluation used the risk of bias tier groupings for individual studies examining a particular outcome (Tables C-5, C-6, and C-7). Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for risk of bias:
  ○ No downgrade if most studies are in the risk of bias first tier
  ○ Downgrade one confidence level if most studies are in the risk of bias second tier
  ○ Downgrade two confidence levels if most studies are in the risk of bias third tier
- Unexplained inconsistency. Evaluation of whether there is inconsistency or large variability in the magnitude or direction of estimates of effect across studies that cannot be explained. Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for unexplained inconsistency:
  ○ No downgrade if there is little inconsistency across studies or if only one study evaluated the outcome
  ○ Downgrade one confidence level if there is variability across studies in the magnitude or direction of the effect
  ○ Downgrade two confidence levels if there is substantial variability across studies in the magnitude or direct of the effect
- Indirectness. Evaluation of four factors that can affect the applicability, generalizability, and relevance of the studies:
  ○ Relevance of the animal model to human health—unless otherwise indicated, studies in rats, mice, and other mammalian species are considered relevant to humans
  ○ Directness of the endpoints to the primary health outcome—examples of secondary outcomes or nonspecific outcomes include organ weight in the absence of histopathology or clinical chemistry findings in the absence of target tissue effects
  ○ Nature of the exposure in human studies and route of administration in animal studies— inhalation, oral, and dermal exposure routes are considered relevant unless there are compelling data to the contrary
  ○ Duration of treatment in animal studies and length of time between exposure and outcome assessment in animal and prospective human studies—this should be considered on an outcome-specific basis
  Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for indirectness:
  ○ No downgrade if none of the factors are considered indirect
  ○ Downgrade one confidence level if one of the factors is considered indirect
  ○ Downgrade two confidence levels if two or more of the factors are considered indirect
- Imprecision. Evaluation of the narrowness of the effect size estimates and whether the studies have adequate statistical power. Data are considered imprecise when the ratio of the upper to lower 95% CIs for most studies is ≥10 for tests of ratio measures (e.g., odds ratios) and ≥100 for absolute measures (e.g., percent control response). Adequate statistical power is determined if the study can detect a potentially biologically meaningful difference between groups (20% change from control response for categorical data or risk ratio of 1.5 for continuous data). Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for imprecision:
  ○ No downgrade if there are no serious imprecisions
  ○ Downgrade one confidence level for serious imprecisions
  ○ Downgrade two confidence levels for very serious imprecisions
- Publication bias. Evaluation of the concern that studies with statistically significant results are more likely to be published than studies without statistically significant results.
  ○ Downgrade one level of confidence for cases where there is serious concern with publication bias

Four properties of the body of evidence were considered to determine whether the confidence rating should be upgraded:

- Large magnitude of effect. Evaluation of whether the magnitude of effect is sufficiently large so that it is unlikely to have occurred due to bias from potential confounding factors.
  ○ Upgrade one confidence level if there is evidence of a large magnitude of effect in a few studies, provided that the studies have an overall low risk of bias and there is no serious unexplained inconsistency among the studies of similar dose or exposure levels; confidence can also be upgraded if there is one study examining the outcome, provided that the study has an overall low risk of bias
- Dose response. Evaluation of the dose-response relationships measured within a study and across studies. Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level for evidence of a monotonic dose-response gradient
  ○ Upgrade one confidence level for evidence of a non-monotonic dose-response gradient where there is prior knowledge that supports a non-monotonic dose-response, and a non-monotonic dose-response gradient is observed across studies
- Plausible confounding or other residual biases. This factor primarily applies to human studies and is an evaluation of unmeasured determinants of an outcome such as residual bias towards the null (e.g., “healthy worker” effect) or residual bias suggesting a spurious effect (e.g., recall bias). Below is the criterion used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level for evidence that residual confounding or bias would underestimate an apparent association or treatment effect (i.e., bias toward the null) or suggest a spurious effect when results suggest no effect
- Consistency in the body of evidence. Evaluation of consistency across animal models and species, consistency across independent studies of different human populations and exposure scenarios, and consistency across human study types. Below is the criterion used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level if there is a high degree of consistency in the database

## C.7 TRANSLATE CONFIDENCE RATING INTO LEVEL OF EVIDENCE OF HEALTH EFFECTS

In the seventh step of the systematic review of the health effects data for nitrophenols, the confidence in the body of evidence for specific outcomes was translated to a level of evidence rating. The level of evidence rating reflected the confidence in the body of evidence and the direction of the effect (i.e., toxicity or no toxicity); route-specific differences were noted. The level of evidence for health effects was rated on a five-point scale:

- High level of evidence: High confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Moderate level of evidence: Moderate confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Low level of evidence: Low confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Evidence of no health effect: High confidence in the body of evidence that exposure to the substance is not associated with the health outcome
- Inadequate evidence: Low or moderate confidence in the body of evidence that exposure to the substance is not associated with the health outcome OR very low confidence in the body of evidence for an association between exposure to the substance and the health outcome

A summary of the level of evidence of health effects for nitrophenols is presented in Table C-16.

Table C-16 Level of Evidence of Health Effects for 4 -Nitrophenol

Outcome | Confidence in body of evidence | Direction of health effect | Level of evidence for health effect
Human studies
Hematological effects | No data | | No data
Ocular effects | No data | | No data
Body weight effects | No data | | No data
Animal studies
Hematological effects | Low | Health effect | Low
Ocular Effects | Moderate | Health effect | Moderate
Body weight effects | Low | Health effect | Low

## C.8 INTEGRATE EVIDENCE TO DEVELOP HAZARD IDENTIFICATION CONCLUSIONS

The final step involved the integration of the evidence streams for the human studies and animal studies to allow for a determination of hazard identification conclusions. For health effects, there were four hazard identification conclusion categories:

- Known to be a hazard to humans
- Presumed to be a hazard to humans
- Suspected to be a hazard to humans
- Not classifiable as to the hazard to humans

The initial hazard identification was based on the highest level of evidence in the human studies and the level of evidence in the animal studies; if there were no data for one evidence stream (human or animal), then the hazard identification was based on the one data stream (equivalent to treating the missing evidence stream as having low level of evidence). The hazard identification scheme is presented in Figure C-1 and described below:

- Known: A health effect in this category would have:
  ○ High level of evidence for health effects in human studies AND a high, moderate, or low level of evidence in animal studies.
- Presumed: A health effect in this category would have:
  ○ Moderate level of evidence in human studies AND high or moderate level of evidence in animal studies OR
  ○ Low level of evidence in human studies AND high level of evidence in animal studies
- Suspected: A health effect in this category would have:
  ○ Moderate level of evidence in human studies AND low level of evidence in animal studies OR
  ○ Low level of evidence in human studies AND moderate level of evidence in animal studies
- Not classifiable: A health effect in this category would have:
  ○ Low level of evidence in human studies AND low level of evidence in animal studies

Figure C-1 Hazard Identification Scheme

Figure C-1 description

Other relevant data such as mechanistic or mode-of-action data were considered to raise or lower the level of the hazard identification conclusion by providing information that supported or opposed biological plausibility.

Two hazard identification conclusion categories were used when the data indicated that there may be no health effect in humans:

- Not identified to be a hazard in humans
- Inadequate to determine hazard to humans

If the human level of evidence conclusion of no health effect was supported by the animal evidence of no health effect, then the hazard identification conclusion category of “not identified” was used. If the human or animal level of evidence was considered inadequate, then a hazard identification conclusion category of “inadequate” was used. As with the hazard identification for health effects, the impact of other relevant data was also considered for no health effect data.

The hazard identification conclusions for nitrophenols are listed below and summarized in Table C-17.

Suspected Health Effects

- Ocular effects
  ○ No human data regarding ocular effects following exposure to 4-nitrophenol.
  ○ Moderate evidence from animal studies that examine acute- and intermediate-duration inhalation exposure of 4-nitrophenol show changes in ocular function, including corneal opacity, as well as unilateral and bilateral diffused anterior capsular cataracts (Hazleton 1983; Smith et al. 1988). Severe eye irritation, inflammation, neovascularization, visible destruction of iris, and corneal opacity have been observed in rabbits following direct ocular exposure to 4-nitrophenol (EPA 1992b; Monsanto 1983a). It is likely that the ocular effects noted in inhalation studies are due to direct ocular contact with dust particles in the air. No ocular effects were observed following oral or dermal exposure to 4-nitrophenol (Hazleton 1989; NTP 1993).

Not Classifiable

- Hematological effects following inhalation exposure
  ○ No human studies evaluating hematological endpoints following inhalation exposure to 4-nitrophenol were identified.
  ○ Low evidence of hematological effects, specifically methemoglobinemia, in laboratory animals due to moderate risk of bias in the study reporting methemoglobinemia following acute inhalation exposure to high concentrations of 4-nitrophenol (Smith et al. 1988). An intermediate-duration inhalation study did not observe methemoglobinemia in rats (Hazleton 1983). This apparent inconsistency may be due to exposure at comparatively lower concentrations by Hazleton (1984), compared to Smith et al. (1988), or due to study design issues.
- Body weight effects following oral exposure
  ○ No human studies evaluating body weight following inhalation exposure to 4-nitrophenol were identified.
  ○ Low evidence of body weight effects in laboratory animals due to unexplained inconsistencies across studies and exposure durations. Some acute-duration studies reported decreased body weights (EPA 1992a; Li et a. 2017; Plasterer et al. 1985; Tang et al. 2016), while others did not (Abu-Qare et al. 2000; Kavlock 1990; Koizumi et al. 2001). Body weight effects were not noted in intermediate-duration studies (Hazleton 1989; Koizumi et al. 2001). Additionally, body weight effects are often subjected to publication bias due to lack of reporting in the absence of adverse effects.

Table C-17 Hazard Identification Conclusions for 4 - Nitrophenol

Outcome | Hazard identification
Ocular effects | Suspected health effect
Hematological effects (inhalation only) | Health effect not classifiable
Body weight effects (oral only) | Health effect not classifiable