# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemicalinduced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substances than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Office of Innovation and Analytics, Toxicology Section, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Office of Innovation and Analytics, Toxicology Section, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S102-1, Atlanta, Georgia 30329-4027.

## 2-Nitrophenol Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2-Nitrophenol
CAS Numbers: | 88-75-5
Date: | April 2023
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL.

Rationale for Not Deriving an MRL: An MRL was not derived for acute inhalation exposure (≤14 days) to 2-nitrophenol. No adequately conducted studies were identified that investigated health effects of 2-nitrophenol for this route and duration.

Agency Contacts (Chemical Managers): Brittany Szafran, D.V.M., Ph.D.

## 2-Nitrophenol Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2-Nitrophenol
CAS Numbers: | 88-75-5
Date: | April 2023
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL.

Rationale for Not Deriving an MRL: An MRL was not derived for intermediate inhalation exposure (15–364 days) to 2-nitrophenol. In the only available intermediate-duration inhalation study evaluating 2-nitrophenol, the only adverse effect noted in rats exposed intermittently for 4 weeks was increased incidence of squamous metaplasia of the nasal epithelium observed in both male and female rats at ≥32.5 mg/m^3^ (Hazleton 1984). Although the Hazleton (1984) is a well-conducted study, the study on its own is not strong enough to support the derivation of an MRL. No adverse respiratory effects were noted in acute or inhalation studies evaluating 4-nitrophenol (Hazleton 1983; Smith et al. 1988), and respiratory effects noted following oral exposure to 4-nitrophenol are limited to clinical signs of respiratory distress associated with lethal doses (Branch et al. 1983b; Hazleton 1989). This lack of supporting literature precludes the derivation of an MRL for this route and duration. The relevant NOAEL and LOAEL values are presented in Table A-1.

Table A-1 Summary of Relevant NOAEL and LOAEL Values Following Intermediate-Duration Inhalation Exposure to 2-Nitrophenol

Species | Duration/route | NOAEL (NOAEL_ADJ_) (mg/m^3^) | LOAEL (LOAEL_ADJ_) (mg/m^3^) | Effect | Reference
Respiratory effects
Sprague-Dawley rat | 4 weeks; 5 days/week; 6 hours/day | 5 (0.89) | 32.5 (5.8) | Increased incidence of squamous metaplasia of the nasal epithelium | Hazleton 1984

Adjusted daily dose = I n t e r m i t t e n t d o s e × (E x p o s u r e h o u r s)/(24 h o u r s) × (E x p o s u r e d a y s)/(7 d a y s)

ADJ = adjusted; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level

Agency Contacts (Chemical Managers): Brittany Szafran, D.V.M., Ph.D.

## 2-Nitrophenol Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2-Nitrophenol
CAS Numbers: | 88-75-5
Date: | April 2023
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL.

Rationale for Not Deriving an MRL: An MRL was not derived for chronic inhalation exposure (≥365 days) to 2-nitrophenol. No adequately conducted studies were identified that investigated health effects of 2-nitrophenol for this route and duration.

Agency Contacts (Chemical Managers): Brittany Szafran, D.V.M., Ph.D.

## 2-Nitrophenol Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2-Nitrophenol
CAS Numbers: | 88-75-5
Date: | April 2023
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL as the most sensitive endpoint is represented by a serious effect.

Rationale for Not Deriving an MRL: Available acute-duration oral studies are limited to acute lethality studies in rats and mice (Vernot et al. 1977) and a gestational exposure study in rats (Laughlin et al. 1983). The reported LD_50_ values in rats and mice were 620 and 1,300 mg/kg, respectively (Vernot et al. 1977). The only observed health effect following maternal exposure on GDs 6–15 was a 1.9-fold increase in post implantation loss at 1,000 mg/kg/day, compared to control rats (Laughlin et al. 1983). Since the most sensitive adverse effect reported following acute oral exposure to 2-nitrophenol was death, this precludes the derivation of an acute-duration oral MRL (ATSDR 2018).

Agency Contacts (Chemical Managers): Brittany Szafran, D.V.M., Ph.D.

## 2-Nitrophenol Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2-Nitrophenol
CAS Numbers: | 88-75-5
Date: | April 2023
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration oral MRL.

Rationale for Not Deriving an MRL: No adequately conducted studies were identified that investigated health effects of 2-nitrophenol for this route and duration.

Agency Contacts (Chemical Managers): Brittany Szafran, D.V.M., Ph.D.

## 2-Nitrophenol Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2-Nitrophenol
CAS Numbers: | 88-75-5
Date: | April 2023
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL.

Rationale for Not Deriving an MRL: No adequately conducted studies were identified that investigated health effects of 2-nitrophenol for this route and duration.

Agency Contacts (Chemical Managers): Brittany Szafran, D.V.M., Ph.D.

## 3-Nitrophenol Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 3-Nitrophenol
CAS Numbers: | 554-84-7
Date: | April 2023
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL.

Rationale for Not Deriving an MRL: No adequately conducted studies were identified that investigated health effects of 3-nitrophenol for this route and duration.

Agency Contacts (Chemical Managers): Brittany Szafran, D.V.M., Ph.D.

## 3-Nitrophenol Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 3-Nitrophenol
CAS Numbers: | 554-84-7
Date: | April 2023
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL.

Rationale for Not Deriving an MRL: No adequately conducted studies were identified that investigated health effects of 3-nitrophenol for this route and duration.

Agency Contacts (Chemical Managers): Brittany Szafran, D.V.M., Ph.D.

## 3-Nitrophenol Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 3-Nitrophenol
CAS Numbers: | 554-84-7
Date: | April 2023
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL.

Rationale for Not Deriving an MRL: No adequately conducted studies were identified that investigated health effects of 3-nitrophenol for this route and duration.

Agency Contacts (Chemical Managers): Brittany Szafran, D.V.M., Ph.D.

## 3-Nitrophenol Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 3-Nitrophenol
CAS Numbers: | 554-84-7
Date: | April 2023
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL.

Rationale for Not Deriving an MRL: Available data are limited to an acute lethality study reporting LD_50_ values of 930 and 1,410 mg/kg in rats and mice, respectively (Vernot et al. 1977). These data are not appropriate to support derivation of an acute-duration oral MRL for 3-nitrophenol.

Agency Contacts (Chemical Managers): Brittany Szafran, D.V.M., Ph.D.

## 3-Nitrophenol Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 3-Nitrophenol
CAS Numbers: | 554-84-7
Date: | April 2023
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration oral MRL.

Rationale for Not Deriving an MRL: No adequately conducted studies were identified that investigated health effects of 3-nitrophenol for this route and duration.

Agency Contacts (Chemical Managers): Brittany Szafran, D.V.M., Ph.D.

## 3-Nitrophenol Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 3-Nitrophenol
CAS Numbers: | 554-84-7
Date: | April 2023
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL.

Rationale for Not Deriving an MRL: No adequately conducted studies were identified that investigated health effects of 3-nitrophenol for this route and duration.

Agency Contacts (Chemical Managers): Brittany Szafran, D.V.M., Ph.D.

## 4-Nitrophenol Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 4-Nitrophenol
CAS Numbers: | 100-02-7
Date: | April 2023
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL.

Rationale for Not Deriving an MRL: Inhalation data following acute-duration exposure to 4-nitrophenol are limited to three separate studies from a single report by Smith et al. (1988). The only adverse effects reported in this study include corneal opacity after a 4-hour exposure to 4,059 mg/m^3^ and increased methemoglobin observed in rats at ≥112 mg/m^3^ following exposure for 2 weeks (Smith et al. 1988). The relevant NOAELs and LOAELs are presented in Table A-2.

A systematic review of the literature was performed for both health effects (see details in Appendix C). This review determined that hematological effects following inhalation exposure to 4-nitrophenol are not classifiable as health effects due to no data in humans and a low level of evidence from animal studies. Therefore, data are inadequate to support selection of methemoglobinemia as the critical effect for MRL derivation. While it was determined that ocular effects are a suspected health effect of 4-nitrophenol, it is likely that observed effects are due to direct ocular contact with dust particles, rather than a systemic effect. This is supported by evidence of ocular effects, including corneal opacity, in rabbits following direct ocular instillation with 4-nitrophenol (EPA 1992b; Monsanto 1983a) and lack of ocular effects following oral or dermal exposure to 4-nitrophenol (Hazleton 1989; NTP 1993). Therefore, this critical effect is not considered appropriate as the basis for an inhalation MRL.

Table A-2 Summary of Relevant NOAEL and LOAEL Values Following Acute-Duration Oral Exposure to 4-Nitrophenol

Species | Duration/route | NOAEL (mg/m^3^) | LOAEL (mg/m^3^) | Effect | Reference
Hematological effects
Crl:CD rat | 2 weeks; 5 days/week; 6 hours/day | ND | 294 | Methemoglobin increased from 0.2% (in controls) to 0.87% | Smith et al. 1988
Crl:CD rat | 2 weeks; 5 days/week; 6 hours/day | 26 | 112 | Methemoglobin increased from 0.5% (in controls) to 1.5% | Smith et al. 1988
Ocular effects
Crl:CD Rat | 4 hours | 1,304 | 4,059 (Serious LOAEL) | Corneal opacity | Smith et al. 1988

LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level

Agency Contacts (Chemical Managers): Brittany Szafran, D.V.M., Ph.D.

## 4-Nitrophenol Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 4-Nitrophenol
CAS Numbers: | 100-02-7
Date: | April 2023
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL as the most sensitive endpoint is represented by a serious effect.

Rationale for Not Deriving an MRL: Hazleton (1983) was the only adequately conducted study identified for intermediate-duration inhalation exposures to 4-nitrophenol. The only observed health effect in rats after exposure to 4-nitrophenol for 4 weeks was unilateral and bilateral diffused anterior capsular cataracts at 29.18 mg/m^3^. While a systematic review of the evidence (Appendix C) determined that ocular effects are a suspected health effect of 4-nitrophenol, it is likely that observed effects are due to direct ocular contact with dust particles, rather than a systemic effect. This is supported by evidence of ocular effects, including corneal opacity, in rabbits following direct ocular instillation with 4-nitrophenol (EPA 1992b; Monsanto 1983a) and lack of ocular effects following oral or dermal exposure to 4-nitrophenol (Hazleton 1989; NTP 1993). Therefore, this critical effect is not considered appropriate as the basis for an inhalation MRL.

Agency Contacts (Chemical Managers): Brittany Szafran, D.V.M., Ph.D.

## 4-Nitrophenol Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 4-Nitrophenol
CAS Numbers: | 100-02-7
Date: | April 2023
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL.

Rationale for Not Deriving an MRL: No adequately conducted studies were identified that investigated health effects of 4-nitrophenol for this route and duration.

Agency Contacts (Chemical Managers): Brittany Szafran, D.V.M., Ph.D.

## 4-Nitrophenol Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 4-Nitrophenol
CAS Numbers: | 100-02-7
Date: | April 2023
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL.

Rationale for Not Deriving an MRL: The most sensitive endpoint following acute-duration oral exposure to 4-nitrophenol is decreased maternal body weight gain in rats exposed to 27.6 mg/kg/day on GDs 6–15 (EPA 1992a). However, there are inconsistencies in body weight findings following acute-duration oral exposure (Table A-3). A systematic review of the evidence determined that body weight effects are not classifiable as a health effect following oral exposure due to no data in humans and low evidence in laboratory animals (see Appendix C for details). Therefore, it is not appropriate to base the MRL on maternal body weight effects reported by EPA (1992a).

The next most sensitive endpoint is dyspnea and increased mortality at 171 mg/kg in an acute lethality study (Branch et al. 1983b). Due to observed lethality, this precludes the derivation of an acute-duration oral MRL at this dose or based on any effect observed at higher doses (ATSDR 2018).

Table A-3 NOAEL and LOAEL Values for Body Weight Effects Following Acute-Duration Oral Exposure to 4-nitrophenol

Species | Duration | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Sprague-Dawley rat | 10 days; GDs 6-15 | 13.8 | 27.6 | 12% decrease in maternal body weight | EPA 1992a
Sprague-Dawley rat | Once; GD 14, 15, 16, 17, or 18 | 100 | ND | | Abu-Qare et al. 2000
Sprague-Dawley rat | Once; GD 11 | 1,000 | ND | | Kavlock 1990
Wistar rat | Once | 200 | ND | | Li et al. 2017; Tang et al. 2016
Wistar rat | 3 days | ND | 200 Serious LOAEL | 25% decrease in body weight gain | Li et al. 2017; Tang et al. 2016
Sprague-Dawley rat | 14 days | 200 | ND | | Koizumi et al. 2001
CD-1 mouse | 8 days; GDs 7–14 | ND | 400 | 18% decrease in maternal body weight gain | Plasterer et al. 1985
CD-1 mouse | 8 days | 1,000 | ND | | Plasterer et al. 1985

GD = gestational day; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level

Agency Contacts (Chemical Managers): Brittany Szafran, D.V.M., Ph.D.

## 4-Nitrophenol Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 4-Nitrophenol
CAS Numbers: | 100-02-7
Date: | April 2023
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration oral MRL.

Rationale for Not Deriving an MRL: The most sensitive effects observed following intermediate-duration oral exposure to 4-nitrophenol included increased mortality preceded by wheezing, dyspnea, and prostration at 140 mg/kg/day (Hazleton 1989). Due to observed lethality, this precludes the derivation of an intermediate-duration oral MRL at this dose or based on any effects observed at higher doses (ATSDR 2018).

Agency Contacts (Chemical Managers): Brittany Szafran, D.V.M., Ph.D.

## 4-Nitrophenol Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 4-Nitrophenol
CAS Numbers: | 100-02-7
Date: | April 2023
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL.

Rationale for Not Deriving an MRL: No adequately conducted studies were identified that investigated health effects of 4-nitrophenol for this route and duration.

Agency Contacts (Chemical Managers): Brittany Szafran, D.V.M., Ph.D.