# CHAPTER 8 REFERENCES

Agrawal A, Gutch M, Arora R, . 2011. Acute cardiogenic pulmonary oedema with multiorgan dysfunction-still to learn more about nitrobenzene poisoning. BMJ Case Rep 2011:5026. 10.1136/bcr.10.2011.5026.
Albrecht W, Neumann HG. 1985. Biomonitoring of aniline and nitrobenzene: hemoglobin-binding in rats and analysis of adducts. Arch Toxicol 57(1):1–5. 10.1007/BF00286566.4015392
Allenby G, Sharpe RM, Foster PM. 1990. Changes in Sertoli cell function in vitro induced by nitrobenzene. Fundam Appl Toxicol 14(2):364–375. 10.1016/0272-0590(90)90216-7.2108073
Allenby G, Foster PM, Sharpe RM. 1991. Evaluation of changes in the secretion of immunoactive inhibin by adult rat seminiferous tubules in vitro as an indicator of early toxicant action on spermatogenesis. Fundam Appl Toxicol 16(4):710–724. 10.1093/toxsci/16.4.710.1653159
Aly FAE, Salman AS, Hassan ZM. 2014. Evaluation of the antimutagenic effect of pomegranate seed oil against genotoxicity induced by nitrobenzene in mice. Glob J Pharmacol 8(2):189–195. 10.5829/idosi.gjp.2014.8.2.82270.
Anderson D, Styles JA. 1978. The bacterial mutation test. Six tests for carcinogenicity. Br J Cancer 37(6):924–930. 10.1038/bjc.1978.134.354673
Ashurst JV, Wasson MN, Hauger W, . 2010. Pathophysiologic mechanisms, diagnosis, and management of dapsone-induced methemoglobinemia. J Am Osteopath Assoc 110(1):16–20. 10.7556/jaoa.2010.110.1.16.20093649
Ask K, Décologne N, Asare N, . 2004. Distribution of nitroreductive activity toward nilutamide in rat. Toxicol Appl Pharmacol 201(1):1–9. 10.1016/j.taap.2004.04.006.15519603
Aspinall R, Andrew D. 2000. Thymic involution in aging. J Clin Immunol 20(4):250–256. 10.1023/A:1006611518223.10939712
Assmann N, Emmrich M, Kampf G, . 1997. Genotoxic activity of important nitrobenzenes and nitroanilines in the Ames test and their structure-activity relationship. Mutat Res 395(2–3):139–144. 10.1016/S1383-5718(97)00158-7.9465924
Astier A. 1992. Simultaneous high-performance liquid chromatographic determination of urinary metabolites of benzene, nitrobenzene, toluene, xylene and styrene. J Chromatogr 573(2):318–322. 10.1016/0378-4347(92)80136-e.1601967
ATSDR. 2022a. Nitrobenzene. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/SPL/resources. June 21, 2023.
ATSDR. 2022b. Shower and household water-use exposure (SHOWER) model v3.0 user’s guide [and search results]. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
Baby RE, Cabezas M, Walsöe de Reca EN. 2000. Electronic nose: a useful tool for monitoring environmental contamination. Sens Actuators B Chem 69(3):214–218. 10.1016/S0925-4005(00)00491-3.
Balwani MR, Bawankule CP, Ramteke V, . 2017. Methylene blue induced methemoglobinemia with acute kidney injury in a glucose-6-phosphate dehydrogenase-deficient patient. Indian J Nephrol 27(6):465–467.29217886
Bao Y, Huang Q, Li Y, . 2012. Prediction of nitrobenzene toxicity to the algae (Scenedesmus obliguus) by quantitative structure–toxicity relationship (QSTR) models with quantum chemical descriptors. Environ Toxicol Pharmacol 33(1):39–45. 10.1016/j.etap.2011.09.003.22088683
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486. 10.1016/0273-2300(88)90047-5.3222488
Barr DB, Turner WE, DiPietro E, . 2002. Measurement of p-nitrophenol in the urine of residents whose homes were contaminated with methyl parathion. Environ Health Perspect 110(Suppl 6):1085–1091. 10.1289/ehp.02110s61085.12634145
Bidleman TF. 1988. Atmospheric processes. Environ Sci Technol 22(4):361–367. 10.1021/es00169a002.
Biodynamics. 1983. A range finding study to evaluate the toxicity of nitrobenzene in the pregnant rabbit. Bio/dynamics Inc. Project Number 83-2723.
Biodynamics. 1984. An inhalation teratology study in rabbits with nitrobenzene (final report). Bio/dynamics Incorporated. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0510651. 408424492. 47004H1A1. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0510651.xhtml. October 28, 2022.
Bojar RM, Rastegar H, Payne DD, . 1987. Methemoglobinemia from intravenous nitroglycerin: a word of caution. Ann Thorac Surg 43(3):332–334. 10.1016/S0003-4975(10)60627-3.3103557
Bonacker D, Stoiber T, Böhm KJ, . 2004. Chromosomal genotoxicity of nitrobenzene and benzonitrile. Arch Toxicol 78(1):49–57. 10.1007/s00204-003-0508-1.14513206
Bonnefoy A, Chiron S, Botta A. 2012. Environmental nitration processes enhance the mutagenic potency of aromatic compounds. Environ Toxicol 27(6):321–331. 10.1002/tox.20644.20737582
Booth G. 2012. Nitro compounds, aromatic. In: Ullmann’s Encyclopedia of industrial chemistry. Vol. 23. 6^th^ ed. Weinham, Germany: VCH Verlagsgesellschaft, 131.
Boukobza M, Garnier R, Cleophax C, . 2015. CT and MRI findings and follow-up after massive nitrobenzene ingestion. A case report. J Neurol Sci 357(1–2):322–325. 10.1016/j.jns.2015.07.039.26248705
Bozzelli JW, Kebbekus BB. 1982. A study of some aromatic and halocarbon vapors in the ambient atmosphere of New Jersey. J Environ Sci Health A17(5):693–711. 10.1080/10934528209375072.
Briggs GG. 1981. Theoretical and experimental relationships between soil adsorption, octanol-water partition coefficients, water solubilities, bioconcentration factors, and the parachor. J Agric Food Chem 29(5):1050–1059. 10.1021/jf00107a040.
Bronaugh RL, Maibach HI. 1985. Percutaneous absorption of nitroaromatic compounds: in vivo and in vitro studies in the human and monkey. J Invest Dermatol 84(3):180–183. 10.1111/1523-1747.ep12264716.3919108
Budavari S. 1983. Nitrobenzene. In: Merck index: an encyclopedia of chemicals, drugs, and biologicals. 10^th^ ed. Rahway, NJ: Merck & Co., 6437.
Burns LA, Bradley SG, White KL, . 1994. Immunotoxicity of nitrobenzene in female B6C3F1 mice. Drug Chem Toxicol 17(3):271–315. 10.3109/01480549409017862.7988385
Butterworth BE, Smith-Oliver T, Earle L, . 1989. Use of primary cultures of human hepatocytes in toxicology studies. Cancer Res 49(5):1075–1084.2917345
Canton JH, Slooff W, Kool HJ, . 1985. Toxicity, biodegradability, and accumulation of a number of Cl/N-containing compounds for classification and establishing water quality criteria. Regul Toxicol Pharmacol 5(2):123–131. 10.1016/0273-2300(85)90026-1.4023284
Carreón T, Hein MJ, Hanley KW, . 2014. Bladder cancer incidence among workers exposed to o-toluidine, aniline and nitrobenzene at a rubber chemical manufacturing plant. Occup Environ Med 71(3):175–182. 10.1136/oemed-2013-101873.24368697
Carter FW. 1936. An unusual case of poisoning, with some notes on non-alkaloidal organic substances. Med J Aust 2(17):558–564. 10.5694/j.1326-5377.1936.tb106628.x.
Castle L, Philo MR, Sharman M. 2004. The analysis of honey samples for residues of nitrobenzene and petroleum from the possible use of Frow mixture in hives. Food Chem 84(4):643–649. 10.1016/j.foodchem.2003.07.027.
Cattley RC, Everitt JI, Gross EA, . 1994. Carcinogenicity and toxicity of inhaled nitrobenzene in B6C3F1 mice and F344 and CD rats. Fundam Appl Toxicol 22(3):328–340. 10.1006/faat.1994.1039.8050629
Cattley RC, Everitt JI, Gross EA, . 1995. Erratum: Carcinogenicity and toxicity of inhaled nitrobenzene in B6C3F1 mice and F344 and CD rats [Fundam Appl Toxicol 22(3):328-340]. Fundam Appl Toxicol 25:159. 10.1006/faat.1994.1039.
CDC. 2021a. Fourth report on human exposure to environmental chemicals. Updated tables, March 2021. Volume one: NHANES 1999-2010. Atlanta, GA: Centers for Disease Control and Prevention. https://www.cdc.gov/exposurereport/index.html. November 1, 2022.
CDC. 2021b. Fourth report on human exposure to environmental chemicals. Updated tables, March 2021. Volume two: NHANES 2011-2016. Atlanta, GA: Centers for Disease Control and Prevention. https://www.cdc.gov/exposurereport/index.html. November 1, 2022.
Chang MJ, Kao GI, Tsai CT. 1993. Biological monitoring of exposure to low dose aniline, p-aminophenol, and acetaminophen. Bull Environ Contam Toxicol 51(4):494–500. 10.1007/BF00192163.8400650
Chen Y, Wang M, Fu H, . 2019. Spectroscopic and molecular modeling investigation on inhibition effect of nitroaromatic compounds on acetylcholinesterase activity. Chemosphere 236:124365. 10.1016/j.chemosphere.2019.124365.31325829
Chiu C, Lee L, Wang C, . 1978. Mutagenicity of some commercially available nitro compounds for Salmonella typhimurium. Mutat Res 58(1):11–22. 10.1016/0165-1218(78)90090-3.362191
Chongtham DS, Phurailatpam J, Singh MM, . 1997. Methaemoglobinemia in nitrobenzene poisoning. J Postgrad Med 43(3):73–74.10740728
Chou WL, Speece RE, Siddiqui RH. 1978. Acclimation and degradation of petrochemical wastewater components by methane fermentation. Biotechnol Bioeng Symp 8:391–414.
CIIT. 1993. Initial submission: A chronic inhalation toxicity study of nitrobenzene in B6CF1 mice, Fischer 344 rats and Sprague-Dawley (CD) rats. First Chemical Corporation. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0538399. 88930000170. 8EHQ02938723. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0538399.xhtml. November 9, 2022.
Clark DA, De La Garza M. 1967. Species differences in methemoglobin levels produced by administration of monomethylhydrazine. Proc Soc Exp Biol Med 125(3):912–916. 10.3181/00379727-125-32238.15938299
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131. 10.1177/074823378500100408.3843496
CMR. 1987. Chemical profiles: Nitrobenzene. Chem Mark Rep
Cole RH, Frederick RE, Healy RP, . 1984. Preliminary findings of the priority pollutant monitoring project of the nationwide urban runoff program. J Water Pollut Control Fed 56(7):898–908.
Dai Y, Mihara Y, Tanaka S, . 2010a. Nitrobenzene-adsorption capacity of carbon materials released during the combustion of woody biomass. J Hazard Mater 174(1–3):776–781. 10.1016/j.jhazmat.2009.09.119.19853376
Dai Y, Terui N, Lin Y, . 2010b. Determination of nitrobenzene in water and ice samples collected from the Songhua River after an explosion of a petrochemical plant and investigation on enclosing behavior of nitrobenzene into ice. Anal Sci 26(4):519–523. 10.2116/analsci.26.519.20410580
Dangwal SK, Jethani BM. 1980. A simple method of determination of nitrobenzene and nitrochlorobenzene in air and urine. Am Ind Hyg Assoc J 41(11):847–850. 10.1080/15298668091425752.7457378
Dasgupta A, Matos J, Muramatsu H, . 2018. Nanostructured carbon materials for enhanced nitrobenzene adsorption: Physical vs. chemical surface properties. Carbon 139:833–844. 10.1016/j.carbon.2018.07.045.
Davis B. 2012. Endometrial stromal polyps in rodents: biology, etiology, and relevance to disease in women. Toxicol Pathol 40(3):419–424. 10.1177/0192623311431466.22215514
Davis EM, Murray HE, Liehr JG, . 1981. Basic microbial degradation rates and chemical byproducts of selected organic compounds. Water Res 15(9):1125–1127.
Davis EM, Turley JE, Casserly DM, . 1983. Partitioning of selected organic pollutants in aquatic ecosystems. In: Oxley TA, Barry S, eds. Biodeterioration. John Wiley & Sons, 176–184.
Dellarco VL, Prival MJ. 1989. Mutagenicity of nitro compounds in salmonella typhimurium in the presence of flavin mononucleotide in a preincubation assay. Environ Mol Mutagen 13:116–127. 10.1002/em.2850130206.2645131
DeSesso JM, Scialli AR. 2018. Bone development in laboratory mammals used in developmental toxicity studies. Birth Defects Res 110(15):1157–1187. 10.1002/bdr2.1350.29921029
Dodd DE, Fowler EH, Snellings WM, . 1987. Reproduction and fertility evaluations in CD rats following nitrobenzene inhalation. Fundam Appl Toxicol 8(4):493–505. 10.1016/0272-0590(87)90135-7.3609536
DOE. 2018a. Table 3: Protective action criteria (PAC) rev. 29a based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. June 2018. U.S. Department of Energy. https://edms3.energy.gov/pac/docs/Revision_29A_Table3.pdf. July 6, 2022.
DOE. 2018b. Protective action criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29A, June 2018. U.S. Department of Energy. https://edms3.energy.gov/pac/. July 6, 2022.
Dong J, Zhao Y, Zhao R, . 2010. Effects of pH and particle size on kinetics of nitrobenzene reduction by zero-valent iron. J Environ Sci (China) 22(11):1741–1747. 10.1016/s1001-0742(09)60314-4.21235162
Draper WM, Crosby DG. 1984. Solar photooxidation of pesticides in dilute hydrogen peroxide. J Agric Food Chem 32(2):231–237. 10.1021/jf00122a014.
D’sa SR, Victor P, Jagannati M, . 2014. Severe methemoglobinemia due to ingestion of toxicants. Clin Toxicol 52(8):897–900. 10.3109/15563650.2014.947377.
Dsouza D, Baddala R, Sharath Kumar GG, . 2022. MRI brain features in nitrobenzene toxic encephalopathy. Ann Indian Acad Neurol 25(2):267–268. 10.4103/aian.aian_497_21.35693641
Dunlap KL. 1981. Nitrobenzene and nitrotoluenes. In: Grayson M, Eckroth D, eds. Kirk Othmer encyclopedia of chemical technology. John Wiley and Sons, Inc, 3916–3932.
Dupont. 1981. Initial submission: Acute inhalation toxicity of benzene, nitro in male Crl:Cd rats with cover letter dated 090292. E.I. du Pont de Nemours & Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8. OTS0570970. 88920009220. 8EHQ099210932. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0570970.xhtml. January 18, 2023.
Ellis DD, Jone CM, Larson RA, . 1982. Organic constituents of mutagenic secondary effluents from wastewater treatment plants. Arch Environ Contam Toxicol 11(3):373–382. 10.1007/BF01055214.7103563
EPA. 1976. Air pollution assessment of nitrobenzene. McLean, VA: U.S. Environmental Protection Agency. PB257776. MTR-7228.
EPA. 1978. Quantification of chlorinated hydrocarbons in previously collected air samples. Research Triangle Park, NC: U.S. Environmental Protection Agency. PB289804. EPA600778062. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB289804.xhtml. November 9, 2022.
EPA. 1979a. Identification of organic compounds in industrial effluent discharges. Athens, GA: Environmental Protection Agency. EPA600479016. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9101LV4K.txt. November 9, 2022.
EPA. 1979b. Biodegradation and treatability of specific pollutants. Washington, DC: U.S. Environmental Protection Agency. PB80106438. EPA600979034. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB80106438.xhtml. November 9, 2022.
EPA. 1979c. Sources of toxic pollutants found in influents to sewage treatment plants: VI. Integrated interpresentation. Washington, DC: U.S. Environmental Protection Agency. PB81219685. EPA440481008. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9101UZJP.txt. January 17, 2023.
EPA. 1980a. Ambient water quality criteria for nitrobenzene: The Division. Washington, DC: U.S. Environmental Protection Agency. EPA440580061. https://www.epa.gov/sites/default/files/2019-03/documents/ambient-wqc-nitrobenzene-1980.pdf. January 18, 2023.
EPA. 1980b. Fate of toxic and hazardous materials in the air environment. Research Triangle Park, NC: US Environmental Protection Agency. PB80221948. EPA6003680084. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB80221948.xhtml. November 9, 2022.
EPA. 1981. Economic impact analysis of proposed test rule for dichloromethane, 1,1,1-trichloroethane, and nitobenzene: Support document proposed test rule, Toxic Substances Control Act, Section 4. Washington, DC: U.S. Environmental Protection Agency. EPA560281004. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=91003821.txt. November 9, 2022.
EPA. 1982a. Exposure analysis model system (EXAMS): User manual and system documentation. Athens, GA: U.S. Environmental Protection Agency. PB82258096. EPA600382023. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB82258096.xhtml. November 9, 2022.
EPA. 1982b. Aquatic fate process data for organic priority pollutants. Washington, DC: U.S. Environmental Protection Agency. EPA440481014. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9100O12M.txt. January 18, 2023.
EPA. 1982c. Test methods: Methods for organic chemical analysis of municipal and industrial wastewater. Cincinnati, OH: U.S. Environmental Protection Agency. EPA600482057. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=2000ATB1.txt. November 9, 2022.
EPA. 1983. Treatability manual: Volume I. Treatability data. Washington, DC: U.S. Environmental Protection Agency. EPA600282001A. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=30005R3P.txt. November 9, 2022.
EPA. 1984a. Validation of chemical and biological techniques for evaluation of vapors in ambient air/mutagenicity testing of twelve (12) vapor-phase compounds. Research Triangle Park, NC: U.S. Environmental Protection Agency. PB84164219. EPA6001684005. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB84164219.xhtml. July 10, 2023.
EPA. 1984b. Nitrobenzene: Decision to withdraw a proposed rule. U.S. Environmental Protection Agency. Fed Regist 49(119):25013–25016. https://www.govinfo.gov/app/details/FR-1984-06-19. January 18, 2023.
EPA. 1984c. Hazardous air pollutants: Wet removal rates and mechanisms. Research Triangle Park, NC: U.S. Environmental Protection Agency. PB85138626. EPA600384113. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB85138626.xhtml. November 9, 2022.
EPA. 1985. Health and environmental effects profile for nitrobenzene. U.S. Environmental Protection Agency. PB688180500. EPA600X685365. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB88180500.xhtml. November 9, 2022.
EPA. 1986a. Method 8270: Gas chromatography/mass spectrometry for semivolatile organics: Capillary column technique. Washington, DC: U.S. Environmental Protection Agency.
EPA. 1986b. Method 8090: Nitroaromatics and cyclic ketones. Washington, DC: U.S. Environmental Protection Agency. SW846.
EPA. 1986c. Method 8250: Gas chromatography/mass spectrometry for semivolatile organics: Packed column technique. Washington, DC: U.S. Environmental Protection Agency.
EPA. 1988. Land disposal restrictions for first third schedule wastes. U.S. Environmental Protection Agency. Fed Regist 53(159):31138–31222. https://www.govinfo.gov/app/details/FR-1988-08-17. January 18, 2023.
EPA. 1989. Land disposal restrictions for second third schedule wastes. U.S. Environmental Protection Agency. Fed Regist 54(7):1056–1119. https://www.govinfo.gov/app/details/FR-1989-01-11. January 18, 2023.
EPA. 1994. Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry. Washington, DC: U.S. Environmental Protection Agency. EPA600890066F. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=30001K4C.txt. November 9, 2022.
EPA. 2003. First unregulated contaminant monitoring rule data. U.S. Environmental Protection Agency. https://www.epa.gov/dwucmr/first-unregulated-contaminant-monitoring-rule. November 9, 2022.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. EPA260B05001. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P100EI4V.txt. November 9, 2022.
EPA. 2009a. Toxicological review of nitrobenzene. U.S. Environmental Protection Agency. PB2009108276. EPA635R08004F. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB2009108276.xhtml. November 9, 2022.
EPA. 2009b. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency. EPA816F09004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. August 2, 2019.
EPA. 2012. Estimation Programs Interface Suite™ for Microsoft® Windows, v 4.11. Washington, DC: U.S. Environmental Protection Agency. https://www.epa.gov/tsca-screening-tools/epi-suitetm-estimation-program-interface. September 26, 2022.
EPA. 2014. Method 8410: Gas chromatography/fourier transform infrared spectrometry for semivolatile organics: Capillary column. Washington, DC: U.S. Environmental Protection Agency. https://www.epa.gov/sites/default/files/2015-12/documents/8410.pdf. January 18, 2023.
EPA. 2017. National emission inventory (NEI) data. U.S. Environmental Protection Agency. https://www.epa.gov/air-emissions-inventories/2017-national-emissions-inventory-nei-data. October 18, 2022.
EPA. 2018a. 2018 Edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency. EPA822F18001. https://www.epa.gov/system/files/documents/2022-01/dwtable2018.pdf. June 15, 2022.
EPA. 2018b. Compiled AEGL values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2018-08/documents/compiled_aegls_update_27jul2018.pdf. April 12, 2020.
EPA. 2022. Nitrobenzene. 2020 Chemical data reporting (CDR) data. U.S. Environmental Protection Agency. https://www.epa.gov/chemical-data-reporting/access-cdr-data. November 16, 2022.
Ewert R, Buttgereit F, Prügel M, . 1998. Intravenous injection of India ink with suicidal intent. Int J Legal Med 111(2):91–92. 10.1007/s004140050122.9541858
Facchini V, Griffiths LA. 1981. The involvement of the gastro-intestinal microflora in nitro-compound-induced methaemoglobinaemia in rats and its relationship to nitrogroup reduction. Biochem Pharmacol 30(9):931–935. 10.1016/0006-2952(81)90036-8.7236314
FDA. 2022. Substances added to food. U.S. Food and Drug Administration. https://www.cfsanappsexternal.fda.gov/scripts/fdcc/?set=FoodSubstances. January 24, 2022.
Feldmann RJ, Maibach HI. 1970. Absorption of some organic compounds through the skin in man. J Invest Dermatol 54(5):399–404.4245370
Francis GJ, Langford VS, Milligan DB, . 2009. Real-time monitoring of hazardous air pollutants. Anal Chem 81(4):1595–1599. 10.1021/ac802510h.19159214
Freitag D, Geyer H, Kraus A, . 1982. Ecotoxicological profile analysis: VII. Screening chemicals for their environmental behavior by comparative evaluation. Ecotoxicol Environ Saf 6(1):60–81. 10.1016/0147-6513(82)90081-1.6802631
Fritz H, Hess R. 1970. Ossification of the rat and mouse skeleton in the perinatal period. Teratology 3(4):331–338. 10.1002/tera.1420030409.5538530
Fu W, Fu H, Skøtt K, . 2008. Modeling the spill in the Songhua River after the explosion in the petrochemical plant in Jilin. Environ Sci Pollut Res Int 15(3):178–181. 10.1065/espr2007.11.457.18504834
Garner RC, Nutman CA. 1977. Testing of some azo dyes and their reduction products for mutagenicity using Salmonella typhimurium TA 1538. Mutat Res 44(1):9–19. 10.1016/0027-5107(77)90110-5.331098
Gatermann R, Huehnerfuss H, Rimkus G, . 1995. The distribution of nitrobenzene and other nitroaromatic compounds in the North Sea. Mar Pollut Bull 30(3):221–227. 10.1016/0025-326X(94)00161-2.
Goldfrank L, Lewin N, Flomenbaum N, . 1998. Methemoglobin Inducers. In: Goldfrank’s Toxicologic emergencies. Vol. 11. 6^th^ ed. New York, NY: McGraw-Hill Professional Publishing,
Goldstein RS, Rickert DE. 1984. Macromolecular covalent binding of [14C] nitrobenzene in the erythrocyte and spleen of rats and mice. Chem-Biol Interact 50(1):27–37. 10.1016/0009-2797(84)90129-7.6733803
Goldstein A, Aronow L, Kalman SM. 1969. Nitrobenzene. In: Principles of drug action: The basis of pharmacology. New York, NY: Hoeber Medical Division, Harper & Row, 434–452.
Goldstein RS, Chism JP, Hamm TJ. 1984. Influence of diet on intestinal microfloral metabolism and toxicity of nitrobenzene [abstract]. Toxicologist 4:143.
Gomółka E, Gomółka B. 1979. Ability of activated sludge to degrade nitrobenzene in municipal wastewater. Acta Hydrochim Hydrobiol 7(6):605–622. 10.1002/aheh.19790070609.
Gosselin RE, Smith RP, Hodge HC, . 1984. Nitrobenzene. In: Clinical toxicology of commercial products. 5^th^ ed. Baltimore, MD: Williams and Wilkins, 11–214.
Greer FR, Shannon M. 2005. Infant methemoglobinemia: the role of dietary nitrate in food and water. Pediatrics 116(3):784–786. 10.1542/peds.2005-1497.16140723
Gu D, Shao N, Zhu Y, . 2017. Solar-driven thermo- and electrochemical degradation of nitrobenzene in wastewater: Adaptation and adoption of solar STEP concept. J Hazard Mater 321:703–710. 10.1016/j.jhazmat.2016.09.069.27710892
Gupta G, Poddar B, Salaria M, . 2000. Acute nitrobenzene poisoning. Indian Pediatr 37(10):1147–1148.11042725
Gupta A, Jain N, Agrawal A, . 2012. A fatal case of severe methaemoglobinemia due to nitrobenzene poisoning. Emerg Med J 29(1):70–71. 10.1136/emj.07.2011.4431rep.22186264
Hallas LE, Alexander M. 1983. Microbial transformation of nitroaromatic compounds in sewage effluent. Appl Environ Microbiol 45(4):1234–1241. 10.1128/aem.45.4.1234-1241.1983.6859845
Hamm TE, Gibson JE, Irons RD, . 1984. Ninety day inhalation toxicity study of nitrobenzene in F-344 rats, and CD rats and B6C3F1 mice with cover letter. Chemical Industry Institute of Technology. Submitted to the U.S. Environmental Protection Agency under section 8D. OTS0206507. 878214291. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0206507.xhtml. January 18, 2023.
Hanley KW, Viet SM, Hein MJ, . 2012. Exposure to o-toluidine, aniline, and nitrobenzene in a rubber chemical manufacturing plant: a retrospective exposure assessment update. J Occup Environ Hyg 9(8):478–490. 10.1080/15459624.2012.693836.22708702
Harkov R, Kebbekus B, Bozzelli JW, . 1983. Measurement of selected volatile organic compounds at three locations in New Jersey during the summer season. J Air Pollut Control Assoc 33(12):1177–1183. 10.1080/00022470.1983.10465709.
Harkov R, Kebbekus B, Bozzelli JW, . 1984. Comparison of selected volatile organic compounds during the summer and winter at urban sites in New Jersey. Sci Total Environ 38:259–274. 10.1016/0048-9697(84)90220-1.
Harkov R, Gianti SJ, Bozzelli JW, . 1985. Monitoring volatile organic compounds at hazardous and sanitary landfills in New Jersey. J Environ Sci Health A20(5):491–501. 10.1080/10934528509375237.
Hastings SH, Matsen FA. 1948. The photodecomposition of nitrobenzene. J Am Chem Soc 70(10):3514–3515. 10.1021/ja01190a508.18891915
Haworth S, Lawlor T, Mortelmans K, . 1983. Salmonella mutagenicity test results for 250 chemicals. Environ Mutagen 5(Suppl 1):3–49. 10.1002/em.2860050703.
Haynes W. 2015. Nitrobenzene. In: CRC handbook of chemistry and physics: A ready-reference book of chemical and physical data. 95^th^ ed. Boca Raton, FL: CRC Press, 3–411, 414–410, 416–442, 416–459.
He MC, Sun Y, Li XR, . 2006. Distribution patterns of nitrobenzenes and polychlorinated biphenyls in water, suspended particulate matter and sediment from mid- and down-stream of the Yellow River (China). Chemosphere 65(3):365–374. 10.1016/j.chemosphere.2006.02.033.16580044
Ho CH, Clark BR, Guerin MR, . 1981. Analytical and biological analyses of test materials from the synthetic fuel technologies: IV. Studies of chemical structure-mutagenic activity relationships of aromatic nitrogen compounds relevant to synfuels. Mutat Res 85(5):335–345. 10.1016/0165-1161(81)90224-7.7029261
Holder JW. 1999. Nitrobenzene carcinogenicity in animals and human hazard evaluation. Toxicol Ind Health 15(5):445–457.10487355
Huang Q, Wang L, Han S. 1995. The genotoxicity of substituted nitrobenzenes and the quantitative structure-activity relationship studies. Chemosphere 30(5):915–923. 10.1016/0045-6535(94)00450-9.7712138
Huang QG, Kong LR, Liu YB, . 1996. Relationships between molecular structure and chromosomal aberrations in in vitro human lymphocytes induced by substituted nitrobenzenes. Bull Environ Contam Toxicol 57(3):349–353. 10.1007/s001289900197.8672058
Hurley R, Testa AC. 1966. Photochemical n→π* excitation of nitrobenzene. J Am Chem Soc 88(19):4330–4332. 10.1021/ja00971a005.
Hurley R, Testa AC. 1967. Nitrobenzene photochemistry. II. Protonation in the excited state. J Am Chem Soc 89(26):6917–6919. 10.1021/ja01002a019.
IARC. 1996. Printing processes and printing inks, carbon black and some nitro compounds. IARC monographs on the evaluation of carcinogenic risks to humans: Volume 65. Lyon, France: International Agency for Research on Cancer. https://monographs.iarc.who.int/wp-content/uploads/2018/06/mono65.pdf. November 9, 2022.
IARC. 2019. Agents classified by the IARC monographs. Volumes 1–123. Lyon, France: International Agency for Research on Cancer. https://monographs.iarc.fr/wp-content/uploads/2019/02/List_of_Classifications.pdf. November 9, 2022.
Iida S, Misaka H, Naya M. 1997. A flow cytometric analysis of cytotoxic effects of nitrobenzene on rat spermatogenesis. J Toxicol Sci 22(5):397–407. 10.2131/jts.22.5_397.9442449
Ikeda M, Kita A. 1964. Excretion of p-nitrophenol and p-aminophenol in the urine of a patient exposed to nitrobenzene. Occup Environ Med 21(3):210–213. 10.1136/oem.21.3.210.
IRIS. 2009. Nitrobenzene; CASRN 98-95-3. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. https://iris.epa.gov/static/pdfs/0079_summary.pdf. October 31, 2022.
Jury WA, Spencer WF, Farmer WJ. 1984. Behavior assessment model for trace organics in soil: III. Application of screening model. J Environ Qual 13(4):573–579. 10.2134/jeq1984.00472425001300040013x.
Kamiguchi Y, Tateno H. 2002. Radiation- and chemical-induced structural chromosome aberrations in human spermatozoa. Mutat Res 504(1–2):183–191. 10.1016/s0027-5107(02)00091-x.12106658
Kao AS. 1994. Formation and removal reactions of hazardous air pollutants. J Air Waste Manage Assoc 44(5):683–696. 10.1080/1073161X.1994.10467272.
Kao J, Faulkner J, Bridges JW. 1978. Metabolism of aniline in rats, pigs and sheep. Drug Metab Disposition 6(5):549–555.
Kato M, Makino S, Kimura H, . 2002. Evaluation of mitochondrial function and membrane integrity by dual fluorescent staining for assessment of sperm status in rats. J Toxicol Sci 27(1):11–18. 10.2131/jts.27.11.
Kawaguchi T, Kawachi M, Morikawa M, . 2004. Key parameters of sperm motion in relation to male fertility in rats given alpha-chlorohydrin or nitrobenzene. J Toxicol Sci 29(3):217–231. 10.2131/jts.29.217.15467271
Kawashima K, Usami M, Sakemi K, . 1995. Studies on the establishment of appropriate spermatogenic endpoints for male fertility disturbance in rodent induced by drugs and chemicals. I. Nitrobenzene. J Toxicol Sci 20(1):15–22. 10.2131/jts.20.15.
Kincannon DF, Lin YS. 1985. Microbial degradation of hazardous wastes by land treatment. Proc Indust Waste Conf 40:607–619.
Kincannon DF, Stover EL, Nichols V, . 1983. Removal mechanisms for toxic priority pollutants. J Water Pollut Control Fed 55(2):157–163.
Kissel JC, Curl CL, Kedan G, . 2005. Comparison of organophosphorus pesticide metabolite levels in single and multiple daily urine samples collected from preschool children in Washington State. J Expo Anal Environ Epidemiol 15(2):164–171. 10.1038/sj.jea.7500384.15187987
Kligerman AD, Erexson GL, Wilmer JL, . 1983. Analysis of cytogenetic damage in rat lymphocytes following in vivo exposure to nitrobenzene. Toxicol Lett 18(3):219–226. 10.1016/0378-4274(83)90096-6.6665794
Kopfler FC, Melton RG, Mullaney JL, . 1977. Human exposure to water pollutants. In: Fate of pollutants in the air and water environments; part 2: Chemical and biological fate of pollutants in environment. John Wiley and Sons, 419–433.
Korte F, Klein W. 1982. Degradation of benzene in the environment. Ecotoxicol Environ Saf 6(4):311–327.7117183
Krishnan K, Anderson ME, Clewell HJ, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kudale S, Sethi SK, Dhaliwal M, . 2014. Methemoglobinemia due to quinine causing severe acute kidney injury in a child. Indian J Nephrol 24(6):394–396. 10.4103/0971-4065.134681.25484537
Kumar A, Chawla R, Ahuja S, . 1990. Nitrobenzene poisoning and spurious pulse oximetry. Anaesthesia 45(11):949–951. 10.1111/j.1365-2044.1990.tb14627.x.2252189
Kumar A, Bhavsar C, Aggarwal P, . 2017. Toxic brain injury with nitrobenzene poisoning. Int J Appl Basic Med Res 7(3):207–209. 10.4103/ijabmr.IJABMR_271_16.28904926
LaRegina J, Bozzelli JW, Harkov R, . 1986. Volatile organic compounds at hazardous waste sites and a sanitary landfill in New Jersey: An up-to-date review of the present situation. Environ Prog 5(1):18–27. 10.1002/ep.670050109.
Leader SD. 1932. Nitrobenzene poisoning: report of an unusual case in a child. Arch Pediat 49:245–250.
Lee CH, Kim SH, Kwon DH, . 2013. Two cases of methemoglobinemia induced by the exposure to nitrobenzene and aniline. Ann Occup Environ Med 25(1):31. 10.1186/2052-4374-25-31.24475977
Lei B, Huang S, Qiao M, . 2008. Prediction of the environmental fate and aquatic ecological impact of nitrobenzene in the Songhua River using the modified AQUATOX model. J Environ Sci 20:769–777. 10.1016/S1001-0742(08)62125-7.
Levin AA, Dent JG. 1982. Comparison of the metabolism of nitrobenzene by hepatic microsomes and cecal microflora from Fischer-344 rats in vitro and the relative importance of each in vivo. Drug Metab Dispos 10(5):450–454.6128191
Levin AA, Bosakowski T, Earle LL, . 1988. The reversibility of nitrobenzene-induced testicular toxicity: continuous monitoring of sperm output from vasocystotomized rats. Toxicology 53(2–3):219–230. 10.1016/0300-483X(88)90215-6.3212784
Li H, Cheng Y, Wang H, . 2003a. Inhibition of nitrobenzene-induced DNA and hemoglobin adductions by dietary constituents. Appl Radiat Isot 58:291–298. 10.1016/S0969-8043(02)00315-9.12595006
Li H, Wang H, Sun H, . 2003b. Binding of nitrobenzene to hepatic DNA and hemoglobin at low doses in mice. Toxicol Lett 139(1):25–32. 10.1016/S0378-4274(02)00438-1.12595155
Li P, Yin W, Li P, . 2010. Distribution and migration of nitrobenzene in water following a simulated spill. J Hazard Mater 182(1–3):787–791. 10.1016/j.jhazmat.2010.06.105.20667658
Lide DR. 2005. Nitrobenzene. In: CRC Handbook of chemistry and physics. 85^th^ ed. Boca Raton, FL: CRC Press, 3–424, 423–425, 416–439.
Lin Y, Han X, Lu H, . 2013. Study of archaea community structure during the biodegradation process of nitrobenzene wastewater in an anaerobic baffled reactor. Int Biodeterior Biodegrad 85:499–505. 10.1016/j.ibiod.2013.05.017.
Linder RE, Strader LF, Slott VL, . 1992. Endpoints of spermatotoxicity in the rat after short duration exposures to fourteen reproductive toxicants. Reprod Toxicol 6(6):491–505. 10.1016/0890-6238(92)90034-q.1288759
Lioy PJ, Daisey JM, Atherholt T, . 1983. The New Jersey project on airborne toxic elements and organic substances (ATEOS): a summary of the 1981 summer and 1982 winter studies. J Air Pollut Control Assoc 33(7):649–657. 10.1080/00022470.1983.10465621.
Lo SC, Agar NS. 1986. NADH-methemoglobin reductase activity in the erythrocytes of newborn and adult mammals. Experientia 42(11–12):1264–1265. 10.1007/BF01946415.3780953
Løkke H. 1984. Sorption of selected organic pollutants in Danish soils. Ecotoxicol Environ Saf 8(5):395–409. 10.1016/0147-6513(84)90062-9.6435992
Lopes TJ, Furlong ET. 2001. Occurrence and potential adverse effects of semivolatile organic compounds in streambed sediment, United States, 1992-1995. Environ Toxicol Chem 20(4):727–737. 10.1002/etc.5620200406.11345447
Lu PY, Metcalf RL. 1975. Environmental fate and biodegradability of benzene derivatives as studied in a model aquatic ecosystem. Environ Health Perspect 10:269–284. 10.1289/ehp.7510269.1157796
Ludlow JT, Wilkerson RG, Nappe TM. 2021. StatPearls: Methemoglobinemia [Updated 2021 Sep 2]. Treasure Island, FL: StatPearls Publishing. https://www.ncbi.nlm.nih.gov/books/NBK537317. November 9, 2022.
Lutin PA, Cibulka JJ, Malaney GW. 1965. Oxidation of selected carcinogenic compounds by activated sludge. Eng Bull 49(4):131–145. https://earchives.lib.purdue.edu/digital/collection/engext/id/12321/. January 19, 2023.
Lyman WJ, Reehl WF, Rosenblatt DH. 1990. Nitrobenzene. In: Handbook of chemical property estimation methods: Environmental behavior of organic compounds. Washington, DC: American Chemical Society, 15-11 to 15-29.
Mahmood N, Khan MU, Haq IUL, . 2019. A case of dapsone induced methemoglobinemia. J Pharm Policy Pract 12:22. 10.1186/s40545-019-0185-y.31249693
Mallouh AA, Sarette WO. 1993. Methemoglobinemia induced by topical hair oil. Ann Saudi Med 13(1):78–80. 10.5144/0256-4947.1993.78.17587998
Marion CV, Malaney GW. 1963. Ability of activated sludge microorganisms to oxidize aromatic organic compounds. J Purdue Univ Eng Ext Ser 115:297–308.
Marshall JB, Ecklund RE. 1980. Methemoglobinemia from overdose of nitroglycerin. JAMA 244(4):330. 10.1001/jama.1980.03310040014005.
Martínez MA, Ballesteros S, Almarza E, . 2003. Acute nitrobenzene poisoning with severe associated methemoglobinemia: Identification in whole blood by GC-FID and GC-MS. J Anal Toxicol 27(4):221–225. 10.1093/jat/27.4.221.12820744
Matsumara H, Yoshida T. 1959. Experimental studies of nitrobenzol poisoning. Kyushu J Med Sci 10(6):259–264.
Mattioli F, Martelli A, Gosmar M, . 2006. DNA fragmentation and DNA repair synthesis induced in rat and human thyroid cells by chemicals carcinogenic to the rat thyroid. Mutat Res 609(2):146–153. 10.1016/j.mrgentox.2006.06.028.16942904
McCann KG, Moomey CM, Runkle KD, . 2002. Chicago area methyl parathion response. Environ Health Perspect 110(Suppl 6):1075–1078. 10.1289/ehp.02110s61075.12634143
McCarthy DJ, Waud WR, Struck RF, . 1985. Disposition and metabolism of aniline in Fischer 344 rats and C57BL/6 x C3H F_1_ mice. Cancer Res 45(1):174–180.2578091
McFarlane C, Nolt C, McDowell M, . 1987a. The uptake, distribution and metabolism of four organic chemicals by soybean plants and barley roots. Environ Toxicol Chem 6(11):847–856. 10.1002/etc.5620061104.
McFarlane JC, Pfleeger T, Fletcher J. 1987b. Transpiration effect on the uptake and distribution of bromacil, nitrobenzene, and phenol in soybean plants. J Environ Qual 16(4):372–376. 10.2134/jeq1987.00472425001600040014x.
McLaren TT, Foster PM, Sharpe RM. 1993a. Identification of stage-specific changes in protein secretion by isolated seminiferous tubules from the rat following exposure to either m-dinitrobenzene or nitrobenzene. Fundam Appl Toxicol 21(3):384–392. 10.1093/toxsci/21.3.384.8258392
McLaren TT, Foster PM, Sharpe RM. 1993b. Effect of age on seminiferous tubule protein secretion and the adverse effects of testicular toxicants in the rat. Int J Androl 16(6):370–379. 10.1111/j.1365-2605.1993.tb01364.x.8132380
Medinsky MA, Irons RD. 1985. Sex, strain, and species differences in the response. In: Ricker D, ed. Toxicity of nitroaromatic compounds. New York, NY: Hemisphere Publishing Corporation, 35–51.
Mestankova H, Parker AM, Bramaz N, . 2016. Transformation of Contaminant Candidate List (CCL3) compounds during ozonation and advanced oxidation processes in drinking water: Assessment of biological effects. Water Res 93:110–120. 10.1016/j.watres.2015.12.048.26900972
Mirsalis JC, Tyson CK, Butterworth BE. 1982. Detection of genotoxic carcinogens in the in vivo-in vitro hepatocyte DNA repair assay. Environ Mutagen 4(5):553–562. 10.1002/em.2860040506.7140674
Mitsumori K, Kodama Y, Uchida O, . 1994. Confirmation study, using nitrobenzene, of the combined repeat dose and reproductive/developmental toxicity test protocol proposed by the Organization for Economic Cooperation and Development (OECD). J Toxicol Sci 19(3):141–149. 10.2131/jts.19.3_141.7966451
Morgan KT, Gross EA, Lyght O, . 1985. Morphologic and biochemical studies of a nitrobenzene-induced encephalopathy in rats. Neurotoxicology 6(1):105–116.3873033
Myslak Z, Piotrowski JK, Musialowicz E. 1971. Acute nitrobenzene poisoning. A case report with data on urinary excretion of p-nitrophenol and p-aminophenol. Arch Toxikol 28(3):208–213. 10.1007/BF00330250.5134187
Nappe TM, Pacelli AM, Katz K. 2015. An atypical case of methemoglobinemia due to self-administered benzocaine. Case Rep Emerg Med 2015:670979. 10.1155/2015/670979.25874137
NAS/NRC. 1989. Report of the oversight committee. Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press. 15–35.
NBS. 1973. Reactivity of the hydroxyl radical in aqueous solutions. National Bureau of Standards. NSRDS-NBS 46. https://nvlpubs.nist.gov/nistpubs/Legacy/NSRDS/nbsnsrds46.pdf. January 18, 2023.
Nelson CR, Hites RA. 1980. Aromatic amines in and near the Buffalo River. Environ Sci Technol 14(9):1147–1149. 10.1021/es60169a020.
Newton JF, Kuo CH, Gemborys MW, . 1982. Nephrotoxicity of p-aminophenol, a metabolite of acetaminophen, in the Fischer 344 rat. Toxicol Appl Pharmacol 65(2):336–344. 10.1016/0041-008X(82)90017-5.7179289
NFPA. 2002. Nitrobenzene. In: Fire protection guide to hazardous materials. 13^th^ ed. Quincy, MA: National Fire Protection Association, 325–391.
NIOSH. 1977. Nitrobenzene. NIOSH manual of analytical methods. 2^nd^ ed. Volume 3. Cincinnati, OH: National Institute for Occupational Safety and Health. Method S217.
NIOSH. 1984. Nitrobenzenes. NIOSH manual of analytical methods. 3^rd^ ed. Cincinnati, OH: National Institute for Occupational Safety and Health. Method 2005.
NIOSH. 1988. National occupational exposure survey. Cincinnati, OH: National Institute of Occupational Safety and Health.
NIOSH. 2019. Nitrobenzene. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgd0450.html. November 1, 2022.
NITE. 2022. Biodegradation and bioconcentration data under CSCL. Japan Chemicals Collaborative Knowledge database. National Institute of Technology and Evaluation. https://www.nite.go.jp/en/chem/kasinn/cscl_data.html. October 28, 2022.
NLM. 2021. PubChem data: Nitrobenzene. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/Nitrobenzene. November 11, 2021.
Nojima K, Kanno S. 1977. Studies on photochemistry of aromatic hydrocarbons. IV: Mechanism of formation of nitrophenols by the photochemical reaction of benzene and toluene with nitrogen oxides in air. Chemosphere 6(6):371–376. 10.1016/0045-6535(77)90102-3.
NTP. 1982. Repeated dose dermal toxicity test of nitrobenzene in Fischer 344 rats and B6C3F1 mice. Bethesda, MD: National Toxicology Program. MRI-NTP 17-82-28.
NTP. 1983a. Report on subchronic toxicity via gavage of nitrobenzene (C60082) in Fischer 344 rats and B6C3F1 mice. Worcester, MA: National Toxicology Program. MRI-NTP 09-83-19.
NTP. 1983b. Report on the subchronic dermal toxicity of nitrobenzene (C60082) in Fischer 344 rats and B6C3F1 mice. Research Triangle Park, NC: National Toxicology Program. MRI-NTP 06-83-13.
NTP. 2021. Nitrobenzene. In: Report on carcinogens. 15^th^ ed. National Toxicology Program, https://ntp.niehs.nih.gov/ntp/roc/content/profiles/nitrobenzene.pdf. November 1, 2022.
Ohkuma Y, Kawanishi S. 1999. Oxidative DNA damage by a metabolite of carcinogenic and reproductive toxic nitrobenzene in the presence of NADH and Cu(II). Biochem Biophys Res Commun 257(2):555–560. 10.1006/bbrc.1999.0525.10198250
Oladele JO, Oyeleke OM, Oladele OT, . 2020a. Neuroprotective mechanism of Vernonia amygdalina in a rat model of neurodegenerative diseases. Toxicol Rep 7:1223–1232. 10.1016/j.toxrep.2020.09.005.32995297
Oladele JO, Oyeleke OM, Oladele OT, . 2020b. Supplemental material: Neuroprotective mechanism of Vernonia amygdalina in a rat model of neurodegenerative diseases. Toxicol Rep 7 10.1016/j.toxrep.2020.09.005.
Oladele JO, Oyeleke OM, Oladele OT, . 2020c. Nitrobenzene-induced hormonal disruption, alteration of steroidogenic pathway, and oxidative damage in rat: protective effects of Vernonia amygdalina. Clinical Phytoscience 6:15. 10.1186/s40816-020-00161-4.
Oladele JO, Oyeleke OM, Olowookere BD, . 2021. Bitter Leaf (Vernonia amygdalina) modulates nitrobenzene-induced renal damage in rats via suppression of oxido-inflammatory activities. Serbian J Exp Clin Res 22(4):317–324. 10.2478/sjecr-2020-0040.
OSHA. 2021a. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z-1: Limits for air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. https://www.govinfo.gov/content/pkg/CFR-2021-title29-vol6/pdf/CFR-2021-title29-vol6-sec1910-1000.pdf. August 28, 2022.
OSHA. 2021b. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. https://www.govinfo.gov/content/pkg/CFR-2021-title29-vol7/pdf/CFR-2021-title29-vol7-sec1915-1000.pdf. August 28, 2022.
OSHA. 2021c. Safety and health regulations for construction. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55. https://www.govinfo.gov/content/pkg/CFR-2021-title29-vol8/pdf/CFR-2021-title29-vol8-sec1926-55.pdf. August 28, 2022.
Parke DV. 1956. Studies in detoxication. 68. The metabolism of [14C]nitrobenzene in the rabbit and guinea pig. Biochem J 62(2):339–346. 10.1042/bj0620339.13293194
Patel A, Dewan A, Upadhyay K, . 2008. Chemically induced methemoglobinemia from acute nitrobenzene poisoning. Internet J Lab Med 3(2):4490.
Patil SS, Shinde VM. 1988. Biodegradation studies of aniline and nitrobenzene in aniline plant wastewater by gas chromatography. Environ Sci Technol 22(10):1160–1165. 10.1021/es00175a005.22148608
Perera M, Shihana F, Kularathne K, . 2009. Acute methaemoglobinaemia after massive nitrobenzene ingestion. BMJ Case Rep 2009:0515. 10.1136/bcr.07.2008.0515.
Piotrowski JK. 1967. Further investigations on the evaluation of exposure to nitrobenzene. Occup Environ Med 24(1):60–65. 10.1136/oem.24.1.60.
Pitter P. 1976. Determination of biological degradability of organic substances. Water Res 10(3):231–235. 10.1016/0043-1354(76)90132-9.
Piwoni MD, Wilson JT, Walters DM, . 1986. Behavior of organic pollutants during rapid-infiltration of wastewater into soil: I. Processes, definition, and characterization using a microcosm. Haz Waste Haz Mater 3(1):43–55. 10.1089/hwm.1986.3.43.
Reddy BG, Pohl LR, Krishna G. 1976. The requirement of the gut flora in nitrobenzene-induced methemoglobinemia in rats. Biochem Pharmacol 25(9):1119–1122. 10.1016/0006-2952(76)90507-4.1267854
RePORTER. 2022. Nitrobenzene. Research Portfolio Online Reporting Tools. National Institutes of Health. https://reporter.nih.gov/. October 28, 2022.
Richburg JH, Nañez A. 2003. Fas- or FasL-deficient mice display an increased sensitivity to nitrobenzene-induced testicular germ cell apoptosis. Toxicol Lett 139(1):1–10. 10.1016/S0378-4274(02)00419-8.12595153
Rickert DE. 1987. Metabolism of nitroaromatic compounds. Drug Metab Rev 18(1):23–53. 10.3109/03602538708998299.3311683
Rickert DE, Bond JA, Long RM, . 1983. Metabolism and excretion of nitrobenzene by rats and mice. Toxicol Appl Pharmacol 67(2):206–214. 10.1016/0041-008X(83)90226-0.6836574
Ricking M, Schwarzbauer J, Franke S. 2003. Molecular markers of anthropogenic activity in sediments of the Havel and Spree Rivers (Germany). Water Res 37(11):2607–2617. 10.1016/s0043-1354(03)00078-2.12753838
Robbiano L, Baroni D, Carrozzino R, . 2004. DNA damage and micronuclei induced in rat and human kidney cells by six chemicals carcinogenic to the rat kidney. Toxicology 204(2–3):187–195. 10.1016/j.tox.2004.06.057.15388244
Robinson D, Smith JN, Williams RT. 1951. Studies in detoxication. 40. The metabolism of nitrobenzene in the rabbit. o-, m-and p-Nitrophenols, o-, m-and p-aminophenols and 4-nitrocatechol as metabolites of nitrobenzene. Biochem J 50(2):228–235. 10.1042/bj0500228.14904398
Roth CM, Goss KU, Schwarzenbach RP. 2004. Sorption of diverse organic vapors to snow. Environ Sci Technol 38(15):4078–4084. 10.1021/es0350684.15352444
Rubin C, Esteban E, Kieszak S, . 2002. Assessment of human exposure and human health effects after indoor application of methyl parathion in Lorain County, Ohio, 1995-1996. Environ Health Perspect 110(Suppl 6):1047–1051. 10.1289/ehp.02110s61047.
Ruth JH. 1986. Odor thresholds and irritation levels of several chemical substances: a review. Am Ind Hyg Assoc J 47(3):A142–A151. 10.1080/15298668691389595.3706135
Salmowa J, Piotrowski J, Neuhorn U. 1963. Evaluation of exposure to nitrobenzene: Absorption of nitrobenzene vapour through lungs and excretion of p-nitrophenol in urine. Occup Environ Med 20(1):41–46. 10.1136/oem.20.1.41.
Saxena H, Prakash Saxena A. 2010. Acute methaemoglobinaemia due to ingestion of nitrobenzene (paint solvent). Indian J Anaesth 54(2):160–162. 10.4103/0019-5049.63635.20661357
Seip HM, Alstad J, Carlberg GE, . 1986. Measurement of mobility of organic compounds in soils. Sci Total Environ 50:87–101. 10.1016/0048-9697(86)90353-0.
Shackelford WM, Cline DM, Faas L, . 1983. An evaluation of automated spectrum matching for survey identification of wastewater components by gas chromatography - mass spectrometry. Anal Chim Acta 146:15–27. 10.1016/S0003-2670(00)80588-7.
Shimizu M, Yasui Y, Matsumoto N. 1983. Structural specificity of aromatic compounds with special reference to mutagenic activity in Salmonella typhimurium-a series of chloro- or fluoro-nitrobenzene derivatives. Mutat Res 116(3–4):217–238. 10.1016/0165-1218(83)90060-5.6339893
Shinoda K, Mitsumori K, Yasuhara K, . 1998. Involvement of apoptosis in the rat germ cell degeneration induced by nitrobenzene. Arch Toxicol 72(5):296–302. 10.1007/s002040050505.9630016
Shrestha N, Karki B, Shrestha PS, . 2020. Management of nitrobenzene poisoning with oral methylene blue and vitamin C in a resource limited setting: A case report. Toxicol Rep 7:1008–1009. 10.1016/j.toxrep.2020.08.012.32874924
Simmons MS, Zepp RG. 1986. Influence of humic substances on photolysis of nitroaromatic compounds in aqueous systems. Water Res 20(7):899–904. 10.1016/0043-1354(86)90179-x.
Smith MT, McHale CM. 2018. Toxic responses of the blood. In: Klassen CD, ed. Casarett and Doull’s toxicology: The basic science of poisons. 9^th^ ed. McGraw-Hill Education,
Smith RP, Alkaitis AA, Shafer PR. 1967. Chemically induced methemoglobinemias in the mouse. Biochem Pharmacol 16(2):317–328. 10.1016/0006-2952(67)90033-0.6043619
Smyth HF, Weil CS, West JS, . 1969. An exploration of joint toxic action: Twenty-seven industrial chemicals intubated in rats in all possible pairs. Toxicol Appl Pharmacol 14(2):340–347. 10.1016/0041-008X(69)90115-X.5772858
Staples CA, Werner AF, Hoogheem TJ. 1985. Assessment of priority pollutant concentrations in the United States using STORET database. Environ Toxicol Chem 4(2):131–142. 10.1002/etc.5620040202.
Stolk JM, Smith RP. 1966. Species differences in methemoglobin reductase activity. Biochem Pharmacol 15(3):343–351. 10.1016/0006-2952(66)90305-4.4380376
Stover EL, Kincannon DF. 1983. Biological treatability of specific organic compounds found in chemical industry wastewaters. Water Pollut Control Fed 57:97–109.
Suzuki J, Koyama T, Suzuki S. 1983. Mutagenicities of mono-nitrobenzene derivatives in the presence of norharman. Mutat Res 120(2–3):105–110. 10.1016/0165-7992(83)90150-1.6341826
Suzuki J, Takahashi N, Kobayashi Y, . 1987. Dependence on Salmonella typhimurium enzymes of mutagenicities of nitrobenzene and its derivatives in the presence of rat-liver S9 and norharman. Mutat Res 178(2):187–193. 10.1016/0027-5107(87)90268-5.3295532
Tabak HH, Quave SA, Mashni CI, . 1981. Biodegradability studies with organic priority pollutant compounds. J Water Pollut Control Fed 53(10):1503–1518.
Toker I, Yesilaras M, Tur FC, . 2015. Methemoglobinemia caused by dapsone overdose: Which treatment is best? Turk J Emerg Med 15(4):182–184. 10.1016/j.tjem.2014.09.002.27239625
TRI21. 2022. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Toxics Release Inventory. U.S. Environmental Protection Agency. http://www.epa.gov/triexplorer/. November 10, 2022.
Turney GL, Goerlitz DF. 1990. Organic contamination of ground water at Gas Works Park, Seattle, Washington. Ground Water Monit Remediat 10(3):187–198. 10.1111/j.1745-6592.1990.tb00014.x.
Tyl RW, France KA, Fisher LC, . 1987. Developmental toxicity evaluation of inhaled nitrobenzene in CD rats. Appl Toxicol 8(4):482–492. 10.1016/0272-0590(87)90134-5.
Vance WA, Levin DE. 1984. Structural features of nitroaromatics that determine mutagenic activity in Salmonella typhimurium. Environ Mutagen 6(6):797–811. 10.1002/em.2860060607.6389108
Veith GD, DeFoe DL, Bergstedt BV. 1979. Measuring and estimating the bioconcentration factor of chemicals in fish. J Fish Res Board Can 36(9):1040–1048. 10.1139/f79-146.
Von Oettingen WF. 1941. The aromatic amino and nitro compounds: Their toxicity and potential dangers. In: Public health bulletin. Washington, DC: Superintendent of Documents, 76–105.
Wang A, Hu C, Qu J, . 2008. Phototransformation of nitrobenzene in the Songhua River: kinetics and photoproduct analysis. J Environ Sci (China) 20(7):787–795. 10.1016/s1001-0742(08)62127-0.18814572
WHO. 2003. Nitrobenzene. Geneva, Switzerland: World Health Organization. Environmental Health Criteria 230. https://inchem.org/documents/ehc/ehc/ehc230.htm. November 9, 2022.
WHO. 2009. Nitrobenzene in drinking-water: Background document for development of WHO Guidelines for Drinking-water Quality. Geneva, Switzerland: World Health Organization. https://www.who.int/water_sanitation_health/water-quality/guidelines/chemicals/nitrobenzene-background.pdf. November 9, 2022.
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. April 25, 2012.
WHO. 2022. Guidelines for drinking-water quality. Fourth edition incorporating the first and second addenda. World Health Organization. https://www.who.int/publications/i/item/9789240045064. June 22, 2022.
Wilson JT, Enfield CG, Dunlap WJ, . 1981. Transport and fate of selected organic pollutants in a sandy soil. J Environ Qual 10(4):501–506. 10.2134/jeq1981.00472425001000040016x.
Wirtschafter ZT, Wolpaw R. 1944. A case of nitrobenzene poisoning. Ann Intern Med 21:135–141. 10.7326/0003-4819-21-1-135.
Wolfe NL. 1992. Abiotic transformations of pesticides in natural waters and sediments. In: Schnoor JR, ed. Fate of pesticides and chemicals in the environment. New York, NY: John Wiley and Sons, Inc., 93–104.
Young DR, Gossett RW, Baird RB, . 1983. Wastewater inputs and marine bioaccumulation of priority pollutant organics off Southern California [abstract]. In: Jolley RL, Brungs WA, Cotruro JA, ., eds. Water chlorination environmental impact and health effects, volume 4, book 2. Pacific Grove, CA: Fourth Water Chlorination Conference, SCCWRP # 294.
Yu YS, Bailey GW. 1992. Reduction of nitrobenzene by four sulfide minerals: Kinetics, products, and solubility. J Environ Qual 21(1):86–94. 10.2134/jeq1992.00472425002100010014xa.
Zasada K, Karbownik-Lewinska M. 2015. Comparison of potential protective effects of melatonin and propylthiouracil against lipid peroxidation caused by nitrobenzene in the thyroid gland. Toxicol Ind Health 31(12):1195–1201. 10.1177/0748233713491799.23723263
Zepp RG, Schlotzhauer PF. 1983. Influence of algae on photolysis rates of chemicals in water. Environ Sci Technol 17(8):462–468. 10.1021/es00114a005.22283164
Zepp RG, Braun AM, Hoigne J, . 1987. Photoproduction of hydrated electrons from natural organic solutes in aquatic environments. Environ Sci Technol 21(5):485–490. 10.1021/es00159a010.22296137
Zhang HK, Liang SX, Liu SJ. 2007. Determination of nitrobenzene by differential pulse voltammetry and its application in wastewater analysis. Anal Bioanal Chem 387(4):1511–1516. 10.1007/s00216-006-1014-0.17200860