# CONTRIBUTORS & REVIEWERS

## CHEMICAL MANAGER TEAM

- Malcolm Williams, D.V.M., Ph.D. (Lead)
  Jennifer Przybyla, Ph.D.
  Sam Keith, M.S., C.H.P.
  ATSDR, Office of Innovation and Analytics, Toxicology Section, Atlanta, GA
- Lauren Brown, MS, DABT
  Meghan Lynch, DSc
  Kerry Diskin, DSc
  Rekha Balachandran, PhD
  Hannah Derrick, BS
  Abt Associates, Inc., Rockville, MD
  Texas A&M University, College Station, TX (subcontractor to Abt Associates)
- Heather Carlson-Lynch, M.S., D.A.B.T.
  Claire Heit, Ph.D.
  Mario Citra, Ph.D.
  Ramsey Hanna, Ph.D.
  SRC, Inc., North Syracuse, NY

## REVIEWERS

- Interagency Minimal Risk Level Workgroup:
  Includes ATSDR; National Center for Environmental Health (NCEH); National Institute for Occupational Safety and Health (NIOSH); U.S. Environmental Protection Agency (EPA); National Toxicology Program (NTP).
- Additional reviews for science and/or policy:
  ATSDR, Office of Community Health Hazard Assessment; ATSDR, Office of Capacity Development and Applied Prevention Science; ATSDR, Office of Science; NCEH, Division of Laboratory Sciences; NCEH, Division of Environmental Health Science and Practice.

## PEER REVIEWERS

1. Mary Beth Genter, Ph.D., Professor, Department of Environmental Health, University of Cincinnati, Cincinnati, Ohio (Reviewed Draft for Public Comment Profile and MRLs in the Post-Public Comment Profile)
2. Stephen M. Roberts, Ph.D., Director, Center for Environmental & Human Toxicology, Professor, College of Veterinary Medicine, College of Medicine, and College of Public Health and Health Professions, University of Florida, Gainesville, Florida (Reviewed Draft for Public Comment Profile and MRLs in the Post-Public Comment Profile)
3. Andrew Gow, Ph.D., M.Ed. Professor, Ernest Mario School of Pharmacy, Rutgers University, New Brunswick, New Jersey (Reviewed Draft for Public Comment Profile)
4. Russell C. Cattley, VMD, PhD, Dipl. ACVP, Fellow IATP, Tyler & Frances Young Emeritus Professor of Pathology, College of Veterinary Medicine, Auburn University, Auburn, Alabama (Reviewed MRLs in the Post-Public Comment Profile)

These experts collectively have knowledge of toxicology, chemistry, and/or health effects. All reviewers were selected in conformity with Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

ATSDR scientists review peer reviewers’ comments and determine whether changes will be made to the profile based on comments. The peer reviewers’ comments and responses to these comments are part of the administrative record for this compound.

The listing of peer reviewers should not be understood to imply their approval of the profile’s final content. The responsibility for the content of this profile lies with ATSDR.