# VERSION HISTORY

Date | Description
January 2024 | Final toxicological profile released
April 2022 | Draft for public comment toxicological profile released
December 1990 | Final toxicological profile released