# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding nitrobenzene in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for nitrobenzene.

Table 7-1 Regulations and Guidelines Applicable to Nitrobenzene

Agency | Description | Information | Reference
Air
EPA | RfC | 9×10^−3^ mg/m^3^; (2×10^−3^ ppm) | IRIS 2009
WHO | Air quality guidelines | No data | WHO 2010
Water & Food
EPA | Drinking water standards and health advisories | Not listed | EPA 2018a
EPA | National primary drinking water regulations | Not listed | EPA 2009b
EPA | RfD | 2×10^−3^ mg/kg/day | IRIS 2009
WHO | Drinking water quality guidelines | Guidelines not established^a^ | WHO 2022, WHO 2009
FDA | Substances added to food (formerly EAFUS) | Not listed | FDA 2022
Cancer
HHS | Carcinogenicity classification | Reasonably anticipated to be a human carcinogen | NTP 2021
EPA | Carcinogenicity classification | Likely to be carcinogenic to humans | IRIS 2009
EPA | Inhalation unit risk | 4×10^−5^ per µg/m^3^ | IRIS 2009
IARC | Carcinogenicity classification | Group 2B^b^ | IARC 1996
Occupational
OSHA | PEL (8-hour TWA) for general industry, shipyards, and construction | 1 ppm (5 mg/m^3^)^c^ | OSHA 2021a, 2021b, 2021c
NIOSH | REL (up to 10-hour TWA) | 1 ppm (5 mg/m^3^)^c^ | NIOSH 2019
NIOSH | IDLH | 200 ppm | NIOSH 2019
Emergency Criteria
EPA | AEGLs-air | No data | EPA 2018b
DOE | PACs-air | | DOE 2018a
DOE | PAC-1^d^ | 3 ppm | DOE 2018a
DOE | PAC-2^d^ | 20 ppm | DOE 2018a
DOE | PAC-3^d^ | 200 ppm | DOE 2018a

a Reason: nitrobenzene is rarely found in drinking water at concentrations of health concern.

b Group 2B: possibly carcinogenic to humans.

c Skin notation.

d Definitions of PAC terminology are available from U.S. Department of Energy (DOE 2018b).

AEGL = acute exposure guideline levels; DOE = Department of Energy; EAFUS = Everything Added to Food in the United States; EPA = U.S. Environmental Protection Agency; FDA = Food and Drug Administration; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TWA = time-weighted average; WHO = World Health Organization