# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Nitrobenzene is a colorless to pale yellow oily liquid composed of a benzene ring with a single substituted nitro group. The compound is a synthetic chemical, and it does not occur naturally. It has an odor similar to bitter almonds or shoe polish. The chemical is primarily used in the synthesis of aniline and in producing the chemical intermediate to polyurethane. Nitrobenzene is also used as a solvent during petroleum refining and in the manufacture of cellulose ethers and acetates. It is a starting material for dinitrobenzenes, dichloroanilines, and other compounds including acetaminophen. Some of nitrobenzene’s synonyms include mirbane oil and myrbane oil.

Table 4-1 lists common synonyms, trade names, and other pertinent identification information for nitrobenzene.

Table 4-1 Chemical Identity of Nitrobenzene

Characteristic | Information | Reference
Chemical name | Nitrobenzene | NLM 2021
Synonym(s) and registered trade name(s) | Nitrobenzol; essence of mirbane, essence of myrbane; oil of mirbane; mononitrobenzene; nitrobenzol; Caswell No.600 | NLM 2021
Chemical formula | C_6_H_5_NO_2_ | Lide 2005
Chemical structure | Chemical structure | Lide 2005
CAS registry number | 98-95-3 | Lei et al. 2008; Lide 2005

CAS = Chemical Abstracts Service

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Nitrobenzene is a liquid at room temperature. It is sparingly soluble in water and most organic solvents, and it represents a fire hazard. It is completely miscible in diethyl ether, benzene, and alcohol.

Nitrobenzene has a relatively high vapor pressure, which contributes to its flammability. Nitrobenzene has a relatively low K_ow_ value, suggesting that it is unlikely to bioaccumulate. Nitrobenzene’s low K_oc_ indicates its high to moderate mobility in soil. The Henry’s Law constant for nitrobenzene suggests that it will volatilize from moist soil and water surfaces. The high vapor pressure of nitrobenzene indicates that if released into the air, it will exist solely as a vapor in the atmosphere. Table 4-2 lists important physical and chemical properties of nitrobenzene.

Table 4-2 Physical and Chemical Properties of Nitrobenzene

Property | Information | Reference
Molecular weight | 123.11 g/mol | Lei et al. 2008; Lide 2005
Color | Colorless to greenish-yellow or yellow | NLM 2021
Physical state | Crystals or oily liquid | Haynes 2015
Melting point(s) | 5.7°C | Lide 2005
Boiling point(s) | 210.8°C | Lei et al. 2008; Lide 2005
Critical temperature and pressure | 720 K and 4.824 MN/M SQ | NLM 2021
Density | 1.2037 g/cm^3^ at 20°C | Lide 2005
Viscosity | 1.863 mPas at 25°C | Lide 2005
Taste | Sweet (aqueous solutions) | NLM 2021
Odor | Volatile oil almond odor; pungent odor | NLM 2021
Odor threshold: | | NLM 2021
Water | 30–110 μg/L
Air | 4.7×10^−3^–1.90 ppm
Solubility: | | Haynes 2015
Water | 2.1 g/LH_2_O at 25°C
Organic solvent(s) at 20°C | Slightly soluble in carbon tetrachloride; very soluble in ethanol, diethyl ether, acetone, benzene
Inorganic solvent(s)
Partition coefficients:
Log K_ow_ | 1.85 | Lei et al. 2008; Lide 2005
Log K_oc_ | 1.94 | NLM 2021
Relative Vapor Density | 4.2 (air=1) | NLM 2021
Vapor pressure at 25°C | 0.245 mmHg | NLM 2021
Henry’s law constant | 2.3 ×10^−5^ atm m^3^/mol at 25°C | Lei et al. 2008
Degradation half-life in air via reaction with OH radicals | 44 days | EPA 2012
Heat of combustion | −10,420 Btu/pound | NLM 2021
Heat of vaporization | 55.01 kJ/mol at 25°C | Haynes 2015
Autoignition temperature | 900°F | NFPA 2002
Flashpoint | 88°C | Haynes 2015
Flammability limits in air | 1.8% by volume at 200°F | Lide 2005
Conversion factors: | 1 mg/m^3^=0.199 ppm^a^; 1 ppm=5.04 mg/m^3^
Explosive limits | Moderate when exposed to heat or flame | NLM 2021
Incompatibilities and reactivity | Explosive reaction with solid or concentrated alkali and heat (e.g., sodium hydroxide or potassium hydroxide), aluminum chloride and phenol, aniline and glycerin, N_2_O, and AgClO_4_ | NLM 2021

a Concentration (ppm) = 24.45 × concentration (mg/m^3^)/molecular weight at standard temperature and pressure.