# 9 REFERENCES

* Not cited in text

ACGIH. 2013. Threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists. http://www.acgih.org/home.htm. January 08, 2014.
Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environmental Health Perspectives Supplement 103(7):103–112.
AIHA. 2013. Emergency response planning guidelines (ERPG). Fairfax, VA: American Industrial Hygiene Association. https://www.aiha.org/get-involved/AIHAGuidelineFoundation/EmergencyResponsePlanningGuidelines/Pages/default.aspx. January 08, 2014.
Alavantic D, Sunjevaric I, Cerovic G, . 1988a. In-vivo genotoxicity of nitrates and nitrites in germ cells of male mice. 2. Unscheduled DNA synthesis and sperm abnormality after treatment of spermatids. Mutat Res 204(4):697–702.3352651
Alavantic D, Sunjevaric I, Pecevski J, . 1988b. In vivo genotoxicity of nitrates and nitrites in germ cells of male mice. 1. Evidence for gonadal exposure and lack of heritable effects. Mutat Res 204(4):689–695.3352650
Al-Dabbagh S, Forman D, Bryson D, . 1986. Mortality of nitrate fertilizer workers. Br J Ind Med 43(8):507–515.3015194
Al-Gayyar MM, Alyoussef A, Hamdan AM, . 2015. Cod liver oil ameliorates sodium nitrite-induced insulin resistance and degradation of rat hepatic glycogen through inhibition of cAMP/PKA pathway. Life Sci 120:13–21. 10.1016/j.lfs.2014.11.002.25447450
Altman PL, Dittmer DS. 1974. Biological handbooks: Biology data book. Vol. III. 2nd ed. Bethesda, MD: Federation of American Societies of Experimental Biology, 1987–2008, 2041.
Alyoussef A, Al-Gayyar MM. 2016a. Thymoquinone ameliorated elevated inflammatory cytokines in testicular tissue and sex hormones imbalance induced by oral chronic toxicity with sodium nitrite. Cytokine 83:64–74. 10.1016/j.cyto.2016.03.018.27038016
Alyoussef A, Al-Gayyar MM. 2016b. Thymoquinone ameliorates testicular tissue inflammation induced by chronic administration of oral sodium nitrite. Andrologia 48(5):501–508. 10.1111/and.12469.26260072
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, and replacement. New York, NY: Marcel Dekker, Inc., 9–25.
Andersen ME, Clewell HJ, Gargas ML, . 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87(2):185–205.3824380
Anderson LM, Giner-Sorolla A, Haller IM, . 1985. Effects of cimetidine, nitrite, cimetidine plus nitrite, and nitrosocimetidine on tumors in mice following transplacental plus chronic lifetime exposure. Cancer Res 45(8):3561–3566.4016736
Andrews AW, Fornwald JA, Lijinsky W. 1980. Nitrosation and mutagenicity of some amine drugs. Toxicol Appl Pharmacol 52:237–244.6987779
Andrews AW, Lijinsky W, Snyder SW. 1984. Mutagenicity of amine drugs and their products of nitrosation. Mutat Res 135:105–108.6363913
Aoyagi M, Matsukura N, Uchida E, . 1980. Induction of liver tumors in Wistar rats by sodium nitrite given in pellet diet. J Natl Cancer Inst 65(2):411–414.6931259
Aquanno JJ, Chan KM, Dietzler DN. 1981. Accidental poisoning of two laboratory technologists with sodium nitrite. Clin Chem 27(6):1145–1146.7237751
Arbuckle TE, Sherman GJ, Corey PN, . 1988. Water nitrates and CNS birth defects: A population-based case-control study. Arch Environ Health 43(2):162–167.3377550
Armijo R, Gonzalez A, Orellana M, . 1981. Epidemiology of gastric cancer in Chile: 2. Nitrate exposures and stomach cancer frequency. Int J Epidemiol 10(1):57–62.7239764
Asahina S, Friedman MA, Arnold E, . 1971. Acute synergistic toxicity and hepatic necrosis following oral administration of sodium nitrite and secondary amines to mice. Cancer Res 31(9):1201–1205.5115049
Aschebrook-Kilfoy B, Cross AJ, Stolzenberg-Solomon RZ, . 2011. Pancreatic cancer and exposure to dietary nitrate and nitrite in the NIH-AARP Diet and Health Study. Am J Epidemiol 174(3):305–315.21685410
Aschebrook-Kilfoy B, Heltshe SL, Nuckols JR, . 2012. Modeled nitrate levels in well water supplies and prevalence of abnormal thyroid conditions among the Old Order Amish in Pennsylvania. Environ Health (Lond) 11:6–16.
Aschebrook-Kilfoy B, Shu X, Gao Y, . 2013a. Thyroid cancer risk and dietary nitrate and nitrite intake in the Shanghai Women’s Health Study. Int J Cancer 132:897–904.22674227
Aschebrook-Kilfoy B, Ward MH, Dave BJ, . 2013b. Dietary nitrate and nitrite intake and risk of non-Hodgkin lymphoma. Leuk Lymphoma 54(5):945–950. 10.3109/10428194.2012.734613.23013327
Aschengrau A, Zierler S, Cohen A. 1989. Quality of community drinking water and the occurrence of spontaneous abortion. Arch Environ Health 44(5):283–290.2554824
Aschengrau A, Zierler S, Cohen A. 1993. Quality of community drinking water and the occurrence of late adverse pregnancy outcomes. Arch Environ Health 48(2):105–113.8476301
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37634.
ATSDR. 2013a. ATSDR case studies in environmental medicine. Nitrate/nitrite toxicity. Atlanta, GA: Agency for Toxic Substances and Disease Registry. U.S. Department of Health and Human Services. http://www.atsdr.cdc.gov/csem/nitrate_2013/docs/nitrite.pdf. May 20, 2014.
ATSDR. 2013b. Nitrate/nitrite toxicity. Clinical assessment-laboratory tests [CE original date: December 5, 2013, CE renewal date: December 5, 2015, CE expiration date: December 5, 2017. http://www.atsdr.cdc.gov/csem/nitrate_2013/docs/nitrite.pdf. September 15, 2016.
ATSDR. 2015. Ammonium nitrate, sodium nitrate, and sodium nitrite . Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry, Centers for Disease Control and Prevention. http://www.atsdr.cdc.gov/SPL/resources. August 3, 2016.
Avery AA. 1999. Infantile methemoglobinemia: Reexamining the role of drinking water nitrates. Environ Health Perspect 107(7):583–586.10379005
Bahadoran Z, Mirmiran P, Ghasemi A, . 2015. Is dietary nitrate/nitrite exposure a risk factor for development of thyroid abnormality? A systematic review and meta-analysis. Nitric Oxide 47:65–76. 10.1016/j.niox.2015.04.002.25889269
Bailey SJ, Vanhatalo A, Winyard PG, . 2012. The nitrate-nitrite-nitric oxide pathway: Its role in human exercise physiology. Eur J Sport Sci 12(4):309–320. 10.1080/17461391.2011.635705. January 1, 2013.
Bailey WP. 1966. Methemoglobinemia--acute nitrate poisoning in infants: Second report. J Am Osteopath Assoc 66(4):431–434.5182521
Balimandawa M, de Meester C, Leonard A. 1994. The mutagenicity of nitrite in the Salmonella/microsome test system. Mutat Res 321(1–2):7–11.7510847
Barbone F, Austin H, Partridge EE. 1993. Diet and endometrial cancer: A case-control study. Am J Epidemiol 137(4):393–403.8460621
Barclay PJ. 1998. Nitrates and nitrites. In: Viccellio P, ed. Emergency toxicology. 2nd ed. Philadelphia, PA: Lippincott-Raven Publishers, 315–323.
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486.3222488
Bauer SE, Koch D, Unger N, . 2007. Nitrate aerosols today and in 2030: A global simulation including aerosols and tropospheric ozone. Atmos Chem Phys 7(19):5043–5059.
Behroozi K, Robinson S, Gruener N, . 1972. The effect of chronic exposure to sodium nitrite on the electroencephalogram of rats. Environ Res 5(4):409–417.4651615
Berger GS, ed. 1994. Epidemiology of endometriosis. In: Endometriosis: Modern surgical management of endometriosis. New York, NY: Springer-Verlag, 3–7.
Blood AB, Power GG. 2015. Nitrite: On the journey from toxin to therapy. Clin Pharmacokinet 54(3):221–223. 10.1007/s40262-014-0231-5.25603820
Bloom JC, Schade AE, Brandt JT. 2013. Toxic responses of the blood. In: Klaassen CD, ed. Casarett and Doull’s toxicology: The basic science of poisons. 8th ed. New York: McGraw Hill Education, 532–533.
Bloomfield RA, Welsch CW, Garner GB, . 1961. Effect of dietary nitrate on thyroid function. Science 134(3491):1690.13870154
Blowers L, Preston-Martin S, Mack WJ. 1997. Dietary and other lifestyle factors of women with brain gliomas in Los Angeles County (California, USA). Cancer Causes Control 8(1):5–12.9051317
Bondonno CP, Croft KD, Puddey IB, . 2012. Nitrate causes a dose-dependent augmentation of nitric oxide status in healthy women. Food Funct 3(5):522–527.22336776
Börzsönyi M, Pintér A, Surján A, . 1976. Transplacental induction of lymphomas in Swiss mice by carbendazim and sodium nitrite. Int J Cancer 17:742–747.988851
Börzsönyi M, Pintér A. 1977. The carcinogenicity of N-nitroso compounds formed endogenously in mice from benzimidazole carbamate pesticides. Neoplasma 21(1):119–122.
Börzsönyi M, Pintér A, Surján A, . 1978. Carcinogenic effect of a quanidine pesticide administered with sodium nitrite on adult mice and on the offspring after prenatal exposure. Cancer Lett 5(2):107–113.581183
Bosch HM, Rosenfield AB, Huston R, . 1950. Methemoglobinemia and Minnesota well supplies. J Am Water Works Assoc 42(2):161–170.
Brambilla G, Martelli A. 2007. Genotoxic and carcinogenic risk to humans of drug-nitrite interaction products. Mutat Res 635(1):17–52.17157055
Brambilla G, Cavanna M, Faggin P, . 1983. Genotoxic effects in rodents given high oral doses of ranitidine and sodium nitrite. Carcinogenesis 4(10):1281–1285.6311451
Brams A, Buchet JP, Crutzen-Fayt MC, . 1987. A comparative study, with 40 chemicals, of the efficiency of the Salmonella assay and the SOS chromotest (kit procedure). Toxicol Lett 38:1–2.3629621
Brender JD, Olive JM, Felkner M, . 2004. Dietary nitrites and nitrates, nitrosatable drugs, and neural tube defects. Epidemiology 15(3):330–336.15097014
Brender JD, Weyer PJ, Romitti PA, . 2013. Prenatal nitrate intake from drinking water and selected birth defects in offspring of participants in the National Birth Defects Prevention Study. Environ Health Perspect. 121(9):1083–1089.23771435
Bronson KF. 2008. Forms of inorganic nitrogen in soil. In: Schepers JS, Raun WR, eds. Nitrogen in agricultural systems. Madison, WI: American Society of Agronomy, Inc., Crop Science Society of America, Inc., Soil Science Society of America, Inc., 31–55.
Bruning-Fann CS, Kaneene JB. 1993. The effects of nitrate nitrite and n-nitroso compounds on human health: A review. Vet Hum Toxicol 35(6):521–538.8303822
Bruning-Fann C, Kaneene JB, Miller RA, . 1994. The use of epidemiological concepts and techniques to discern factors associated with the nitrate concentration of well water on swine farms in the USA. Sci Total Environ 153(1–2):85–96.7939621
Bryan NS, van Grinsven H. 2013. The role of nitrate in human health. In: Sparks D, ed. Advances in agronomy. Vol. 119. Delaware: Elsevier, Inc., 153–181.
Bucklin R, Myint MK. 1960. Fatal methemoglobinemia due to well water nitrates. Ann Intern Med 52:703–705.13805592
Buiatti E, Palli D, Decarli A, . 1990. A case-control study of gastric cancer and diet in Italy: II. Association with nutrients. Int J Cancer 45(5):896–901.2335393
Bukowski J, Somers G, Bryanton J. 2001. Agricultural contamination of groundwater as a possible risk factor for growth restriction or prematurity. J Occup Environ Med 43(4):377–383.11322099
Burow KR, Nolan BT, Rupert MG, . 2010. Nitrate in groundwater of the United States, 1991−2003. Environ Sci Technol 44(13):4988–4997.20540531
Casu A, Carlini M, Contu A, . 2000. Type 1 diabetes in Sardinia is not linked to nitrate levels in drinking water. Diabetes Care 23(7):1043–1044.10895879
CDC. 1996. Spontaneous abortions possibly related to ingestion of nitrate-contaminated well water-LaGrange County, Indiana, 1991-1994. MMWR Morb Mortal Wkly Rep 45(26):569–572.9132576
CDC. 1997. Methemoglobinemia attributable to nitrite contamination of potable water through boiler fluid additives-New Jersey, 1992 and 1996. MMWR Morb Mortal Wkly Rep 46(9):202–204.9072681
CDC. 1998. A survey of the quality of water drawn from domestic wells in nine midwest states. Centers for Disease Control and Prevention, National Center for Environmental Health. http://www.cdc.gov/nceh/hsb/disaster/pdfs/A%20Survey%20of%20the%20Quality%20ofWater%20Drawn%20from%20Domestic%20Wells%20in%20Nine%20Midwest%20States.pdf. May 21, 2014.
CDC. 2002. Methemoglobinemia following unintentional ingestion of sodium nitrite - New York, 2002. Centers for Disease Control and Prevention, U.S. Department of Health and Human Services. Morbidity and Mortality Weekly Report 51(29):639–642.12186221
CDC. 2013. Fourth national report on human exposure to environmental chemicals, updated tables, September 2013. Atlanta, GA: Centers for Disease Control and Prevention, Department of Health and Human Services. http://www.cdc.gov/exposurereport/pdf/FourthReport_UpdatedTables_Sep2013.pdf. May 20, 2014.
Cedergren MI, Selbing AJ, Lofman O, . 2002. Chlorination byproducts and nitrate in drinking water and risk for congenital cardiac defects. Environ Res 89(2):124–130.12123645
Chan WC, Fong YY. 1977. Ascorbic acid prevents liver tumour production by aminopyrine and nitrite in the rat. Int J Cancer 20(2):268–270.892935
Chapin FJ. 1947. Methemoglobinemia from nitrates in well water. J Mich State Med Soc 46(8):938.20257852
ChemID Plus. 2014. Nitrate ion and nitrite ion. ChemIDplus: A Toxnet database. Bethesda, MD: U.S. National Library of Medicine. http://chem.sis.nlm.nih.gov/chemidplus/. May 22, 2014.
Chiu BC, Dave BJ, Ward MH, . 2008. Dietary factors and risk of t(14;18)-defined subgroups of non-Hodgkin lymphoma. Cancer Causes Control 19(8):859–867. 10.1007/s10552-008-9148-3.18386141
Chiu HF, Tsai SS, Chen PS, . 2011. Does calcium in drinking water modify the association between nitrate in drinking water and risk of death from colon cancer? J Water Health 9(3):498–506.21976196
Chiu HF, Tsai SS, Yang CY. 2007. Nitrate in drinking water and risk of death from bladder cancer: An ecological case-control study in Taiwan. J Toxicol Environ Health A 70(12):1000–1004. 10.1080/15287390601171801.17497410
Chow CK, Chen CJ, Gairola C. 1980. Effect of nitrate and nitrite in drinking water on rats. Toxicol Lett 6(3):199–206.7404601
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Cohen B, Myant NB. 1959. Concentration of salivary iodide: A comparative study. J Physiol 145(3):595–610.13642324
Comly HH. 1987. Landmark article Sept 8, 1945: Cyanosis in infants caused by nitrates in well water. JAMA 257(20):2788–2792.3553637
Commoner B, Woolum JC, Senturia BH, . 1970. The effects of 2-acetylaminofluorene and nitrite on free radicals and carcinogenesis in rat liver. Cancer Res 30(8):2091–2097.4318918
Cornblath M, Hartmann AF. 1948. Methemoglobinemia in young infants. J Pediatr 33:421–425.18887514
Cornell University. 2009. Nitrogen: All forms are not equal. Cornell University, Cooperative Extension. www.greenhouse.cornell.edu/crops/factsheets/nitrogen_form.pdf. November 17, 2014.
Cortas NK, Wakid NW. 1991. Pharmacokinetic aspects of inorganic nitrate ingestion in man. Pharmacol Toxicol 68(3):192–195.2057449
Cortesi ML, Vollano L, Francesca M, . 2015. Determination of nitrate and nitrite levels in infant foods marketed in Southern Italy. CyTA - Journal of Food 13(4):629–634. 10.1080/19476337.2015.1035337.
Costa LG, Aschner M, Vitalone A, . 2004. Developmental neuropathology of environmental agents. Annu Rev Pharmacol Toxicol 44:87–110.14744240
Couch DB, Friedman MA. 1975. Interactive mutagenicity of sodium nitrite, dimethylamine, methylurea, and ethylurea. Mutat Res 31:109–114.1090815
Craun GF, Greathouse DG, Gunderson DH. 1981. Methemoglobin levels in young children consuming high nitrate well water in the USA. Int J Epidemiol 10(4):309–317.7327829
Croen LA, Todoroff K, Shaw GM. 2001. Maternal exposure to nitrate from drinking water and diet and risk for neural tube defects. Am J Epidemiol 153(4):325–331.11207149
Cuello C, Correa P, Haenszel W, . 1976. Gastric cancer in Colombia: I. Cancer risk and suspect environmental agents. J Natl Cancer Inst 57(5):1015–1020.1003537
Dahlquist GG, Blom LG, Persson LA, . 1990. Dietary factors and the risk of developing insulin dependent diabetes in childhood. Br Med J 300(6735):1302–1306.2369660
Dean JA. 1985. Table 5-7. Proton-transfer reactions of inorganic materials in water at 25 °C. In: Lange’s handbook of chemistry. Thirteenth ed. New York, NY: McGraw Hill Book Company, 5–16.
De Flora S. 1981. Study of 106 organic and inorganic compounds in the Salmonella/microsome test. Carcinogenesis 2:283–298.7023727
De Flora S, Zanacchi P, Camoirano A, . 1984. Genotoxic activity and potency of 135 compounds in the Ames reversion test and in a bacterial DNA-repair test. Mutat Res 133:161–198.6374443
De Groef B, Decallonne BR, Van der Geyten S, . 2006. Perchlorate versus other environmental sodium/iodide symporter inhibitors: Potential thyroid-related health effects. Eur J Endocrinol 155(1):17–25.16793945
DellaValle CT, Daniel CR, Aschebrook-Kilfoy B, . 2013. Dietary intake of nitrate and nitrite and risk of renal cell carcinoma in the NIH-AARP Diet and Health Study. Br J Cancer 108:205–212.23169285
Denshaw-Burke M, DelGiacco E, Curran AL, . 2013. Methemoglobinemia. In: Medscape. http://emedicine.medscape.com/article/204178-overview. May 13, 2014.
De Roos AJ, Ward MH, Lynch CF, . 2003. Nitrate in public water supplies and the risk of colon and rectum cancers. Epidemiology 14(6):640–649.14569178
DOE. 2012. Protective action criteria (PAC). Oak Ridge, TN: U.S. Department of Energy and Subcommittee on Consequence Assessment and Protective Actions (SCAPA). http://orise.orau.gov/emi/scapa/chem-pacs-teels/default.htm. January 08, 2014.
Donahoe WE. 1949. Cyanosis in infants with nitrates in drinking water as cause. Pediatrics 3(3):308–311.18113111
Dorsch MM, Scragg RK, McMichael AJ, . 1984. Congenital malformations and maternal drinking water supply in rural South Australia: A case-control study. Am J Epidemiol 119(4):473–486.6711537
*Druckrey H, Steinhoff D, Beuthner H, . 1963. Screening of nitrite for chronic toxicity in rats. Arzneim Forsch 13:320–323.
Dusdieker LB, Getchell JP, Liarakos TM, . 1994. Nitrate in baby foods: Adding to the nitrate mosaic. Arch Pediatr Adolesc Med 148(5):490–494.8180640
DWI. 1999. Nitrate in drinking water and childhood-onset insulin-dependent diabetes mellitus in Scotland and central England. Drinking Water Inspectorate. DWI0801. http://dwi.defra.gov.uk/research/completed-research/reports/dwi0801.pdf. November 17, 2014.
EEA. 2010. Data and maps. Maps and graphs. The nitrogen cycle. European Environment Agency. http://www.eea.europa.eu/data-and-maps/figures/the-nitrogen-cycle. July 8, 2014.
Ehrenberg L, Hussain S, Noor Saleh M, . 1980. Nitrous esters: A genetical hazard from nitrogen oxides (NO_x_)? Hereditas 92:127–130.
Ek CJ, Dziegielewska KM, Habgood MD, . 2012. Barriers in the developing brain and neurotoxicology. Neurotoxicology 33(3):586–604.22198708
El-Wakf AM, Hassan HA, El-said FG, . 2008. Hypothyroidism in male rats of different ages exposed to nitrate polluted drinking water. Mansoura J Forensic Med Clin Toxicol 15(2):77–89.
El-Wakf AM, Hassan HA, Mahmoud AZ, . 2015. Fenugreek potent activity against nitrate-induced diabetes in young and adult male rats. Cytotechnology 67(3):437–447. 10.1007/s10616-014-9702-7.24615531
Engel LS, Chow WH, Vaughan TL, . 2003. Population attributable risks of esophageal and gastric cancers. J Natl Cancer Inst 95(18):1404–1413.13130116
Environment Canada. 2012. Nitrate ion. Canadian environmental quality guidelines. http://ceqg-rcqe.ccme.ca/download/en/197/. May 20, 2014.
EPA. 1990a. The drinking water criteria document on nitrate/nitrite. Washington, DC: U.S. Environmental Protection Agency. PB91142836.
EPA. 1990b. Interim methods for development of inhalation reference concentrations. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Office of Research and Development. EPA600890066A. PB90238890.
EPA. 1993. Method 353.2. Determination of nitrate-nitrite nitrogen by automated colorimetry. Cincinnati, OH: U.S. Environmental Protection Agency. http://water.epa.gov/scitech/methods/cwa/bioindicators/upload/2007_07_10_methods_method_353_2.pdf. May 21, 2014.
EPA. 1997. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics. EPA630R96012.
EPA. 1998. RCRA waste minimization PBT priority chemical list. U.S. Environmental Protection Agency. Fed Regist 63 FR 60332. http://www.gpo.gov/fdsys. January 08, 2014.
EPA. 2008. Child-specific exposure facts handbook. Washington, DC: U.S. Environmental Protection Agency, National Center for Environmental Assessment, Office of Research and Development. EPA600R06096F.
EPA. 2009a. Contaminant occurrence support document for category 2 contaminants for the second six-year review of national primary drinking water regulations. U.S. Environmental Protection Agency. EPA815B09011. http://water.epa.gov/lawsregs/rulesregs/regulatingcontaminants/sixyearreview/second_review/upload/6YearCategory2Report_final.pdf. May 21, 2014.
EPA. 2009b. Drinking water contaminant candidate list. U.S. Environmental Protection Agency. Fed Regist 74 FR 51850:51850-51862. http://www.gpo.gov/fdsys. January 08, 2014.
EPA. 2009c. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency, Office of Ground Water and Drinking Water. EPA816F090004. http://water.epa.gov/drink/contaminants/. January 08, 2014.
EPA. 2009d. Nitrogen and phosphorus loads in large rivers. Report on the environment. U.S. Environmental Protection Agency. http://cfpub.epa.gov/eroe/index.cfm?fuseaction=detail.viewInd&lv=list.listbyalpha&r=216594&subtop=200. June 17, 2015.
EPA. 2012a. CADDIS volume 2: Sources. stressors & responses. Ammonia: Simple conceptual diagram. Nitrogen cycle. U.S. Environmental Protection Agency. http://www.epa.gov/caddis/ssr_amm_nitrogen_cycle_popup.html. July 7, 2014.
EPA. 2012b. Drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency, Office of Water. EPA822S12001. http://water.epa.gov/drink/standards/hascience.cfm. January 08, 2014.
EPA. 2013a. Acute exposure guideline levels (AEGLs). Washington, DC: U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics. http://www.epa.gov/oppt/aegl/. January 08, 2014.
EPA. 2013b. Designated as hazardous substances in accordance with section 311(b)(2)(a) of the Clean Water Act. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 116.4. http://www.gpo.gov/fdsys. January 08, 2014.
EPA. 2013c. Identification and listing of hazardous waste. Hazardous constituents. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 261, Appendix VIII. http://www.gpo.gov/fdsys. January 08, 2014.
EPA. 2013d. Reportable quantities of hazardous substances designated pursuant to section 311 of the Clean Water Act. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 117.3. http://www.gpo.gov/fdsys. January 08, 2014.
EPA. 2013e. Standards for owners and operators of hazardous waste TSD facilities. Groundwater monitoring list. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 264, Appendix IX. http://www.gpo.gov/fdsys. January 08, 2014.
EPA. 2013f. Superfund, emergency planning, and community right-to-know programs. Designation, reportable quantities, and notifications. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 302.4. http://www.gpo.gov/fdsys. January 08, 2014.
EPA. 2013g. Superfund, emergency planning, and community right-to-know programs. Extremely hazardous substances and their threshold planning quantities. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 355, Appendix A. http://www.gpo.gov/fdsys. January 08, 2014.
EPA. 2013h. Superfund, emergency planning, and community right-to-know programs. Toxic chemical release reporting. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 372.65. http://www.gpo.gov/fdsys. January 08, 2014.
EPA. 2013i. Toxic Substances Control Act. Chemical lists and reporting periods. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 712.30. http://www.gpo.gov/fdsys. January 08, 2014.
EPA. 2013j. Toxic Substances Control Act. Health and safety data reporting. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 716.120. http://www.gpo.gov/fdsys. January 08, 2014.
EPA. 2014a. Hazardous air pollutants. Clean Air Act. U.S. Environmental Protection Agency. United States Code 42 USC 7412. http://www.epa.gov/ttn/atw/orig189.html. January 08, 2014.
EPA. 2014b. Inert ingredients permitted for use in nonfood pesticide products. Washington, DC: U.S. Environmental Protection Agency. http://iaspub.epa.gov/apex/pesticides/f?p=124:1. January 08, 2014.
EPA. 2014c. Master testing list. Washington, DC: U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics. http://www.epa.gov/opptintr/chemtest/pubs/mtl.html. January 08, 2014.
EPA. 2014d. National ambient air quality standards (NAAQS). Washington, DC: U.S. Environmental Protection Agency, Office of Air and Radiation. http://www.epa.gov/air/criteria.html. January 08, 2014.
EPA. 2014e. National recommended water quality criteria. Washington, DC: U.S. Environmental Protection Agency, Office of Water, Office of Science and Technology. http://water.epa.gov/scitech/swguidance/standards/criteria/current/index.cfm. January 08, 2014.
EPA. 2014f. Ammonium nitrate, CAS registry 6484-52-2; sodium nitrate, CAS registry 7631-99-4; sodium nitrite, CAS registry 7632-00-0; potassium nitrate, CAS registry 7757-79-1; potassium nitrite, CAS registry 7758-09-0. Pesticide chemical search. U.S. Environmental Protection Agency. http://iaspub.epa.gov/apex/pesticides/f?p=CHEMICALSEARCH:1:0. May 23, 2014.
EPA. 2014g. 2012. Chemical data reporting (CDR) information on the production and use of chemicals manufactured or imported into the United States. U.S. Environmental Protection Agency. http://java.epa.gov/oppt_chemical_search/. November 17, 2014.
Ericson A, Kallen B, Lofkvist E. 1988. Environmental factors in the etiology of neural tube defects: A negative study. Environ Res 45(1):38–47.3338434
Eskandari S, Loo DDF, Dai G, . 1997. Thyroid Na+/I- symporter. J Biol Chem. 272(43):27230–27238.9341168
Eskiocak S, Dundar C, Basoglu T, . 2005. The effects of taking chronic nitrate by drinking water on thyroid functions and morphology. Clin Exp Med 5(2):66–71.16096856
Espejo-Herrera N, Cantor KP, Malats N, . 2015. Nitrate in drinking water and bladder cancer risk in Spain. Environ Res 137:299–307. 10.1016/j.envres.2014.10.034.25601732
Espejo-Herrera N, Gracia-Lavedan E, Boldo E, . 2016a. Colorectal cancer risk and nitrate exposure through drinking water and diet. Int J Cancer 139(2):334–346. 10.1002/ijc.30083.26954527
Espejo-Herrera N, Gracia-Lavedan E, Pollan M, . 2016b. Ingested nitrate and breast cancer in the Spanish multicase-control study on cancer (MCC-Spain). Environ Health Perspect 124(7):1042–1029. 10.1289/ehp.1510334.26942716
Exner ME, Perea-Estrada H, Spalding RF. 2010. Long-term response of groundwater nitrate concentrations to management regulations in Nebraska’s central Platte valley. Sci World J 10:286–297.
Fan AM, Steinberg VE. 1996. Health implications of nitrate and nitrite in drinking water: An update on methemoglobinemia occurrence and reproductive and developmental toxicity. Regul Toxicol Pharmacol 23(1 Part 1):35–43.8628918
Fan AM, Willhite CC, Book SA. 1987. Evaluation of the nitrate drinking water standard with reference to infant methemoglobinemia and potential reproductive toxicity. Regul Toxicol Pharmacol 7(2):135–148.3303167
Fandrem SI, Kjuus H, Andersen A, . 1993. Incidence of cancer among workers in a Norwegian nitrate fertiliser plant. Br J Ind Med 50(7):647–652.8393697
Faucett RL, Miller HC. 1946. Methemoglobinemia occurring in infants fed milk diluted with well water of high nitrate content. J Pediatr 29(5):593–596.21002863
FDA. 2013. Requirements for specific standardized beverages. U.S. Food and Drug Administration. Code of Federal Regulations 21 CFR 165.110. http://www.gpo.gov/fdsys. January 08, 2014.
FDA. 2014. Everything added to food in the United States (EAFUS). Washington, DC: U.S. Food and Drug Administration. http://www.accessdata.fda.gov/scripts/fcn/fcnnavigation.cfm?rpt=eafuslisting. January 08, 2014.
Ferrant M. 1946. Methemoglobinemia; two cases in newborn infants caused by nitrates in well water. J Pediatr 29(5):585–592.21002862
Fewtrell L. 2004. Drinking-water nitrate, methemoglobinemia, and global burden of disease: A discussion. Environ Health Perspect 112(14):1371–1374.15471727
Finan A, Keenan P, Donovan FO, . 1998. Methaemoglobinaemia associated with sodium nitrite in three siblings. BMJ 317(7166):1138–1139.9784456
Fomon SJ. 1966. Body composition of the infant: Part 1: The male reference infant. In: Faulkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
Fomon SJ, Haschke F, Ziegler EE, . 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35(Suppl 5):1169–1175.7081099
Forman D, Al-Dabbagh S, Doll R. 1985. Nitrates, nitrites and gastric cancer in Great Britain. Nature 313(6004):620–625.3974695
Fraser P, Chilvers C, Day M, . 1989. Further results from a census based mortality study of fertilizer manufacturers. Br J Ind Med 46(1):38–42.2537650
Fraser P, Chilvers C, Goldblatt P. 1982. Census-based mortality study of fertilizer manufacturers. Br J Ind Med 39(4):323–329.6291578
Freedman DM, Cantor KP, Ward MH, . 2000. A case-control study of nitrate in drinking water and non-Hodgkin’s lymphoma in Minnesota. Arch Environ Health 55(5):326–329.11063407
Friedman MA, Staub J. 1976. Inhibition of mouse testicular DNA synthesis by mutagens and carcinogens as a potential simple mammalian assay for mutagenesis. Mutat Res 37(1):67–76.967187
Gangolli SD, Van Den Brandt PA, Feron VJ, . 1994. Nitrate, nitrite and N-nitroso compounds. Eur J Pharmacol 292:1–38.7867685
Gatseva PD, Argirova MD. 2008. Iodine status and goitre prevalence in nitrate-exposed schoolchildren living in rural Bulgaria. Public Health 122(5):458–461.18187169
Gautami S, Rao RN, Raghuram TC, . 1995. Accidental acute fatal sodium nitrite poisoning. J Toxicol Clin Toxicol 33(2):131–133.7897751
George M, Wiklund L, Aastrup M, . 2001. Incidence and geographical distribution of sudden infant death syndrome in relation to content of nitrate in drinking water and groundwater levels. Eur J Clin Invest 31(12):1083–1094.11903496
Giles GG, McNeil JJ, Donnan G, . 1994. Dietary factors and the risk of glioma in adults: Results of a case-control study in Melbourne, Australia. Int J Cancer 59(3):357–362.7927941
Giri AK, Talukder G, Sharma A. 1986. Sister chromatid exchange induced by metanil yellow and nitrite singly and in combination in vivo on mice. Cancer Lett 31(3):299–303.3741537
Giwercman A, Carlsen E, Keiding N, . 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect 101(Supp 2):65–71.7902273
Globus M, Samuel D. 1978. Effect of maternally administered sodium nitrite on hepatic erythropoiesis in fetal CD-1 mice. Teratology 18(3):367–378.741389
Gowans WJ. 1990. Fatal methaemoglobinaemia in a dental nurse. A case of sodium nitrite poisoning. Br J Gen Pract 40(340):470–471.2271282
Graf U, Frei H, Kaegi A, . 1989. Thirty compounds tested in the Drosophila wing spot test. Mutat Res 222(4):359–374.2495439
Grant D, Butler WH. 1989. Chronic toxicity of sodium nitrite in the male F344 rat. Food Chem Toxicol 27(9):565–571.2807101
Greenberg M, Birnkrant WB, Schiftner JJ. 1945. Outbreak of sodium nitrite poisoning. Am J Public Health Nations Health 35(11):1217–1220.18016267
Greenblatt M, Lijinsky W. 1972. Failure to induce tumors in Swiss mice after concurrent administration of amino acids and sodium nitrite. J Natl Cancer Inst 48(5):1389–1392.5030954
Greenblatt M, Lijinsky W. 1974. Carcinogenesis and chronic toxicity of nitrillotriacetic acid in Swiss mice. J Natl Cancer Inst 52(4):1123–1126.4826583
Greenblatt M, Mirvish SS. 1973. Dose-response studies with concurrent administration of piperazine and sodium nitrite to strain A mice. J Natl Cancer Inst. 50(1):119–124.4692858
Greenblatt M, Kommineni VR, Lijinsky W. 1973. Null effect of concurrent feeding of sodium nitrite and amino acids to MRC rats. J Natl Cancer Inst 50(3):799–802.4708158
Greenblatt M, Mirvish S, So BT. 1971. Nitrosamine studies: Induction of lung adenomas by concurrent administration of sodium nitrite and secondary amines in Swiss mice. J Natl Cancer Inst 46(5):1029–1034.5157841
Greer FR, Shannon M. 2005. Infant methemoglobinemia: The role of dietary nitrate in food and water. Pediatrics 116(3):784–786.16140723
Gruener N. 1974. The effect of nitrites on isolation-induced aggression in mice. Pharmacol Biochem Behav 2(2):267–269.4857297
Gruener N, Toeplitz R. 1975. The effect of changes in nitrate concentration in drinking water on methemoglobin levels in infants. Int J Environ Stud 7(3):161–163.
Gupta SK, Fitzgerald JF, Chong SK, . 1998. Expression of inducible nitric oxide synthase (iNOS) mRNA in inflamed esophageal and colonic mucosa in a pediatric population. Am J Gastroenterol 93(5):795–798.9625130
Gupta SK, Gupta RC, Seth AK, . 1999. Adaptation of cytochrome-b5 reductase activity and methaemoglobinaemia in areas with a high nitrate concentration in drinking-water. Bull World Health Organ 77(9):749–753.10534899
Guzelian PS, Henry CJ, Olin SS. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences and Press Institute Press.
Hagmar L, Bellander T, Andersson C, . 1991. Cancer morbidity in nitrate fertilizer workers. Int Arch Occup Environ Health 63(1):63–68.1649801
Hammerl A, Klapotke TM. 2006. Nitrogen: Inorganic chemistry. In: Encyclopedia of inorganic chemistry. Wiley Online Library. http://onlinelibrary.wiley.com/doi/10.1002/0470862106.ia157/abstract. May 20, 2014.
Hawkes CH, Cavanagh JB, Darling JL, . 1992. Chronic low-dose exposure of sodium nitrite in VM-strain mice: Central nervous system changes. Hum Exp Toxicol 11(4):279–281.1354977
Haymond S, Cariappa R, Eby CS, . 2005. Laboratory assessment of oxygenation in methemoglobinemia. Clin Chem 51(2):434–444.15514101
Health Canada. 2012. Nitrate and nitrite in drinking water. Health Canada. Federal-Provincial-Territorial Committee on Drinking Water. http://www.hc-sc.gc.ca/ewh-semt/alt_formats/pdf/consult/_2012/nitrite-nitrite/nitrite-nitrite-eng.pdf. May 21, 2014.
Hegesh E, Shiloah J. 1982. Blood nitrates and infantile methemoglobinemia. Clin Chim Acta 125(2):107–115.7139953
Hellmer L, Bolcsfoldi G. 1992. An evaluation of the Escherichia coli K-12 uvrB/recA DNA repair host-mediated assay: II. In vivo results for 36 compounds tested in the mouse. Mutat Res 272(2):161–173.1383748
Henderson WR, Raskin NH. 1972. “Hot dog” headache: Individual susceptibility to nitrite. Lancet 2(Dec):1162–1163.4117590
Hibbs JB, Westenfelder C, Taintor R, . 1992. Evidence for cytokine-inducible nitric oxide synthesis from L-arginine in patients receiving interleukin-2 therapy. J Clin Invest 89(3):867–877.1541678
Hirose M, Fukushima S, Hasegawa R, . 1990. Effects of sodium nitrite and catechol or 3-methoxycatechol in combination on rat stomach epithelium. Jpn J Cancer Res 81(9):857–861.2121686
Hirose M, Nishikawa A, Shibutani M, . 2002. Chemoprevention of heterocyclic amine-induced mammary carcinogenesis in rats. Environ Mol Mutagen 39(2–3):271–278.11921198
Hirose M, Tanaka H, Takahashi S, . 1993. Effects of sodium nitrite and catechol, 3-methoxycatechol, or butylated hydroxyanisole in combination in a rat multiorgan carcinogenesis model. Cancer Res 53(1):32–37.8416747
Hoel DG, Davis DL, Miller AB, . 1992. Trends in cancer mortality in 15 industrialized countries, 1969-1986. J Natl Cancer Inst 84(5):313–320.1738181
Holtby CE, Guernsey JR, Allen AC, . 2014. A population-based case-control study of drinking-water nitrate and congenital anomalies using geographic information systems (GIS) to develop individual-level exposure estimates. Int J Environ Res Public Health 11(2):1803–1823. 10.3390/ijerph110201803.24503976
Hord NG. 2011. Dietary nitrates, nitrites, and cardiovascular disease. Curr Atheroscler Rep 13(6):484–492.21968645
HSDB. 2003. Urea. Hazardous Substances Data Bank. National Library of Medicine. http://toxnet.nlm.nih.gov. November 17, 2014.
HSDB. 2007. Ammonium nitrate, sodium nitrate, sodium nitrite, potassium nitrate, and potassium nitrite. Hazardous Substances Data Bank. National Library of Medicine. http://toxnet.nlm.nih.gov. May 21, 2014.
HSDB. 2012. Ammonia. Hazardous Substances Data Bank. National Library of Medicine. http://toxnet.nlm.nih.gov. November 17, 2014.
Huber JC, Jr., Brender JD, Zheng Q, . 2013. Maternal dietary intake of nitrates, nitrites and nitrosamines and selected birth defects in offspring: A case-control study. Nutrition journal 12:34.23514444
Hugot D, Causeret J, Richir C. 1980. The influence of large amounts of sodium nitrite on reproductive performances in female rats. Ann Nutr Aliment 34:1115–1124.7258911
Huizenga JR, Tangerman A, Gips CH. 1994. Determination of ammonia in biological fluids. Ann Clin Biochem 31(Pt 6):529–543.7880071
Hunault CC, Lambers AC, Mensinga TT, . 2007. Effects of sub-chronic nitrate exposure on the thyroidal function in humans. Toxicol Lett 175(1–3):64–70.17980977
Huncharek M, Kupelnick B. 2004. A meta-analysis of maternal cured meat consumption during pregnancy and the risk of childhood brain tumors. Neuroepidemiology 23(1–2):78–84.14739572
Huncharek M, Kupelnick B, Wheeler L. 2003. Dietary cured meat and the risk of adult glioma: A meta-analysis of nine observational studies. J Environ Pathol Toxicol Oncol 22(2):129–137.14533876
Iammarino M, Di Taranto A, Cristino M. 2014. Monitoring of nitrites and nitrates levels in leafy vegetables (spinach and lettuce): A contribution to risk assessment. J Sci Food Agric 94(4):773–778. 10.1002/jsfa.6439.24122771
IARC. 2010. Ingested nitrate and nitrite. In: Ingested nitrate and nitrite, and cyanobacterial peptide toxins. IARC Monographs on the evaluation of the carcinogenic risk of chemicals to humans. Vol. 94. Lyon, France: International Agency for Research on Cancer, World Health Organization, 45–325.
IARC. 2014. Agents classified by the IARC monographs. Volumes 1–109. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Classification/index.php. May 15, 2014.
Ibrahim YI, Ninnis JR, Hopper AO, . 2012. Inhaled NO therapy increases blood nitrite, nitrate and S-nitrosohemoglobin concentrations in infants with pulmonary hypertension. J Pediatr 160(20):245–251.21907348
Ilnitsky AP, Kolpakova AS. 1997. The enhancing effect of sodium nitrite on virus-induced leukemia in mice. Cancer Detect Prev 21(4):312–318.9232321
Imaizumi K, Tyuma I, Imai K, . 1980. In vivo studies on methemoglobin formation by sodium nitrite. Int Arch Occup Environ Health 45(2):97–104.7364495
Inai K, Aoki Y, Tokuoka S. 1979. Chronic toxicity of sodium nitrite in mice, with reference to its tumorigenicity. Gann 70(2):203–208.467885
Inoue K, Shibata T, Kosaka H, . 1985. Induction of sister-chromatid exchanges by n-nitrosocimetidine in cultured human lymphocytes and its inhibition by chemical compounds. Mutat Res 156:117–121.4000174
Inoue-Choi M, Jones RR, Anderson KE, . 2015. Nitrate and nitrite ingestion and risk of ovarian cancer among postmenopausal women in Iowa. Int J Cancer 137(1):173–182. 10.1002/ijc.29365.25430487
Inoue-Choi M, Ward MH, Cerhan JR, . 2012. Interaction of nitrate and folate on the risk of breast cancer among postmenopausal women. Nutr Cancer 64(5):685–694.22642949
Inui N, Nishi Y, Mori M, . 1979. Detection of 8-azaguanine resistant mutants of embryonic cells induced by products formed in the stomach on oral administration of sodium nitrite plus aminopyrine to pregnant golden hamsters. Proceedings of the Japan Academy, Series B 55(6):286–289.
IRIS. 2002. Nitrite (CASRN 14797-65-0), nitrate (CASRN 14797-55-8). Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/iris/. January 08, 2014.
Ishidate MJ, Sofuni T, Yoshikawa K. 1981. Chromosomal aberration tests in vitro as a primary screening tool for environmental mutagens and/or carcinogens. Gann Monogr Cancer Res 27:95–108.
Ishidate MJ, Sofuni T, Yoshikawa K, . 1984. Primary mutagenicity screening of food additives currently used in Japan. Food Chem Toxicol 22(8):623–636.6381265
Iurchenko VA, Linnik AB, Il’nitskii AP. 1986. [Carcinogenic hazard of small doses of nitrite in connection with the endogenous synthesis of nitroso compounds]. Eksp Onkol 8(1):41–44.
Ivankovic S. 1979. Teratogenic and carcinogenic effects of some chemicals during prenatal life in rats, Syrian golden hamsters, and minipigs. Natl Cancer Inst Monogr 51:103–115.
Ivankovic S, Preussmann R. 1970. Transplacental production of malignant tumors after oral dose of ethylurea and nitrite to rats. Naturwissenschaften 57:460.5528616
Jablonska S. 1975. Ingestion of ammonium nitrate as a possible cause of erythema dyschromicum perstans (ashy dermatosis). Dermatologica 150(5):287–291.1183692
Jansen EHJ, Van Den Berg RH, Boink ABT, . 1995. A new physiological biomarker for nitrate exposure in humans. Toxicol Lett 77(1–3):265–269.7618150
Jansson EA, Huang L, Malkey R, . 2008. A mammalian functional nitrate reductase that regulates nitrite and nitric oxide homeostasis. Nat Chem Biol 4(7):411–417.18516050
JECFA. 2003a. Nitrate (and potential endogenous formation of N-nitroso compounds). WHO Food Additives Series 50. Joint Expert Committee on Food Additives. International Programme on Chemical Safety. http://www.inchem.org/documents/jecfa/jecmono/v50je06.htm. May 22, 2014.
JECFA. 2003b. Nitrite (and potential endogenous formation of N-nitroso compounds). WHO Food Additives Series 50. Joint Expert Committee on Food Additives. International Programme on Chemical Safety. 1057. http://www.inchem.org/documents/jecfa/jecmono/v50je05.htm. December 18, 2013.
JECFA. 2003c. Nitrate and nitrite: Intake assessment. WHO Food Additives Series 50. Joint Expert Committee on Food Additives. 1059. http://www.inchem.org/documents/jecfa/jecmono/v50je07.htm. December 18, 2013.
Johnson CJ, Bonrud PA, Dosch TL, . 1987. Fatal outcome of methemoglobinemia in an infant. J Am Med Assoc 257(20):2796.
Jones HJ, Sethney HT, Schoenhals GW, . 1973. Grandmother’s poisoned well: Report of a case of methemoglobinemia in an infant in Oklahoma. J Okla State Med Assoc 66(2):60–66.4688467
Jones JA, Hopper AO, Power GG, . 2015. Dietary intake and bio-activation of nitrite and nitrate in newborn infants. Pediatr Res 77(1–2):173–181. 10.1038/pr.2014.168.25314582
Jones JA, Ninnis JR, Hopper AO, . 2014. Nitrite and nitrate concentrations and metabolism in breast milk, infant formula, and parenteral nutrition. JPEN J Parenter Enteral Nutr 38(7):856–866. 10.1177/0148607113496118.23894175
Joossens JV, Hill MJ, Elliott P, . 1996. Dietary salt, nitrate and stomach cancer mortality in 24 countries. European Cancer Prevention (ECP) and the INTERSALT Cooperative Research Group. Int J Epidemiol 25(3):494–504.8671549
Kahn HD, Stralka K. 2009. Estimated daily average per capita water ingestion by child and adult age categories based on USDA’s 1994-1996 and 1998 continuing survey of food intakes by individuals. J Expo Sci Environ Epidemiol 19(4):396–404.18478044
Kamiyama S, Ohshima H, Shimada A, . 1987. Urinary excretion of N-nitrosamino acids and nitrate by inhabitants in high and low-risk areas for stomach cancer in northern Japan. IARC Sci Publ 84:497–502.
Kanady JA, Aruni AW, Ninnis JR, . 2012. Nitrate reductase activity of bacteria in saliva of term and preterm infants. Nitric Oxide 27(4):193–200.22842223
Kaplan A, Smith C, Promnitz DA, . 1990. Methaemoglobinaemia due to accidental sodium nitrite poisoning. Report of 10 cases. S Afr Med J 77(6):300–301.2315812
Kawabe M, Takaba K, Yoshida Y, . 1994. Effects of combined treatment with phenolic compounds and sodium nitrite on two-stage carcinogenesis and cell proliferation in the rat stomach. Jpn J Cancer Res 85(1):17–25.8106288
Kearns GL, Abdel-Rahman SM, Alander SW, . 2003. Developmental pharmacology-drug disposition, action, and therapy in infants and children. N Engl J Med 349(12):1157–1167.13679531
Keating JP, Lell ME, Strauss AW, . 1973. Infantile methemoglobinemia caused by carrot juice. N Engl J Med 288(16):824–826.4693932
Kelley ST, Oehme FW, Hoffman SB. 1974. Effect of chronic dietary nitrates on canine thyroid function. Toxicol Appl Pharmacol 27(1):200–203.4851616
Khera KS. 1982. Reduction of teratogenic effects of ethylenethiourea in rats by interaction with sodium nitrite in vivo. Food Chem Toxicol 20:273–278.7201954
Kilfoy BA, Ward MH, Zheng T, . 2010. Risk of non-Hodgkin lymphoma and nitrate and nitrite from the diet in Connecticut women. Cancer Causes Control 21(6):889–896. 10.1007/s10552-010-9517-6.20204494
Kilfoy BA, Zhang Y, Park Y, . 2011. Dietary nitrate and nitrite and the risk of thyroid cancer in the NIH-AARP Diet and Health Study. Int J Cancer 129(1):160–172. 10.1002/ijc.25650.20824705
Kim HJ, Lee SS, Choi BY, . 2007. Nitrate intake relative to antioxidant vitamin intake affects gastric cancer risk: A case-control study in Korea. Nutr Cancer 59(2):185–191.18001213
Kim SJ, Rim KT, Kim JK, . 2011. Evaluation of the genetic toxicity of cyclopentane and ammonium nitrate in vitro mammalian chromosomal aberration assay in Chinese hamster ovary cells. Saf Health Work 2(1):17–25.22953183
Kissel DE, Cabrera ML, Paramasivam S. 2008. Ammonium, ammonia, and urea reactions in soils. In: Schepers JS, Raun WR, eds. Nitrogen in agricultural systems. Madison, WI: American Society of Agronomy, Inc., Crop Science Society of America, Inc., Soil Science Society of America, Inc., 101–155.
Kitano M, Takada N, Chen T, . 1997. Carcinogenicity of methylurea or morpholine in combination with sodium nitrite in rat multi-organ carcinogenesis bioassay. Jpn J Cancer Res 88(9):797–806.9369926
Kitchen NR, Blanchard PE, Lerch RN. 2015. Long-term agroecosystem research in the central Mississippi river basin: Hydrogeologic controls and crop management influence on nitrates in loess and fractured glacial till. J Environ Qual 44(1):58–70. 10.2134/jeq2014.09.0405.25602321
Kleinjans JC, Albering HJ, Marx A, . 1991. Nitrate contamination of drinking water evaluation of genotoxic risk in human populations. Environ Health Perspect 94(0):189–194.1954930
Knaapen AM, Schins RP, Borm PJ, . 2005. Nitrite enhances neutrophil-induced DNA strand breakage in pulmonary epithelial cells by inhibition of myeloperoxidase. Carcinogenesis 26(9):1642–1648. 10.1093/carcin/bgi116.15878909
Knekt P, Jarvinen R, Dich J, . 1999. Risk of colorectal and other gastro-intestinal cancers after exposure to nitrate, nitrite and N-nitroso compounds: A follow-up study. Int J Cancer 80(6):852–856.10074917
Knight TM, Forman D, Pirastu R, . 1990. Nitrate and nitrite exposure in Italian populations with different gastric cancer rates. Int J Epidemiol 19(3):510–515.2262241
Komori M, Nishio K, Kitada M, . 1990. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry 29(18):4430–4433.2350547
Kortboyer JM, Boink ABTJ, Schothorst RC, . 1998b. Healthy volunteer study investigating the feasibility of an oral bioavailability study of nitrate from vegetables. The Netherlands: National Institute of Public Health and the Environment. RIVM Report 235802012.
Kortboyer JM, Boink ABTJ, Zeilmaker MJ, . 1997a. Methemoglobin formation due to nitrite: Dose-effect relationship in vitro. The Netherlands: National Institute of Public Health and the Environment. RIVM Report 235802006.
Kortboyer JM, Colbers EHP, Vaessen HAMG, . 1995. A pilot-study to investigate nitrate and nitrite kinetics in healthy volunteers with normal and artificially increased gastric pH after sodium nitrate ingestion. In: Health aspects of nitrate and its metabolites (particularly nitrite). Strasbourg: Publishing and Documentation Service, Council of Europe Press, 269–286.
Kortboyer JM, Olling M, Zeilmaker MJ, . 1997b. The oral bioavailability of sodium nitrite investigated in healthy adult volunteers Bilthoven, Netherlands: National Institute for Public Health and the Environment. RIVM Report No. 235802007.
Kortboyer JM, Schothorst RC, Zeilmaker MJ, . 1998a. Intravenous administration of sodium nitrite in healthy volunteers: A single ascending dose study. The Netherlands: National Institute of Public Health and the Environment. RIVM Report 235802011.
Kosaka H, Imaizumi K, Imai K, . 1979. Stoichiometry of the reaction of oxyhemoglobin with nitrite. Biochim Biophys Acta 581(1):184–188.41590
Kostraba JN, Gay EC, Rewers M, . 1992. Nitrate levels in community drinking waters and risk of IDDM: An ecological analysis. Diabetes Care 15(11):1505–1508.1468277
Kramer SB, Reganold JP, Glover JD, . 2006. Reduced nitrate leaching and enhanced denitrifier activity and efficiency in organically fertilized soils. Proc Natl Acad Sci USA 103(12):4522–4527.16537377
Krishnan K, Andersen ME. 1994. Physiologically based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. 3rd ed. New York, NY: Raven Press, Ltd., 149–188.
Krishnan K, Anderson ME, Clewell HJ, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
La Vecchia C, Ferraroni M, D’Avanzo B, . 1994. Selected micronutrient intake and the risk of gastric cancer. Cancer Epidemiol Biomarkers Prev 3(5):393–398.7920206
La Vecchia C, Negri E, Franceschi S, . 1997. Case-control study on influence of methionine, nitrite, and salt on gastric carcinogenesis in northern Italy. Nutr Cancer 27(1):65–68.8970184
Lambers AC, Kortboyer JM, Schothorst RC, . 2000. The oral bioavailability of nitrate from vegetables investigated in health volunteers. The Netherlands: National Institute of Public Health and the Environment. RIVM Report 235802014.
Lee M, Wrensch M, Miike R. 1997. Dietary and tobacco risk factors for adult onset glioma in the San Francisco Bay Area (California, USA). Cancer Causes Control 8(1):13–24.9051318
Leeder JS, Kearns GL. 1997. Pharmacogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77.9057784
Leikin JB, Paloucek FP. 2008. Poisoning and toxicology handbook. 4th ed. Boca Raton, FL: CRC Press, 830.
Leung H. 1993. Physiologically-based pharmacokinetic modelling. In: Ballantyne B, Marrs T, Turner P, eds. General and applied toxicology. Vol. 1. New York, NY: Stockton Press, 153–164.
Levallois P, Ayotte P, Van Maanen JMS, . 2000. Excretion of volatile nitrosamines in a rural population in relation to food and drinking water consumption. Food Chem Toxicol 38(11):1013–1019.11038239
Lewis RJ. 2002. Sodium nitrate. In: Sax’s dangerous properties of industrial materials. Hoboken, NJ: John Wiley & Sons, Inc, 3265.
L’hirondel J, L’hirondel JL. 2002. The case against nitrate: A critical examination. In: Nitrate and man. Toxic, harmless or beneficial? Wallingford, UK: CABI Publishing, 35–69.
Lide DR. 2013. Sodium nitrate. In: CRC handbook of chemistry and physics. 94th ed. Boca Raton, FL: Taylor & Francis Group, LLC, 4–90.
Lijinsky W. 1984a. Induction of tumors of the nasal cavity in rats by concurrent feeding of thiram and sodium nitrite. J Toxicol Environ Health 13(4–6):609–614.6492190
Lijinsky W. 1984b. Induction of tumours in rats by feeding nitrosatable amines together with sodium nitrite. Food Chem Toxicol 22(9):715–720.6541624
Lijinsky W, Greenblatt M. 1972. Carcinogen dimethylnitrosamine produced in vivo from nitrite and aminopyrine. Nat New Biol 236(67):177–178.4503733
Lijinsky W, Reuber MD. 1980. Tumors induced in Fischer 344 rats by the feeding of disulfiram together with sodium nitrite. Food Cosmet Toxicol 18(1):85–87.7372216
Lijinsky W, Taylor HW. 1977. Feeding tests in rats on mixtures of nitrite with secondary and tertiary amines of environmental importance. Food Cosmet Toxicol 15:269–274.590887
Lijinsky W, Greenblatt M, Kommineni C. 1973a. Brief communication: Feeding studies of nitrilotriacetic acid and derivatives in rats. J Natl Cancer Inst 50(4):1061–1063.4703771
Lijinsky W, Kovatch R, Riggs CW. 1983. Altered incidences of hepatic and hemopoietic neoplasms in F344 rats fed sodium nitrite. Carcinogenesis 4(9):1189–1191.6576871
Lijinsky W, Taylor HW, Snyder C, . 1973b. Malignant tumours of liver and lung in rats fed aminopyrine or heptamethyleneimine together with nitrite. Nature 244(5412):176–178.4583503
Lin JK, Ho YS. 1992. Hepatotoxicity and hepatocarcinogenicity in rats fed squid with or without exogenous nitrite. Food Chem Toxicol 30(8):695–702.1328003
Lin K, Shen W, Shen Z, . 2003. Estimation of the potential for nitrosation and its inhibition in subjects from high- and low-risk areas for esophageal cancer in southern China. Int J Cancer 107(6):891–895.14601047
Livingston AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4(2–3):301–324.351201
Lu SH, Ohshima H, Fu HM, . 1986. Urinary excretion of n nitrosamino-acids and nitrate by inhabitants of high-risk and low-risk areas for esophageal cancer in northern China: Endogenous formation of nitrosoproline and its inhibition by vitamin C. Cancer Res 46(3):1485–1491.3943105
Luca D, Luca V, Cotor F, . 1987. In vivo and in vitro cytogenetic damage induced by sodium nitrite. Mutat Res 189(3):333–340.3670336
Luca D, Raileanu L, Luca V, . 1985. Chromosomal aberrations and micronuclei induced in rat and mouse bone marrow cells by sodium nitrate. Mutat Res 155(3):121–126.3974626
Lundberg JO, Govoni M. 2004. Inorganic nitrate is a possible source for systemic generation of nitric oxide. Free Radic Biol Med 37(3):395–400.15223073
Lundberg JO, Weitzberg E. 2013. Biology of nitrogen oxides in the gastrointestinal tract. Gut 62(4):616–629.22267589
Lundberg JO, Gladwin MT, Ahluwalia A, . 2009. Nitrate and nitrite in biology, nutrition and therapeutics. Nat Chem Biol 5(12):865–869.19915529
Lundberg JO, Weitzberg E, Gladwin MT. 2008. The nitrate-nitrite-nitric oxide pathway in physiology and therapeutics. Nat Rev Drug Discov 7(2):156–167.18167491
Lynch SC, Gruenwedel DW, Russell GF. 1983. Mutagenic activity of a nitrosated early Maillard product: DNA synthesis (DNA repair) induced in HeLa S3 carcinoma cells by nitrosated 1-(N-L-tryptophan)-1-deoxy-D-fructose. Food Chem Toxicol 21(5):551–556.6197349
Machha A, Schechter AN. 2012. Inorganic nitrate: A major player in the cardiovascular health benefits of vegetables? Nutr Rev 70(6):367–372.22646129
Maekawa A, Ishiawata H, Odashima S. 1977. Transplacental carcinogenesis and chemical determination of 1-butyl-1-nitrosourea in stomach content after simultaneous oral administration of 1-butylurea and sodium nitrite to ACI rats. Gann. 68(1):81–88.863175
Maekawa A, Ogiu T, Onodera H, . 1982. Carcinogenicity studies of sodium nitrite and sodium nitrate in F-344 rats. Food Chem Toxicol 20(1):25–33.7200054
Malberg JW, Savage EP, Osteryoung J. 1978. Nitrates in drinking water and the early onset of hypertension. Environ Pollut 15:155–160.
Manassaram DM, Backer LC, Messing R, . 2010. Nitrates in drinking water and methemoglobin levels in pregnancy: A longitudinal study. Environ Health 9:60.20946657
Markusova K, Kohutova L, Dzurov J. 1996. Programmed-potential voltammetric determination of nitrate as a static mercury drop electrode in natural waters and soil extracts. Electroanalysis 8(6):582–584.
Marshall PA, Trenerry VC. 1996. The determination of nitrite and nitrate in foods by capillary ion electrophoresis. Food Chem 57(2):339–345.
Martinez A, Sanchez-Valverde F, Gil F, . 2013. Methemoglobinemia induced by vegetable intake in infants in northern Spain. J Pediatr Gastroenterol Nutr 56(5):573–577. 10.1097/MPG.0b013e3182849d2b.23287806
Mascher F, Marth E. 1993. Metabolism and effect of nitrates. Cent Eur J Public Health 1(1):49–52.8305891
Matsukura N, Kawachi T, Sasajima K, . 1977. Induction of liver tumors in rats by sodium nitrite and methylguanidine. Z Krebsforsch 90(1):87–94.
Matsumoto K, Tanaka H. 1996. Formation and dissociation of atmospheric particulate nitrate and chloride: An approach based on phase equilibrium. Atmos Environ 30(4):639–648.
Mayne ST, Risch HA, Dubrow R, . 2001. Nutrient intake and risk of subtypes of esophageal and gastric cancer. Cancer Epidemiol Biomarkers Prev 10(10):1055–1062.11588131
Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74(2–3):135–149.1387742
McCann J, Choi E, Yamasaki E, . 1975. Detection of carcinogens as mutagens in the salmonella/microsome test: Assay of 300 chemicals. Proc Natl Acad Sci USA 72:5135–5139.1061098
McElroy JA, Trentham-Dietz A, Gangnon RE, . 2008. Nitrogen-nitrate exposure from drinking water and colorectal cancer risk for rural women in Wisconsin, USA. J Water Health 6(3):399–409.19108561
McKnight GM, Smith LM, Drummond RS, . 1997. Chemical synthesis of nitric oxide in the stomach from dietary nitrate in humans. Gut 40(2):211–214.9071933
McLetchie NGB, Robertson HE. 1994. Nitrate poisoning from well-water. Can Med Assoc J 60:230–233.
Medovy H. 1948. Well-water methemoglobinemia in infants, its occurrence in rural Manitoba and Ontario. J Lancet 68(5):194–196.18858654
Michaud DS, Holick CN, Batchelor TT, . 2009. Prospective study of meat intake and dietary nitrates, nitrites, and nitrosamines and risk of adult glioma. Am J Clin Nutr 90(3):570–577.19587083
Miller LW. 1971. Methemoglobinemia associated with well water. J Am Med Assoc 216(10):1642–1643.
Mirvish SS, Bulay O, Runge RG, . 1980. Study of the carcinogenicity of large doses of dimethylnitramine, n-nitroso-l-proline, and sodium nitrite administered in drinking water to rats. J Natl Cancer Inst 64(6):1435–1442.6929379
Mirvish SS, Greenblatt M, Kommineni VR. 1972. Nitrosamide formation in vivo: Induction of lung adenomas in Swiss mice by concurrent feeding of nitrite and methylurea or ethylurea. J Natl Cancer Inst 48(5):1311–1315.5030951
Mirvish SS, Patil K, Ghadirian P, . 1975. Disappearance of nitrite from the rat stomach: Contribution of emptying and other factors. J Natl Cancer Inst 54(4):869–875.236394
Mirvish SS, Pelfrene AF, Garcia H, . 1976. Effect of sodium ascorbate on tumor induction in rats treated with morpholine and sodium nitrite, and with nitrosomorpholine. Cancer Lett 2(2):101–108.1016958
Mirvish SS, Salmasi S, Cohen SM, . 1983. Liver and forestomach tumors and other forestomach lesions in rats treated with morpholine and sodium nitrite, with and without sodium ascorbate. J Natl Cancer Inst 71(1):81–85.6575214
Miyauchi M, Nakamura H, Furukawa F, . 2002. Promoting effects of combined antioxidant and sodium nitrite treatment on forestomach carcinogenesis in rats after initiation with N-methyl-N’-nitro-N-nitrosoguanidine. Cancer Lett 178(1):19–24.11849737
Mokhtar NM, el-Aaser AA, el-Bolkainy MN, . 1988. Effect of soybean feeding on experimental carcinogenesis-III. Carcinogenicity of nitrite and dibutylamine in mice: A histopathological study. Eur J Cancer Clin Oncol 24(3):403–411.3383943
Moller H. 1997. Work in agriculture, childhood residence, nitrate exposure, and testicular cancer risk: A case-control study in Denmark. Cancer Epidemiol Biomarkers Prev 6(2):141–144.9037566
Moller H, Landt J, Jensen P, . 1989. Nitrate exposure from drinking water and diet in a Danish rural population. Int J Epidemiol 18(1):206–212.2722365
Moltchanova E, Rytkonen M, Kousa A, . 2004. Zinc and nitrate in the ground water and the incidence of Type 1 diabetes in Finland. Diabet Med 21(3):256–261.15008836
Momen B, Zehr JP, Boylen CW, . 1999. Determinants of summer nitrate concentration in a set of Adirondack lakes, New York. Water Air Soil Pollut 111(1–4):19–28.
Monser L, Sadok S, Greenway GM, . 2002. A simple simultaneous flow injection method based on phosphomolybdenum chemistry for nitrate and nitrite determinations in water and fish samples. Talanta 57:511–518.18968650
Morales Suarez-Varela M, Llopis Gonzalez A, Tejerizo Perez ML, . 1993. Concentration of nitrates in drinking water and its relationship with bladder cancer. J Environ Pathol Toxicol Oncol 12(4):229–236.8189380
Morales Suarez-Varela M, Llopis Gonzalez A, Tejerizo Perez ML. 1995. Impact of nitrates in drinking water on cancer mortality in Valencia, Spain. Eur J Epidemiol 11(1):15–21.7489769
Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokinet 5(6):485–527.7002417
Mueller BA, Searles Nielsen S, Preston-Martin S, . 2004. Household water source and the risk of childhood brain tumours: Results of the SEARCH International Brain Tumor Study. Int J Epidemiol 33(6):1209–1216.15567873
Mulvaney RL. 1996. Nitrogen-inorganic forms. In: Sparks DL, ed. Methods of soil analysis. Part 3. Chemical Methods. Madison, WI: Soil Science Society of America, Inc. and American Society of Agronomy Inc., 1123–1184.
Mukhopadhyay S, Ghosh D, Chatterjee A, . 2005. Evaluation of possible goitrogenic and anti-thyroidal effect of nitrate, a potential environmental pollutant. Indian J Physiol Pharmacol 49(3):284–288.16440845
Murthy AS, Baker JR, Smith ER, . 1979. Neoplasms in rats and mice fed butylurea and sodium nitrite separately and in combination. Int J Cancer 23(2):253–259.761944
NAS/NRC. 1989. Report of the oversight committee. Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press, 15–35.
Nasseri-Moghaddam S, Mofid A, Razjouyan H. 2011. Dietary nitrate may have a role in development of gastro-esophageal reflux disease. Arch Iran Med 14(5):312–314.21888453
Newberne PM. 1979. Nitrite promotes lymphoma incidence in rats. Science 204(4397):1079–1081.451551
Newberne PM, Shank RC. 1973. Induction of liver and lung tumours in rats by the simultaneous administration of sodium nitrite and morpholine. Food Cosmet Toxicol 11(5):819–825.4358606
Newton WE. 2005. Nitrogen fixation. In: Kirk-Othmer encyclopedia of chemical toxicology. http://onlinelibrary.wiley.com/doi/10.1002/0471238961.1409201814052320.a01.pub2/abstract. May 21, 2014.
NFPA. 2002. In: Spencer AB, Colonna GR, eds. Fire protection guide to hazardous materials. Quincy, MA: National Fire Protection Association, 49–19, 704–710.
Nicola JP, Basquin C, Portulano C, . 2009. The Na+/I- symporter mediates active iodide uptake in the intestine. Am J Physiol Cell Physiol. 296(4):C654–662.19052257
NIOSH. 1994a. Acids, inorganic. Method 7903, Issue 2. NIOSH Manual of Analytical Methods. National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/docs/2003-154/pdfs/7903.pdf. May 20, 2014.
NIOSH. 1994b. Nitric oxide and nitrogen dioxide. Method 6014, Issue 1. NIOSH Manual of Analytical Methods. National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/docs/2003-154/pdfs/6014-1.pdf. May 20, 2014.
NIOSH. 1998. Nitric dioxide (diffusive sampler). Method 6700, Issue 2. NIOSH Manual of Analytical Methods. National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/docs/2003-154/pdfs/6700.pdf. May 20, 2014.
NIOSH. 2014. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. http://www.cdc.gov/niosh/npg/. January 08, 2014.
Nishiyama K, Ando-Lu J, Ishimura S, . 1998. Initiating and promoting effects of concurrent oral administration of ethylenethiourea and sodium nitrite on uterine endometrial adenocarcinoma development in Donryu rats. In Vivo 12(4):363–368.9706485
Nixon JE, Koller LD, Exon JH. 1979. Effect of methylmercury chloride on transplacental tumors induced by sodium nitrite and ethylurea in rats. J Natl Cancer Inst 63:1057–1963.480378
Nolan BT. 1999. Nitrate behavior in ground waters of the Southeastern USA. J Environ Qual 28(5):1518–1527.
Nolan BT, Ruddy BC, Hitt KJ, . 1997. Risk of nitrate in groundwaters of the United States: A national perspective. Environ Sci Technol 31(8):2229–2236.
Norat T, Lukanova A, Ferrari P, . 2002. Meat consumption and colorectal cancer risk: Dose-response meta-analysis of epidemiological studies. Int J Cancer 98(2):241–256.11857415
Nordin RN, Pommen LW. 1986. Water quality criteria for nitrogen (nitrate, nitrite, and ammonia). Victoria, BC: Ministry of Environment and Parks Province of British Columbia.
NRC. 1993. Pesticides in the diets of infants and children. Washington, DC: National Research Council. National Academy Press. PB93216091.
NTP. 2001. Toxicology and carcinogenesis studies of sodium nitrite in F 344/N rats and B6C3F1 mice (drinking water studies). National Toxicology Program Technical Report Series 495.
NTP. 2011. Report on carcinogens. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. http://ntp-server.niehs.nih.gov/ntp/roc/twelfth/roc12.pdf. January 08, 2014.
Nyakas C, Buwalda B, Kramers RJ, . 1994. Postnatal development of hippocampal and neocortical cholinergic and serotonergic innervation in rat: Effects of nitrite-induced prenatal hypoxia and nimodipine treatment. Neuroscience 59(3):541–559.8008208
Nyakas C, Markel E, Bohus B, . 1990. Protective effect of the calcium antagonist nimodipine on discrimination learning deficits and impaired retention behavior caused by prenatal nitrite exposure in rats. Behav Brain Res 38(1):69–76.2346617
Ohshima H, Bartsch H. 1988. Urinary N-nitrosamino acids as an index of exposure to N-nitroso compounds. In: Bartsch H, Hemminki K, O’Neil IK, eds. Methods for detecting DNA damaging agents in humans: Applications in cancer epidemiology and prevention. Vol. 89. International Agency for Research on Cancer Institute of Occupational Health, Finland Commission of the European Communities, 83–91.
Oka K, Betto K, Nishimori I. 1974. Development of sarcomata in the livers of albino rats given sodium nitrite and dimethylamine. (Report 1). Acta Med Nagasaki 18:13–25.
Oliveira CP, Gloria MB, Barbour JF, . 1995. Nitrate, nitrite, and volatile nitrosamines in whey-containing food products. J Agric Food Chem 43(4):967–969.
Olsen P, Gry J, Knudsen I, . 1984. Animal feeding study with nitrite-treated meat. International Agency for Research on Cancer. IARC Sci Publ 57:667–676.
Oms MT, Cerda A, Cerda V. 1995. Sequential injection analysis of nitrites and nitrates. Anal Chim Acta 315(3):321–330.
Ormerod AD, Shah AAJ, Li H, . 2011. An observational prospective study of topical acidified nitrite for killing methicillin-resistant Staphylococcus aureus (MRSA) in contaminated wounds. BioMed Central. BMC Res Notes 4(1):1–7. 10.1186/1756-0500-4-458. July 9, 2014.21205301
OSHA. 2013a. List of highly hazardous chemicals, toxics, and reactives. Occupational safety and health standards. Occupational Safety and Health Administration. Code of Federal Regulations 29 CFR 1910.119, Appendix A. http://www.osha.gov/law-regs.html. January 08, 2014.
OSHA. 2013b. Toxic and hazardous substances. Occupational safety and health standards. Occupational Safety and Health Administration. Code of Federal Regulations 29 CFR 1910.1000, Table Z-1. http://www.osha.gov/law-regs.html. January 08, 2014.
Owen GM, Brozek J. 1966. Influence of age, sex and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
Owens LB, Edwards WM, Van Keuren RW. 1994. Groundwater nitrate levels under fertilized grass and grass-legume pastures. J Environ Qual 23(4):752–758.
Palli D, Russo A, Decarli A. 2001. Dietary patterns, nutrient intake and gastric cancer in a high-risk area of Italy. Cancer Causes Control 12(2):163–172.11246845
Parslow RC, McKinney PA, Law GR, . 1997. Incidence of childhood diabetes mellitus in Yorkshire, northern England, is associated with nitrate in drinking water: An ecological analysis. Diabetologia 40(5):550–556.9165223
Pavlov J, Attygalle AB. 2013. Direct detection of inorganic nitrate salts by ambient pressure helium-plasma ionization mass spectrometry. Anal Chem 85(1):278–282.23194245
Perez-Rodriguez ML, Bosch-Bosch N, Garcia-Mata M. 1996. Monitoring nitrite and nitrate residues in frankfurters during processing and storage. Meat Sci 44(1–2):65–73.22060756
Petersen A, Stoltze S. 1999. Nitrate and nitrite in vegetables on the Danish market: Content and intake. Food Addit Contam 16(7):291–299.10656054
Pfenning KS, McMahon PB. 1997. Effect of nitrate, organic carbon, and temperature on potential denitrification rates in nitrate-rich riverbed sediments. J Hydrol 187(3–4):283–295.
Pliss GB, Frolov AG. 1991. Sodium nitrite as possible promotor of carcinogenesis in the bladder of rats. Vopr Onkol 37(2):203–206.2014701
Pogoda JM, Preston-Martin S. 2001a. Maternal cured meat consumption during pregnancy and risk of paediatric brain tumour in offspring: Potentially harmful levels of intake. Public Health Nutr 4(2):183–189.11299090
Pogoda JM, Preston-Martin S. 2001b. Letter to the editor: Maternal cured meat consumption during pregnancy and risk of paediatric brain tumour in offspring: Potentially harmful levels of intake, authors’ response. Public Health Nutr 4:1304–1305.
Pokomy L, Maturana I, Bortle WH. 2006. Sodium nitrate and nitrite. In: Kirk-Othmer encyclopedia of chemical technology. John Wiley & Sons, Inc. 10.1002/0471238961.1915040916151115.a01.pub2.
Power GG, Bragg SL, Oshiro BT, . 2007. A novel method of measuring reduction of nitrite-induced methemoglobin applied to fetal and adult blood of humans and sheep. J Appl Physiol 103:1359–1365.17615278
Preston-Martin S, Pogoda JM, Mueller BA, . 1996. Maternal consumption of cured meats and vitamins in relation to pediatric brain tumors. Cancer Epidemiol Biomarkers Prev 5(8):599–605.8824361
Qin L, Liu X, Sun Q, . 2012. Sialin (SLC17A5) functions as a nitrate transporter in the plasma membrane. Proc Natl Acad Sci USA. 109(33):13434–13439.22778404
Rádiková Z, Tajtakova M, Kocan A, . 2008. Possible effects of environmental nitrates and toxic organochlorines on human thyroid in highly polluted areas in Slovakia. Thyroid 18(3):353–362.18298316
Rafnsson V, Gunnarsdottir H. 1990. Mortality study of fertiliser manufacturers in Iceland. Br J Ind Med 47(11):721–725.2173946
RePORTER. 2014. Ammonium nitrate, nitrates, potassium nitrate, sodium nitrate, sodium nitrite. Research Portfolio Online Reporting Tools (RePORT). National Institutes of Health, U.S. Department of Health and Human Services. http://projectreporter.nih.gov/reporter.cfm. April 7, 2014.
Rijhsinghani KS, Abrahams C, Krakower C, . 1982. Tumor induction in C57BL X C3HF1 mice following single oral administration of diethylamine hydrochloride (DEA . HCl) and sodium nitrite (NaNO2). Cancer Detect Prev 5(3):283–290.7151061
Ringling S, Boo T, Bottei E. 2003. Methemoglobinemia from nitrite-contaminated punch. J Toxicol Clin Toxicol 41(5):730–731.
Risch HA, Jain M, Choi NW, . 1985. Dietary factors and the incidence of cancer of the stomach. Am J Epidemiol 122(6):947–959.2998182
RIVM. 1996. On the etiology of nitrite-induced hypertrophy of the zona glomerulosa of rats: II. The possible role of feed. National Institute for Public Health and the Environment. RIVM Report 235802004. http://www.rivm.nl/en/Documents_and_publications/Scientific/Reports/1996/juli/On_the_etiology_of_nitrite_induced_hypertrophy_of_the_zona_glomerulosa_of_rats_II_The_possible_role_of_feed?sp=cml2bXE9ZmFsc2U7c2VhcmNoYmFzZT0yMjkwMDtyaXZtcT1mYWxzZTs=&pagenr=2291. July 8, 2015.
Rix PJ, Vick A, Attkins NJ, . 2015. Pharmacokinetics, pharmacodynamics, safety, and tolerability of nebulized sodium nitrite (AIR001) following repeat-dose inhalation in healthy subjects. Clin Pharmacokinet 54(3):261–272. 10.1007/s40262-014-0201-y.25421879
Robbiano L, Carlo P, Finollo R, . 1990. DNA damage induced in rats by oral administration of chlordiazepoxide plus sodium nitrite or of N-nitrosochlordiazepoxide. Toxicol Appl Pharmacol 102(1):186–190.2296768
Robertson HE, Riddell WA. 1949. Cyanosis of infants produced by high nitrate concentration in rural waters of Saskatchewan. Can J Public Health 40(2):72–77.18113224
Rodkey FL. 1976. A mechanism for the conversion of oxyhemoglobin to methemoglobin by nitrite. Clin Chem 22(12):1986–1990.11898
Rogers MA, Vaughan TL, Davis S, . 1995. Consumption of nitrate, nitrite, and nitrosodimethylamine and the risk of upper aerodigestive tract cancer. Cancer Epidemiol Biomarkers Prev 4(1):29–36.7894321
RTECS. 2014. Ammonium nitrate, sodium nitrate, potassium nitrite, potassium nitrate and nitrous acid, sodium salt. Registry of Toxic Effects on Chemical Substances. National Institute of Occupational Safety and Health. MDL Information Systems, Inc. July 8, 2014.
Rustia M, Shubik P. 1974. Prenatal induction of neurogenic tumors in hamsters by precursors ethylurea and sodium nitrite. J Natl Cancer Inst 52(2):605–608.4816014
Sackner MA, Dougherty RD, Chapman GA, . 1979. Effects of sodium nitrate aerosol on cardiopulmonary function of dogs, sheep and man. Environ Res 18(2):421–436.510258
Sadeq M, Moe CL, Attarassi B, . 2008. Drinking water nitrate and prevalence of methemoglobinemia among infants and children aged 1-7 years in Moroccan areas. Int J Hyg Environ Health 211(5–6):546–554.18155958
Saito T, Takeichi S, Osawa M, . 2000. A case of fatal methemoglobinemia of unknown origin but presumably due to ingestion of nitrate. Int J Legal Med 113(3):164–167. 10.1007/s004140050290. May 23, 2014.10876989
Sanchez-Echaniz J, Benito-Fernandez J, Mintegui-Raso S. 2001. Methemoglobinemia and consumption of vegetables in infants. Pediatrics 107(5):1024–1028.11331681
Sandhu MS, White IR, McPherson K. 2001. Systematic review of the prospective cohort studies on meat consumption and colorectal cancer risk: A meta-analytical approach. Cancer Epidemiol Biomarkers Prev 10(5):439–446.11352852
Saunders NR, Ek CJ, Habgood MD, . 2008. Barriers in the brain: A renaissance? Trends Neurosci 31(6):279–286.18471905
Saunders NR, Liddelow SA, Dziegielewska KM. 2012. Barrier mechanisms in the developing brain. Front Pharmacol 3(10.3389/fphar.2012.00046):Article 46.
Schepers JS, Moravek MG, Alberts EE, . 1991. Maize production impacts on groundwater quality. J Environ Qual 20(1):12–16.
Scherer-Lorenzen M, Palmborg C, Prinz A, . 2003. The role of plant diversity and composition for nitrate in leaching in grasslands. Ecology 84(6):1539–1552.
Scheunig G, Horn KH, Mehnert WH. 1979. [Induction of tumors in Wistar-rats after oral application of aminopyrine and nitrite (author’s translation)]. Arch Geschwulstforsch 49(3):220–228.496562
Scheuplein R, Charnley G, Dourson M. 2002. Differential sensitivity of children and adults to chemical toxicity. I. Biological basis. Regul Toxicol Pharmacol 35(3):429–447.12202057
Schmitz JT. 1961. Methemoglobinemia-a cause of abortions? Preliminary report. Obstet Gynecol 17:413–415.13748137
Schultz DS, Deen WM, Karel SF, . 1985. Pharmacokinetics of nitrate in humans: Role of gastrointestinal absorption and metabolism. Carcinogenesis 6(6):847–852.3159503
Scragg RK, Dorsch MM, McMichael AJ, . 1982. Birth defects and household water supply. Epidemiological studies in the Mount Gambier region of South Australia. Med J Aust 2(12):577–579.7162445
Seifert SA. 2004. Nitrates and nitrites. In: Dart RC, ed. Medical toxicology. 3rd ed. Philadelphia, PA: Lippincott Williams & Williams, 1174–1180.
Sevier JN, Berbatis CG. 1976. Accidental sodium nitrite ingestion. Med J Aust 1(May):847.958094
Shaffer MJ, Wylie BK, Hall MD. 1995. Identification and mitigation of nitrite leaching hot spots using NLEAP-GIS technology. J Contam Hydrol 20:253–263.
Shank RC, Newberne PM. 1976. Dose-response study of the carcinogenicity of dietary sodium nitrite and morpholine in rats and hamsters. Food Cosmet Toxicol 14(1):1–8.176090
*Sharma MK, Sharma H, Bapna N. 2011. A study of toxicological effects of high nitrate ingestion in rabbits. Journal of Biomedical Sciences and Research 3(3):439–443.
*Sharma MK, Sharma H, Bapna N. 2013. Histopathological changes in the liver of rabbits exposed to high nitrate ingestion in drinking water. J Clin Diagn Res 7(8):1552–1554.24086836
Sheehy MH, Way JL. 1974. Nitrite intoxication: Protection with methylene blue and oxygen. Toxicol Appl Pharmacol 30(Nov):221–226.
Shimada T. 1989. Lack of teratogenic and mutagenic effects of nitrite on mouse fetuses. Arch Environ Health 44(1):59–63.2916857
Shuval HI, Gruener N. 1972. Epidemiological and toxicological aspects of nitrates and nitrites in the environment. Am J Public Health 62(8):1045–1052.5046442
Sierra R, Chinnock A, Ohshima H, . 1993. In vivo nitrosoproline formation and other risk factors in Costa Rican children from high- and low-risk areas for gastric cancer. Cancer Epidemiol Biomarkers Prev 2(6):563–568.8268774
Siervo M, Lara J, Ogbonmwan I, . 2013. Inorganic nitrate and beetroot juice supplementation reduces blood pressure in adults: A systematic review and meta-analysis. J Nutr 143(6):818–826.23596162
Simon C, Manzke H, Kay H, . 1964. Occurrence, pathogenesis, and possible prophylaxis of nitrite induced methemoglobinemia. Z Kinderheilkd 91:124–138.14331887
Sleight SD, Atallah OA. 1968. Reproduction in the guinea pig as affected by chronic administration of potassium nitrate and potassium nitrite. Toxicol Appl Pharmacol 12:179–185.5691096
Small H, Stevens TS, Bauman WC. 1975. Novel ion exchange chromatographic method using conductimetric detection. Anal Chem 47:1801–1809.
*Smyth HF, Jr, Carpenter CP, Weil CS, . 1969. Range-finding toxicity data: List VII. Am Ind Hyg Assoc J. 30(5):470–476.5823428
SRI. 2011. Sodium nitrate, sodium nitrite and potassium nitrite. In: 2011 Directory of chemical producers. Menlo Park, CA: SRI Consulting, 816, 849.
Stafford GE. 1947. Methemoglobinemia in infants from water containing high concentrations of nitrates. Nebr State Med J 32(10):392–394.20267412
Steinhorn RH. 2008. Evaluation and management of the cyanotic neonate. Clin Pediatr Emerg Med 9(3):169–175.19727322
Sun J, Zhang X, Broderick M, . 2003. Measurement of nitric oxide production in biological systems by using Griess Reaction assay. Sensors 3(8):276–284. http://www.mdpi.com/1424-8220/3/8/276. May 24, 2014.
Super M, Heese HdV, MacKenzie D, . 1981. An epidemiological study of well-water nitrates in a group of south west African/Namibian infants. Water Res 15:1265–1270.
Tabacova S, Baird DD, Balabaeva L. 1998. Exposure to oxidized nitrogen: Lipid peroxidation and neonatal health risk. Arch Environ Health 53(3):214–221.9814718
Tabacova S, Balabaeva L, Little RE. 1997. Maternal exposure to exogenous nitrogen compounds and complications of pregnancy. Arch Environ Health 52(5):341–347.9546756
Tahira T, Ohgaki H, Wakabayashi K, . 1988. The inhibitory effect of thioproline on carcinogenesis induced by n-benzylmethylamine and nitrite. Food Chem Toxicol 26(6):511–516.3169650
Tajtáková M, Semanova Z, Tomkova Z, . 2006. Increased thyroid volume and frequency of thyroid disorders signs in schoolchildren from nitrate polluted area. Chemosphere 62(4):559–564.16095667
Taylor AW. 2004. Fertilizers. In: Kirk-Othmer encyclopedia of chemical toxicology. http://onlinelibrary.wiley.com/doi/10.1002/0471238961.0605182008150606.a01.pub2/abstract. May 21, 2014.
Taylor HW, Lijinsky W. 1975a. Tumor induction in rats by feeding aminopyrine or oxytetracycline with nitrite. Int J Cancer 16(2):211–215.168160
Taylor HW, Lijinsky W. 1975b. Tumor induction in rats by feeding heptamethyleneimine and nitrite in water. Cancer Res 35(3):812–815.1116136
Ten Brink WA, Wiezer JH, Luijpen AF, . 1982. Nitrite poisoning caused by food contaminated with cooling fluid. J Toxicol Clin Toxicol 19(2):139–147.7109005
TFI. 2014. History of U.S. fertilizer use. The Fertilizer Institute: http://httpwww.tfi.org/sites/default/files/images/history_of_us_fert_use.pdf (http://www.tfi.org/sites/default/files/images/history_of_us_fert_use.pdf). November 17, 2014.
Thomas K, Colborn T. 1992. Organochlorine endocrine disruptors in human tissue. In: Colborn T, Clement C, eds. Chemically induced alterations in sexual and functional development: The wildlife/human connection. Princeton, NJ: Princeton Scientific Publishing, 365–394.
Tietz NW, ed. 1970. Fundamentals of clinical chemistry. Philadelphia, PA: W.B. Saunders Company, 665, 666, 729–731.
Til HP, Falke HE, Kuper CF, . 1988. Evaluation of the oral toxicity of potassium nitrite in a 13-week drinking-water study in rats. Food Chem Toxicol 26(10):851–859.3220328
Til HP, Kuper CF, Falke HE. 1997. Nitrite-induced adrenal effects in rats and the consequences for the no-observed-effect level. Food Chem Toxicol 35(3–4):349–355.9207897
Toernqvist M, Rannug U, Jonsson A, . 1983. Mutagenicity of methyl nitrite in Salmonella typhimurium. Mutat Res 117:47–54.6339910
TRI13. 2014. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Information Analysis and Access. Office of Environmental Information. U.S. Environmental Protection Agency. Toxics Release Inventory. http://www.epa.gov/triexplorer/. November 17, 2014.
Tsezou A, Kitsiou-Tzeli S, Galla A, . 1996. High nitrate content in drinking water: Cytogenetic effects in exposed children. Arch Environ Health 51(6):458–461.9012325
Tsikas D. 2005. Methods of quantitative analysis of the nitric oxide metabolites nitrite and nitrate in human biological fluids. Free Radic Res 39(8):797–815.16036360
Tsuda H, Kato K. 1977. High rate of endoreduplications and chromosomal aberrations in hamster cells treated with sodium nitrite in vitro. Mutat Res 56(1):69–74.593296
Tsuda H, Inui N, Takayama S. 1973. In vitro transformation of newborn hamster cells by sodium nitrite. Biochem Biophys Res Commun 55:1117–1124.4771986
Tsuda H, Kushi A, Yoshida D, . 1981. Chromosomal aberrations and sister-chromatid exchanges induced by gaseous nitrogen dioxide in cultured Chinese hamster cells. Mutat Res 89(4):303–310.7197321
Tsugane S, Tsuda M, Gey F, . 1992. Cross-sectional study with multiple measurements of biological markers for assessing stomach cancer risks at the population level. Environ Health Perspect 98:207–210.1486851
USDA. 2013. U.S. imports (1995-2012) and exports (1990-2012) of selected fertilizers, by country. U.S. Department of Agriculture. http://www.ers.usda.gov/data-products/fertilizer-importsexports/standard-tables.aspx. April 1, 2014.
USDA. 2014. Soil quality indicators. Soil nitrate. U.S. Department of Agriculture, Natural Resources Conservation Service. http://www.nrcs.usda.gov/wps/PA_NRCSConsumption/download?cid=stelprdb1243373&ext=pdf. July 10, 2014.
USGS. 2009. Nutrient trends in streams and rivers of the United States, 1993-2003. National Water-Quality Assessment Program. Reston, VA: U.S. Geological Survey. U.S. Department of the Interior. Scientific Investigations Report 2008-5202.
USGS. 2010a. The quality of our nation’s water-nutrients in the nation’s streams and groundwater, 1992-2004. National Water-Quality Assessment Program. Reston, VA: U.S. Geological Survey. U.S. Department of the Interior. Circular 1350.
USGS. 2010b. Nitrate loads and concentrations in surface-water base flow and shallow groundwater for selected basins in the United States, water years 1990-2006. National Water-Quality Assessment Program. Reston, VA: U.S. Geological Survey. U.S. Department of the Interior. Scientific Investigations Report 2010-5098.
USGS. 2012. Nitrate-nitrogen concentrations in shallow ground water of the coastal plain of the Albemarle-Pamlico drainage study units, North Carolina and Virginia. U.S. Geological Survey. U.S. Department of the Interior. Fact Sheet 241-96. http://nc.water.usgs.gov/reports/fs24196/. May 20, 2014.
USGS. 2013a. Groundwater contributions of flow, nitrate, and dissolved organic carbon to the lower San Joaquin River, California, 2006-08. Scientific Investigations Report 2013–5151. http://pubs.usgs.gov/sir/2013/5151/pdf/sir2013-5151.pdf. September 5, 2016.
USGS. 2013b. Nitrate in the Mississippi River and its tributaries, 1980-2010: An update. National Water-Quality Assessment Program. Reston, VA: U.S. Geological Survey. U.S. Department of the Interior. Scientific Investigations Report 2013-5169.
Valentín-Blasini L, Blount BC, Delinsky A. 2007. Quantification of iodide and sodium-iodide symporter inhibitors in human urine using ion chromatography tandem mass spectrometry. J Chromatogr A 1155(1):40–46.17466997
van Logten MJ, den Tonkelaar EM, Kroes R, . 1972. Long-term experiment with canned meat treated with sodium nitrite and glucono-delta-lactone in rats. Food Cosmet Toxicol 10(4):475–488.4343302
van Maanen JM, Albering HJ, de Kok TM, . 2000. Does the risk of childhood diabetes mellitus require revision of the guideline values for nitrate in drinking water? Environ Health Perspect 108(5):457–461.
van Maanen JM, van Geel AA, Kleinjans JC. 1996b. Modulation of nitrate-nitrite conversion in the oral cavity. Cancer Detect Prev. 20(6):590–596.8939344
van Maanen JMS, Welle IJ, Hageman G, . 1996a. Nitrate contamination of drinking water: Relationship with HPRT variant frequency in lymphocyte DNA and urinary excretion of N-nitrosamines. Environ Health Perspect 104(5):522–528.8743440
Velthof GL, Lesschen JP, Webb J, . 2014. The impact of the Nitrates Directive on nitrogen emissions from agriculture in the EU-27 during 2000-2008. Sci Total Environ 468–469:1225–1233.
Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238(2):476–483.8681961
Virtanen SM, Jaakkola L, Rasanen L, . 1994. Nitrate and nitrite intake and the risk for type 1 diabetes in Finnish children. Childhood Diabetes in Finland Study Group. Diabet Med 11(7):656–662.7955990
Vitousek PM, Aber JD, Howarth RW, . 1997. Human alteration of the global nitrogen cycle: Sources and consequences. Ecological Society of America. Ecol Appl 7(3):737–750. http://www.esa.org/esa/?post_type=document&p=2770. 2014/07/08.
Vorhees CV, Butcher RE, Brunner RL, . 1984. Developmental toxicity and psychotoxicity of sodium nitrite in rats. Food Chem Toxicol 22(1):1–6.6537931
Wagner DA, Schultz DS, Deen WM, . 1983. Metabolic fate of an oral dose of ^15^N-labeled nitrate in humans: Effect of diet supplementation with ascorbic acid. Cancer Res 43(4):1921–1925.6831427
Walker R. 1995. The conversion of nitrate into nitrite in several animal species and man. In: Health aspects of nitrate and its metabolites (particularly nitrite). Proceedings of an international workshop, Bilthoven (Netherlands) 8-10 November 1994. Strasbourg: Council of Europee Press, 115–123.
Walker R. 1996. The metabolism of dietary nitrites and nitrates. 658th Meeting of the Biochemical Society, Liverpool, England, UK, April 16-19, 1996. Biochemical Society Transactions 24(3):780–785.8878847
Walley T, Flanagan M. 1987. Nitrite-induced methaemoglobinaemia. Postgrad Med J 63(742):643–644.3422863
Walton G. 1951. Survey of literature relating infant methemoglobinemia due to nitrate-contaminated water. Am J Public Health 41:986–996.
Wang W, Fan Y, Xiong G, . 2012. Nitrate in drinking water and bladder cancer: A meta-analysis. J Huazhong Univ Sci Technolog 32(6):912–918. 10.1007/s11596-012-1057-8.
Ward MH, Cantor KP, Riley D, . 2003. Nitrate in public water supplies and risk of bladder cancer. Epidemiology 14(2):183–190. 10.1097/01.ede.0000050664.28048.df.12606884
Ward MH, Cerhan JR, Colt JS, . 2006. Risk of non-Hodgkin lymphoma and nitrate and nitrite from drinking water and diet. Epidemiology 17(4):375–382.16699473
Ward MH, Heineman EF, Markin RS, . 2008. Adenocarcinoma of the stomach and esophagus and drinking water and dietary sources of nitrate and nitrite. Int J Occup Environ Health 14(3):193–197.18686719
Ward MH, Kilfoy BA, Weyer PJ, . 2010. Nitrate intake and the risk of thyroid cancer and thyroid disease. Epidemiology 21(3):389–395.20335813
Ward MH, Mark SD, Cantor KP, . 1996. Drinking water nitrate and the risk of non-Hodgkin’s lymphoma. Epidemiology 7(5):465–471.8862975
Ward MH, Rusiecki JA, Lynch CF, . 2007. Nitrate in public water supplies and the risk of renal cell carcinoma. Cancer Causes Control 18(10):1141–1151.17717631
Wardak C, Grabarczyk M. 2016. Analytical application of solid contact ion-selective electrodes for determination of copper and nitrate in various food products and drinking water. J Environ Sci Health B 51(8):519–524. 10.1080/03601234.2016.1170545.27152951
Weisburger JH, Marquardt H, Hirota N, . 1980. Induction of cancer of the glandular stomach in rats by an extract of nitrite-treated fish. J Natl Cancer Inst 64(1):163–167.6928041
Weitzberg E, Lundberg JO. 2013. Novel aspects of dietary nitrate and human health. Annu Rev Nutr 33:129–159.23642194
Weitzberg E, Hezel M, Lundberg JO. 2010. Nitrate-nitrite-nitric oxide pathway: Implications for anesthesiology and intensive care. Anesthesiology 113(6):1460–1475.21045638
West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
Weyer PJ, Cerhan JR, Kross BC, . 2001. Municipal drinking water nitrate level and cancer risk in older women: The Iowa Women’s Health Study. Epidemiology 12(3):327–338.11338313
WHO. 1978. Nitrates, nitrites and N-nitroso compounds. Environmental Health Criteria 5. World Health Organization. http://www.inchem.org/documents/ehc/ehc/ehc005.htm. July 8, 2014.
WHO. 2010. WHO guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. January 08, 2014.
WHO. 2011a. Guidelines for drinking-water quality. Geneva, Switzerland: World Health Organization. http://www.who.int/water_sanitation_health/publications/2011/dwq_guidelines/en/index.html. January 08, 2014.
WHO. 2011b. Nitrate and nitrite in drinking-water. Background document for development of WHO Guidelines for Drinking-water Quality. Geneva, Switzerland: World Health Organization. WHO/SDE/WSH/07.01/16/Rev/1. http://www.who.int/entity/water_sanitation_health/dwq/chemicals/nitratenitrite_background.pdf. December 18, 2013.
Widdowson EM, Dickerson JWT. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advance treatise. Volume II: The elements Part A. New York, NY: Academic Press, 1–247.
Wilkens LR, Kadir MM, Kolonel LN, . 1996. Risk factors for lower urinary tract cancer: The role of total fluid consumption, nitrites and nitrosamines, and selected foods. Cancer Epidemiol Biomarkers Prev 5(3):161–166.8833615
Winchester PD, Huskins J, Ying J. 2009. Agrichemicals in surface water and birth defects in the United States. Acta Paediatr 98:664–669.19183116
Winton EF, Tardiff RG, McCabe LJ. 1971. Nitrate in drinking water. J Am Water Works Assoc 63(2):95–98.
Wu T, Wang Y, Ho S, . 2013. Plasma levels of nitrate and risk of prostate cancer: A prospective study. Cancer Epidemiol Biomarkers Prev 22(7):1210–1218.23677578
Wu Y, Chen J, Ohshima H, . 1993. Geographic association between urinary excretion of N-nitroso compounds and oesophageal cancer mortality in China. Int J Cancer 54(5):713–719.8325701
Xiang YY, Wang DY, Tanaka M, . 1995. Efficient and specific induction of esophageal tumors in rats by precursors of N-nitrososarcosine ethyl ester. Pathol Int 45(6):415–421.7581932
Yada H, Hirose M, Tamano S, . 2002. Effects of antioxidant 1-O-hexyl-2,3,5trimethylhydroquinone or ascorbic acid on carcinogenesis induced by administration of aminopyrine and sodium nitrite in a rat multi-organ carcinogenesis model. Jpn J Cancer Res 93(12):1299–1307.12495469
Yamamoto K, Nakajima A, Eimoto H, . 1989. Carcinogenic activity of endogenously synthesized n nitrosobis-2-hydroxypropylamine in rats administered bis-2-hydroxypropylamine and sodium nitrite. Carcinogenesis 10(9):1607–1612.2766455
Yan H, Zhuo X, Shen B, . 2016. Determination of nitrite in whole blood by high-performance liquid chromatography with electrochemical detection and a case of nitrite poisoning. J Forensic Sci 61(1):254–258. 10.1111/1556-4029.12918.26271670
Yang YJ, Hwang SH, Kim HJ. 2010. Dietary intake of nitrate relative to antioxidant vitamin in relation to breast cancer risk: A case-control study. Nutr Cancer 62(5):555–566.20574916
Yano SS, Danish EH, Hsia YE. 1982. Transient methemoglobinemia with acidosis in infants. J Pediatr 100(3):415–418.7062175
Yoshida A, Harada T, Hayashi S, . 1994. Endometrial carcinogenesis induced by concurrent oral administration of ethylenethiourea and sodium nitrite in mice. Carcinogenesis 15(10):2311–2318.7955072
Yoshida A, Harada T, Maita K. 1993. Tumor induction by concurrent oral administration of ethylenethiourea and sodium nitrite in mice. Toxicol Pathol 21(3):303–310.8248719
Yoshizumi K, Aoki K, Matsuoka T, . 1985. Determination of nitrate by a flow system with a chemiluminescent nitrogen oxides analyzer. Anal Chem 57(3):737–740.
Zaki A, Ait Chaoui A, Talibi A, . 2004. Impact of nitrate intake in drinking water on the thyroid gland activity in male rat. Toxicol Lett 147(1):27–33.14700525
Zeegers MP, Selen RF, Kleinjans JC, . 2006. Nitrate intake does not influence bladder cancer risk: The Netherlands cohort study. Environ Health Perspect 114(10):1527–1531.17035137
Zeiger E, Anderson B, Haworth S, . 1992. Salmonella mutagenicity tests: V. Results from the testing of 311 chemicals. Environ Mol Mutagen 21:2–141.
Zeilmaker MJ, Bakker MI, Schothorst R, . 2010a. Risk assessment of N-nitrosodimethylamine formed endogenously after fish-with-vegetable meals. Toxicol Sci 116(1):323–335. http://toxsci.oxfordjournals.org/content/116/1/323.abstract. May 20, 2014.20351056
Zeilmaker MJ, Meulenbelt J, Kortboyer JM, . 1996. Safety evaluation of nitrate: Mathematical modeling of nitrite formation in man and its application in the risk assessment of nitrate. Bilthoven, The Netherlands: National Institute of Public Health and the Environment. Report number 235802.002.
Zeilmaker MJ, Meulenbelt J, Slob W. 2010b. Supplementary Information A2-1. Mathematical model of human nitrate/nitrite kinetics, including the formation of methemoglobin in the blood (Supplement to: Toxicol Sci 116(1):323-335). Toxicol Sci. http://toxsci.oxfordjournals.org/content/suppl/2010/03/23/kfq093.DC1/toxsci-09-0763-File002.doc. April 1, 2014.
Zeman CL, Kross B, Vlad M. 2002. A nested case-control study of methemoglobinemia risk factors in children of Transylvania, Romania. Environ Health Perspect 110(8):817–822.12153765
Zhang M, Geng S, Smallwood KS. 1998. Assessing groundwater nitrate contamination for resource and landscape management. Ambio 27(3):170–174.
Zhang WL, Tian ZX, Zhang N, . 1996. Nitrate pollution of groundwater in northern China. Agric Ecosyst Environ 59(3):223–231.
Zhang XL, Bing Z, Xing Z, . 2003. Research and control of well water pollution in high esophageal cancer areas. World J Gastroenterol 9(6):1187–1190.12800221
Zhao HX, Mold MD, Stenhouse EA, . 2001. Drinking water composition and childhood-onset type 1 diabetes mellitus in Devon and Cornwall, England. Diabet Med 18(9):709–717.11606168
Zhou L, Anwar MM, Zahid M, . 2014. Urinary excretion of N-nitroso compounds in rats fed sodium nitrite and/or hot dogs. Chem Res Toxicol 27(10):1669–1674. 10.1021/tx5000188.25183213
Zhuang H, Chan CK, Fang M, . 1999. Size distributions of particulate sulfate, nitrate, and ammonium at a coastal site in Hong Kong. Atmos Environ 33(6):843–853.
Ziegler EE, Edwards BB, Jensen RL, . 1978. Absorption and retention of lead by infants. Pediatr Res 12(1):29–34.643372