# 8 REGULATIONS, ADVISORIES, AND GUIDELINES

MRLs are substance-specific estimates that are intended to serve as screening levels. They are used by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites.

MRLs of 4 mg nitrate/kg/day have been derived for acute-, intermediate, and chronic-duration oral exposure (≤14 days) to nitrate. The MRLs are based on a no-adverse-effect concentration (NOAEC) of 10 mg nitrate-nitrogen/L (44 mg nitrate/L) in drinking water used to prepare formula for infants <6 months of age (Walton 1951). A NOAEL of 4.33 mg nitrate/kg/day at the NOAEC of 44 mg nitrate/L was calculated based on estimates of 0.525 L/day for water intake (Kahn and Stralka 2009) and 5.33 kg for body weight (EPA 2008) of an infant from birth to <3 months of age. A total uncertainty factor of 1 was applied because the point of departure is a NOAEL for nitrate-induced effects on methemoglobin in a sensitive human subpopulation (i.e., <3-month-old infants, which in many cases may have been at increased risk of methemoglobinemia due to microbial contamination and associated gastrointestinal infection). Following ingestion of relatively large amounts of nitrate by healthy normal individuals, blood methemoglobin levels increase rapidly, followed by a return to normal within several hours following intake. Repeated ingestion for intermediate- or chronic-duration time periods would be expected to result in changes in methemoglobin levels similar to those elicited from a single exposure. Therefore, the acute-, intermediate- and chronic-duration oral MRL values are equivalent. Refer to Appendix A for additional information regarding derivation of oral MRLs for nitrate.

MRLs of 0.1 mg nitrite/kg/day have been derived for acute-, intermediate, and chronic-duration oral exposure (≤14 days) to nitrite. The ingestion of nitrate results in the formation of nitrite, which is the moiety responsible for methemoglobinemia. In adults, approximately 5% of an oral dose of nitrate is reduced to nitrite in the saliva, most of which is absorbed into the blood in the small intestine. Based on the assumption of 100% absorption of ingested nitrite, an oral dose of 0.2 mg nitrite/kg/day by an adult would be expected to result in a nitrite blood level similar to that achieved following ingestion of nitrate at the oral MRL dose of 4 mg nitrate/kg/day (i.e., 0.2 mg nitrite/kg/day is 5% of an oral dose of nitrate at the MRL of 4 mg nitrate/kg/day). A modifying factor of 2 was applied to the point of departure (0.2 mg nitrite/kg/day ÷ 2 = 0.1 mg nitrite/kg/day) because young infants exhibit increased susceptibility to methemoglobinemia following nitrate ingestion; the modifying factor assumes that the effective methemoglobin level from a given intake of nitrate by an infant is up to twice that of an adult. Following ingestion of relatively large amounts of nitrate by healthy normal individuals, blood methemoglobin levels increase rapidly, followed by a return to normal within several hours following intake. Repeated ingestion for intermediate- or chronic-duration time periods would be expected to result in changes in methemoglobin levels similar to those elicited from a single exposure. Therefore, the acute-, intermediate-, and chronic-duration oral MRL values are equivalent. Refer to Appendix A for additional information regarding derivation of oral MRLs for nitrite.

EPA (IRIS 2002) derived an oral reference dose (RfD) of 1.6 mg nitrate-nitrogen/kg/day (i.e., 1.6 mg nitrogen from nitrate; ~7 mg nitrate/kg/day) based on a NOAEL of 1.6 mg nitrate-nitrogen/kg/day and a LOAEL of 1.8–3.2 mg nitrate-nitrogen/kg/day (7.92–14.08 mg nitrate/kg/day) for early clinical signs of methemoglobinemia in excess of 10% among formula-fed infants 0–3 months of age (Bosch et al. 1950; Walton 1951). An uncertainty factor of 1 was employed because available data defined the NOAEL for the critical effect in the most sensitive human subpopulation.

EPA (IRIS 2002) derived an RfD of 0.1 mg nitrite-nitrogen/kg/day (~0.33 mg nitrite/kg/day) based on a NOAEL of 10 mg nitrate-nitrogen/L and a LOAEL of 11–20 mg nitrate-nitrogen/L for early clinical signs of methemoglobinemia in excess of 10% (Walton 1951). The NOAEL of 10 mg nitrate-nitrogen/L was converted to an estimated dose of 1 mg nitrate-nitrogen/kg/day based assumptions that a 10-kg child would ingest 1 L of water/day. EPA applied a modifying factor of 10 to the NOAEL of 1 mg nitrate-nitrogen/kg/day from the Walton (1951) study to account for the direct toxicity of nitrite, resulting in an RfD of 0.1 mg nitrite-nitrogen/kg/day. As described in a Drinking Water Criteria Document for Nitrate/Nitrite (EPA 1990a), the modifying factor of 10 was used to account for an estimated rate of 10% conversion of ingested nitrate to nitrite in infants compared to an estimated rate of 5% conversion in adults.

Based on available human data, IARC (2010) determined that there is inadequate evidence for the carcinogenicity of nitrate in food or drinking water and limited evidence for the carcinogenicity of nitrite in food (based on association with increased incidence of stomach cancer). Evaluation of available animal data by IARC (2010) resulted in the determination that there is inadequate evidence for the carcinogenicity of nitrate, limited evidence for the carcinogenicity of nitrite per se, and sufficient evidence for the carcinogenicity of nitrite in combination with amines or amides. The overall conclusions of IARC (2010) were that “ingested nitrate and nitrite under conditions that result in endogenous nitrosation is probably carcinogenic to humans (Group 2A).” IARC (2010) noted that: (1) the endogenous nitrogen cycle in humans includes interconversion of nitrate and nitrite; (2) nitrite-derived nitrosating agents produced in the acid stomach environment can react with nitrosating compounds such as secondary amines and amides to generate N-nitroso compounds; (3) nitrosating conditions are enhanced upon ingestion of additional nitrate, nitrite, or nitrosatable compounds; and (4) some N-nitroso compounds are known carcinogens.

Neither nitrate nor nitrite have been classified as to their carcinogenicity by the U.S. EPA Integrated Risk Information System (IRIS 2002), the National Toxicology Program (NTP, 2011), or the American Conference of Governmental Industrial Hygienists (ACGIH 2013).

The EPA lists maximum contaminant levels (MCL) and maximum contaminant level goals (MCLG) of 10 mg/L for nitrate (as nitrate-nitrogen; ~44 mg nitrate/L) and 1 mg/L for nitrite (as nitrite nitrogen; ~3.3 mg nitrite/L) in the 2012 Edition of the Drinking Water Standards and Health Advisories (EPA 2012b).

The international and national regulations, advisories, and guidelines regarding nitrate and nitrite in air, water, and other media are summarized in Table 8-1.

Table 8-1 Regulations, Advisories, and Guidelines Applicable to Nitrate and Nitrite

Agency | Description | Information | Reference
[underlined: INTERNATIONAL]
Guidelines:
IARC | Carcinogenicity classification | | IARC 2014
IARC | Nitrate or nitrite (ingested) under conditions that result in endogenous nitrosation | Group 2A^a^ | IARC 2014
WHO | Air quality guidelines | No data | WHO 2010
WHO | Drinking water quality guidelines | | WHO 2011a
WHO | Nitrate (as NO_3_^−^) | 50 mg/L^b^ | WHO 2011a
WHO | Nitrite (as NO_2_^−^) | 3 mg/L^c^ | WHO 2011a
WHO | Combined nitrate plus nitrite | The sum of the ratios of the concentrations as reported or detected in the sample of each to its guideline value should not exceed 1 | WHO 2011a
[underlined: NATIONAL]
Regulations and guidelines:
a. Air
ACGIH | TLV-TWA | No data | ACGIH 2013
AIHA | ERPGs | No data | AIHA 2013
DOE | Nitrate(s) | | DOE 2012
DOE | PAC-1^d^ | 30 mg/m^3^ | DOE 2012
DOE | PAC-2 | 330 mg/m^3^ | DOE 2012
DOE | PAC-3 | 2,000 mg/m^3^ | DOE 2012
DOE | Ammonium nitrate | | DOE 2012
DOE | PAC-1^d^ | 6.7 mg/m^3^ | DOE 2012
DOE | PAC-2 | 73 mg/m^3^ | DOE 2012
DOE | PAC-3 | 440 mg/m^3^ | DOE 2012
DOE | Potassium nitrate | | DOE 2012
DOE | PAC-1^d^ | 0.074 mg/m^3^ | DOE 2012
DOE | PAC-2 | 0.82 mg/m^3^ | DOE 2012
DOE | PAC-3 | 600 mg/m^3^ | DOE 2012
DOE | Sodium nitrate | | DOE 2012
DOE | PAC-1^d^ | 12 mg/m^3^ | DOE 2012
DOE | PAC-2 | 130 mg/m^3^ | DOE 2012
DOE | PAC-3 | 250 mg/m^3^ | DOE 2012
EPA | Sodium nitrite
EPA | PAC-1^d^ | 2.3 mg/m^3^
EPA | PAC-2 | 26 mg/m^3^
EPA | PAC-3 | 280 mg/m^3^
EPA | AEGLs | No data | EPA 2013a
EPA | Hazardous air pollutant | No data | EPA 2014a; 42 USC 7412
EPA | NAAQS | No data | EPA 2014d
NIOSH | REL | No data | NIOSH 2014
NIOSH | STEL | No data | NIOSH 2014
NIOSH | IDLH | No data | NIOSH 2014
OSHA | PEL (8-hour TWA) for general industry | No data | OSHA 2013b; 29 CFR 1910.1000, Table Z-2
OSHA | Highly hazardous chemicals | No data | OSHA 2013a; 29 CFR 1910.119, Appendix A
b. Water
EPA | Designated as hazardous substances in accordance with Section 311(b)(2)(A) of the Clean Water Act | No data | EPA 2013b; 40 CFR 116.4
EPA | Drinking water contaminant candidate list | No data | EPA 2009b; 74 FR 51850
EPA | Drinking water standards and health advisories | | EPA 2012b
EPA | Nitrate | | EPA 2012b
EPA | MCL | 10 mg nitrogen/L (~44 mg nitrate/L)^e^ | EPA 2012b
EPA | MCLG | 10 mg nitrogen/L (~44 mg nitrate/L)^f^ | EPA 2012b
EPA | Health advisory for 1 day for 10-kg child | 100 mg nitrogen/L (~440 mg nitrate/L)^e^ | EPA 2012b
EPA | Health advisory for 10 days for 10-kg child | 100 mg nitrogen/L (~440 mg nitrate/L)^e^ | EPA 2012b
EPA | DWEL | No data | EPA 2012b
EPA | Nitrite | | EPA 2012b
EPA | MCL | 1 mg nitrogen/L (~3.3 mg nitrite/L)^f^ | EPA 2012b
EPA | MCLG | 1 mg nitrogen/L (~3.3 mg nitrite/L)^f^ | EPA 2012b
EPA | Health advisory for 1 day for 10-kg child | 10 mg nitrogen/L (~33 mg nitrite/L)^f^ | EPA 2012b
EPA | Health advisory for 10 days for 10-kg child | 10 mg nitrogen/L (~33 mg nitrite/L)^f^ | EPA 2012b
EPA | DWEL | No data | EPA 2012b
EPA | Nitrate + nitrite (both as nitrogen) | | EPA 2012b
EPA | MCL | 10 mg/L | EPA 2012b
EPA | MCLG | 10 mg/L | EPA 2012b
EPA | National primary drinking water standards | | EPA 2009c
EPA | Nitrate | | EPA 2009c
EPA | MCL | 10 mg nitrogen/L (~44 mg nitrate/L)^e^ | EPA 2009c
EPA | Potential health effects from long-term exposure above the MCL | Serious illness; symptoms include shortness of breath and blue-baby syndrome^g^ | EPA 2009c
EPA | Common sources of contaminant in drinking water | Runoff from fertilizer use; leaching from septic tanks, sewage; erosion of natural deposits | EPA 2009c
EPA | Public Health Goal | 10 mg nitrogen/L (~44 mg nitrate/L)^e^ | EPA 2009c
EPA | Nitrite | | EPA 2009c
EPA | MCL | 1 mg nitrogen/L (~3.3 mg nitrite/L)^f^ | EPA 2009c
EPA | Potential health effects from long-term exposure above the MCL | Serious illness; symptoms include shortness of breath and blue-baby syndrome^g^ | EPA 2009c
EPA | Common sources of contaminant in drinking water | Runoff from fertilizer use; leaching from septic tanks, sewage; erosion of natural deposits | EPA 2009c
EPA | Public Health Goal | 1 mg nitrogen/L (~3.3 mg nitrite/L)^f^ | EPA 2009c
EPA | National recommended water quality criteria: human health for the consumption of (at 10^-4^ risk) | | EPA 2014e
EPA | Nitrates | | EPA 2014e
EPA | Water + organism | 10,000 μg nitrogen/L | EPA 2014e
EPA | Organism only | No data | EPA 2014e
EPA | Reportable quantities of hazardous substances designated pursuant to Section 311 of the Clean Water Act | | EPA 2013d; 40 CFR 117.3
EPA | Sodium nitrite | 100 pounds | EPA 2013d; 40 CFR 117.3
c. Food
FDA | Bottled water (allowable limits) | | FDA 2013; 21 CFR 165.110
FDA | Nitrate | 10 mg nitrogen/L (~44 mg nitrate/L)^e^ | FDA 2013; 21 CFR 165.110
FDA | Nitrite | 1 mg nitrogen/L (~3.3 mg nitrite/L)^f^ | FDA 2013; 21 CFR 165.110
FDA | Total nitrate and nitrite (as nitrogen) | 10 mg/L | FDA 2013; 21 CFR 165.110
FDA | EAFUS^h^ | | FDA 2014
FDA | Potassium nitrate, sodium nitrate, potassium nitrite, and sodium nitrite | Yes | FDA 2014
d. Other
ACGIH | Carcinogenicity classification | No data | ACGIH 2013
EPA | Nitrate | | EPA 1990a; IRIS 2002
EPA | Carcinogenicity classification | No data | EPA 1990a; IRIS 2002
EPA | RfC | No data | EPA 1990a; IRIS 2002
EPA | RfD | 1.6 mg nitrogen/kg/day (~7 mg nitrate/kg/day)^e^ | EPA 1990a; IRIS 2002
EPA | Nitrite | | EPA 1990a; IRIS 2002
EPA | Carcinogenicity classification | No data | EPA 1990a; IRIS 2002
EPA | RfC | No data | EPA 1990a; IRIS 2002
EPA | RfD | 0.1 mg nitrogen/kg/day (~0.33 mg nitrite/kg/day)^f^ | EPA 1990a; IRIS 2002
EPA | Identification and listing of hazardous waste | No data | EPA 2013c; 40 CFR 261, Appendix VIII
EPA | Inert pesticide ingredients in pesticide products approved for nonfood use only | | EPA 2014b
EPA | Ammonium nitrate, potassium nitrate, sodium nitrate, potassium nitrite, and sodium nitrite | Yes | EPA 2014b
EPA | Master Testing List | No data | EPA 2014c
EPA | RCRA waste minimization PBT priority chemical list | No data | EPA 1998; 63 FR 60332
EPA | Standards for owners and operators of hazardous waste TSD facilities; groundwater monitoring list | No data | EPA 2013e; 40 CFR 264, Appendix IX
EPA | Superfund, emergency planning, and community right-to-know
EPA | Designated CERCLA hazardous substance and reportable quantity pursuant to Section 311(b)(2) of the Clean Water Act | | EPA 2013f; 40 CFR 302.4
EPA | Sodium nitrite | 100 pounds | EPA 2013f; 40 CFR 302.4
EPA | Nitrate compounds (water dissociable; reportable only when in aqueous solution); sodium nitrite | Effective date of toxic chemical release reporting; 01/01/1995 | EPA 2013h; 40 CFR 372.65
EPA | Superfund, emergency planning, and community right-to-know
EPA | Extremely hazardous substances and its threshold planning quantity | No data | EPA 2013g; 40 CFR 355, Appendix A
EPA | TSCA chemical lists and reporting periods | No data | EPA 2013i; 40 CFR 712.30
EPA | TSCA health and safety data reporting | No data | EPA 2013j; 40 CFR 716.120
NTP | Carcinogenicity classification | No data | NTP 2011

a Group 2A: probably carcinogenic to humans.

b As nitrate ion (or 11 mg/L as nitrate-nitrogen) to protect against methemoglobinemia in bottle-fed infants (short-term exposure).

c As nitrite ion (or 0.9 mg/L as nitrite-nitrogen) to protect against methemoglobinemia in bottle-fed infants (short-term exposure).

d PAC-1: mild, transient health effects; PAC-2: irreversible or other serious health effects that could impair the ability to take protective action; PAC-3: life-threatening health effects (DOE 2012).

e 1 mg nitrate-nitrogen/L (i.e., nitrogen from nitrate) ~4.4 mg nitrate/L

f 1 mg nitrite-nitrogen/L (i.e., nitrogen from nitrite) ~3.3 mg nitrite/L

g Infants below the age of 6 months who drink water containing nitrate and/or nitrite in excess of the MCL could become seriously ill and, if untreated, may die (EPA 2009b).

h The EAFUS list of substances that contains ingredients added directly to food that FDA has either approved as food additives or listed or affirmed as GRAS.

ACGIH = American Conference of Governmental Industrial Hygienists; AEGL = acute exposure guideline level; AIHA = American Industrial Hygiene Association; CERCLA = Comprehensive Environmental Response, Compensation, and Liability Act; CFR = Code of Federal Regulations; DOE = Department of Energy; DWEL = drinking water equivalent level; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; ERPG = emergency response planning guidelines; FDA = Food and Drug Administration; FR = Federal Register; GRAS = generally recognized as safe; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; MCL = maximum contaminant level; MCLG = maximum contaminant level goal; NAAQS = National Ambient Air Quality Standards; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PBT = persistent, bioaccumulative, and toxic; PEL = permissible exposure limit; RCRA = Resource Conservation and Recovery Act; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; STEL = short-term exposure limit; TLV = threshold limit value; TSCA = Toxic Substances Control Act; TSD = treatment, storage, and disposal; TWA = time-weighted average; USC = United States Code; WHO = World Health Organization