# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information regarding the chemical identity of nitrate and nitrite is provided in Table 4-1 and information regarding the chemical identity of selected inorganic nitrate and nitrite compounds is provided in Table 4-2. Information regarding ammonia and urea is provided in Table 4-3.

Inorganic nitrate and nitrite are naturally occurring ionic species that are part of the earth’s nitrogen cycle (see Figure 5-1). These anions are the products formed via the fixation of nitrogen and oxygen. Chemical processes, biological processes, and microbial processes in the environment convert nitrogen compounds to nitrite and nitrate via nitrogen fixation and nitrification. Compounds such as urea are converted via hydrolysis to ammonia, protonation of ammonia to ammonium (cation), followed by oxidation of ammonium to form nitrite, and then oxidation to form nitrate. Nitrate and nitrite are not neutral compounds, but rather the ionic (anionic; negatively charged) portions of compounds, commonly found in commerce as organic and inorganic salts. As used in this profile, the word “ion” is implied and not used, unless added for clarity.

Nitrate and nitrite typically exist in the environment as highly water-soluble inorganic salts, often bound when not solubilized to metal cations such as sodium or potassium. The nitrate ion is the more stable form as it is chemically unreactive in aqueous solution; however, it may be reduced through biotic processes with nitrate reductase to the nitrite ion. The nitrite ion is readily oxidized back to the nitrate ion via Nitrobacter (a genus of proteobacteria), or conversely, the nitrite ion may be reduced to various compounds (IARC 2010; WHO 2011b).

Under certain conditions, nitrite may be converted to a class of compounds called N-nitrosamines. In foods, endogenous production of N-nitrosamines occurs when nitrite reacts with secondary amines or amides. Several factors, including the presence of antioxidants, such as vitamin C, affect the rate of formation. N-nitrosamines are a class of chemical compounds that have a nitroso (N=O) group bonded to an amine (-N(R)R’) with a general chemical structure of RN(R’)-N=O (IARC 94).

There is a wide range of both organic and inorganic nitrate and nitrite compounds. Common nitrate and nitrite salts include potassium nitrate, potassium nitrite, sodium nitrate, sodium nitrite, and ammonium nitrate; these salts are highly soluble in water, dissociate under environmental conditions, and exist as ions (WHO 1978, 2011b). Common inorganic fertilizers that contribute to environmental concentrations of nitrate and nitrite include ammonia and urea.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of selected inorganic nitrate and nitrite compounds is provided in Table 4-4 and information regarding the physical and chemical properties of ammonia and urea is provided in Table 4-5.

Table 4-1 Chemical Identity of Nitrate and Nitrite Ions^a^

Characteristic | Nitrate ion | Nitrite ion
Synonym(s) | Nitrate ion; nitrate(1-); nitrate ion (NO_3_^−^); nitrate ion(1-); nitrato; nitric acid, ion (1-) | Nitrite ion; nitrite (1-); nitrite anion; nitrite ion (NO_2_^−^); nitrite ion (1-); nitrogen dioxide(1-); nitrogen peroxide ion (1-); nitrous acid, ion (1-)
Registered trade name(s) | No data | No data
Chemical formula | NO_3_^−^ | NO_2_^−^
Chemical structure^b^ | [image] | [image]
Ionic weight | 62.005 | 45.995
Identification numbers:
CAS registry | 14797-55-8 | 14797-65-0
NIOSH RTECS | No data | No data
EPA hazardous waste | No data | No data
DOT/UN/NA/IMDG shipping^c^ | UN3218; UN1447 | No data
HSDB | Not applicable | Not applicable
NCI | No data | No data
EPA Pesticide Chemical Code | No data | No data

a All information obtained from IARC (2010), except where noted.

b HSDB 2007.

c ChemIDplus 2014.

CAS = Chemical Abstracts Service; DOT/UN/NA/IMDG = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Chemical Identity of Selected Inorganic Nitrate and Nitrite Compounds^a^

Characteristic | Ammonium nitrate | Sodium nitrate | Sodium nitrite | Potassium nitrate | Potassium nitrite
Synonym(s) | Nitric acid, ammonium salt; ammonium nitrate (NH_4_NO_3_); Emulite; EXP 200; German saltpeter; Norge saltpeter; Norway saltpeter; Norwegian saltpeter; Plenco 12203; Varioform I; ZhVK | Nitric acid, sodium salt; Chile saltpeter; niter; nitric acid sodium salt(1:1); saltpeter; soda niter; nitrate of soda; cubic niter; nitratine | Nitrous acid, sodium salt; nitrous acid soda; nitrous acid sodium salt (1:1) | Nitric acid, potassium salt; niter; nitre; nitric acid potassium salt (1:1); saltpeter; saltpetre; nitrate of potash | Nitrous acid, potassium salt; Chile saltpeter; niter; nitric acid sodium salt (1:1); salpeter; soda niter
Registered trade name(s) | No data | No data | No data | No data | No data
Chemical formula | NH_4_NO_3_ | NaNO_3_ | NaNO_2_ | KNO_3_ | KNO_2_
Chemical structure | Trigonal NH_4_^+^NO_3_^−^ | Na^+^NO_3_^−^ | Trigonal Na^+^NO_2_^−^ | Orthorhombic K^+^NO_3_^−^ | K^+^NO_2_^−^
Chemical structure | [image] | [image] | [image] | [image] | [image]
Identification numbers:
CAS registry | 6484-52-2 | 7631-99-4 | 7632-00-0 | 7757-79-1 | 7758-09-0
NIOSH RTECS | BR9050000 | WC5600000 | RA1225000 | TT3700000 | TT3750000
EPA hazardous waste | No data | No data | No data | No data | No data
DOT/UN/NA/IMDG shipping | UN 2426; UN 0223; UN 1942; UN 2067; UN 2068; UN 2069; UN 2070; UN 2071; UN 2072; UN 0222 IMO 5.1; NA 1942; IMO 1.1; IMO 9.0 | UN 1498; IMO 5.1 | UN 1500; IMO 5.1 | UN 1486; IMO 5.1 | UN 1488; IMO 5.1
HSDB | 475 | 726 | 757 | 1227 | 1216
NCI | No data | No data | No data | No data | No data
NFPA instability hazard^b^ | 3 | No data | No data | No data | No data
EPA Pesticide Chemical Code | 076101^c^ | 076104^c^ | 076204^c^ | 076103^c^ | 076203^c^

a All information obtained from IARC 2010 and HSDB 2007, except where noted.

b NFPA 2002; instability hazard 3 = materials that in themselves are capable of detonation or explosive decomposition or explosive reaction, but that require a strong initiating source or that must be heated under confinement before initiation.

c EPA 2014f.

CAS = Chemical Abstracts Service; DOT/UN/NA/IMDG = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NFPA = National Fire Protection Association; NIOSH = National Institute for Occupational Safety and Health; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-3 Chemical Identity of Ammonia^a^ and Urea^b^

Characteristic | Ammonia | Urea
Synonym(s) | Anhydrous ammonia, ammonia gas; aqua ammonia; liquid ammonia | Alphahydrate; carbamide; carbonyl diamide; carbonyldiamine; isourea
Registered trade name(s) | BCMW; BUSAN 1215 | UAL-37; N-Dure; UF-Concentrate-85; Ureacin-20
Chemical formula | NH_3_ | CH_4_N_2_O
Chemical structure | [image] | [image]
Ionic weight | 17.03 | 60.06
Identification numbers:
CAS registry | 7664-41-7 | 57-13-6
NIOSH RTECS | No data | No data
EPA hazardous waste | No data | No data
DOT/UN/NA/IMDG shipping | UN 1005; UN 3318; UN 2672; UN 2073 | No data
HSDB | 162 | 163
NCI | No data | No data
EPA Pesticide Chemical Code | 005302 | 085702

a HSDB 2012.

b HSDB 2003.

CAS = Chemical Abstracts Service; DOT/UN/NA/IMDG = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-4 Physical and Chemical Properties of Selected Inorganic Nitrate and Nitrite Compounds^a^

Characteristic | Ammonium nitrate | Sodium nitrate | Sodium nitrite | Potassium nitrate | Potassium nitrite
CAS | 6484-52-2 | 7631-99-4 | 7632-00-0 | 7757-79-1 | 7758-09-0
Molecular weight | 80.043 | 84.995 | 68.985 | 101.103 | 85.093
Color | White; colorless (pure); gray or brown (fertilizer grade) | White; colorless | White to pale yellow | Colorless | Pale yellow
Physical state | Solid | Solid | Solid | Solid | Solid
Melting point | 169.7°C | 306°C; 308°C | 271°C | 334°C; 337°C | 440°C
Boiling point | Decomposes at ~210°C (200–260°C) | 380°C; decomposes | 320°C; decomposes | 400°C; decomposes | 537°C; explodes
Density: at 20°C/4°C | 1.725 g/cm^3^ | 2.26 g/cm^3^ | 2.17 g/cm^3^ | 2.11 g/cm^3^ | 1.915 g/cm^3^
Odor | Odorless | Odorless^b^ | No data | Odorless | No data
Odor threshold: | No data | No data | No data | No data | No data
Taste threshold | No data | No data | No data | No data | No data
Solubility:
Water at 25°C | 213 g/100 g | 91.2^c^ g/100 g | 84.8 g/100 g | 38.3 g/100 g | 312 g/100 g
Organic solvent(s) | Acetone, ammonia, ethanol, isopropanol, methanol | Ammonia, hydrazine, ethanol, methanol, acetone, glycerol | Ammonia, ethanol, methanol | Ammonia; glycerol; sl sol ethanol | Ammonia; alcohol
Partition coefficients | Not available | Not available | Not available | Not available | Not available
Vapor pressure | Not available | Not available | Not available | Not available | Not available
Henry’s law constant | Not available | Not available | Not available | Not available | Not available
Flashpoint | Not available | Flames up when heated to 540°C | 498ºC; May explode above 530°C | Not flammable | Not flammable
Flammability limits | Not available | Not available | Not available | Not available | Not available
Explosive limits | Not available | Not available | >1,000°C | Not available | Not available

a All information obtained from HSDB 2007, unless otherwise noted.

b Lewis 2002.

c Lide 2013.

CAS = Chemical Abstracts Service; HSDB = Hazardous Substances Data Bank

Table 4-5 Physical and Chemical Properties of Ammonia^a^ and Urea^b^

Characteristic | Ammonia | Urea
CAS | 7664-41-7 | 57-13-6
Molecular weight | 17.03 | 60.06
Color | Colorless | White
Physical state | Gas | Crystal/powder
Melting point | -77.7°C | 132.70°C
Boiling point | -33.35 °C at 760 mm Hg | Decomposes
Density:
at 20°C/4°C | 0.696 g/L (liquid) | 1.3230
Odor | Sharp, pungent, irritating | Slight odor of ammonia; odorless
Odor threshold: | Water: 1.5 mg/L; Air: 5.2 µL/L | No data
Taste threshold | No data | No data
Solubility:
Water | 4.82x10^5^ mg/L at 24°C | 5.45x10^5^ mg/L at 25°C
Organic solvent(s) | Alcohol, chloroform, ether | Alcohol; acetic acid; pyrimidine
Partition coefficients | No data | -2.11
Vapor pressure at 25°C | 7.51x10^3^ mm Hg | 1.2x10^-5^ mm Hg
Henry’s law constant | 1.61x10^-5^ atm m^3^/mole at 25°C | No data
Flashpoint | No data | No data
Flammability limits | No data | No data
Explosive limits | No data | No data

a HSDB 2012

b HSDB 2003

CAS = Chemical Abstracts Service; HSDB = Hazardous Substances Data Bank

Nitrate is the most oxidized form of nitrogen present in the environment (oxidation state of nitrogen +5). It accounts for the majority of the total available nitrogen in surface waters (Environment Canada 2012), perhaps due to its formation by converting the ammonium ion (e.g., from fertilizer and manure) through a 2-step oxidation process, first to nitrite and then to nitrate. In compounds, nitrate and nitrite typically exist in an oxidation state of 1^−^. Nitrate is the conjugate base of nitric acid (HNO_3_), a strong acid with pKa of −1.38 at 25°C (Dean 1985). Nitric acid and salts of nitric acid completely dissociate in aqueous solutions, except for nitrates of mercury and bismuth (Environment Canada 2012; WHO 1978). Nitrite is the conjugate base of nitrous acid (HNO_2_), a weak acid with a pKa of 3.14 at 25°C (Dean 1985); nitrite readily decomposes to yield water and dinitrogen trioxide (N_2_O_3_), or nitric acid, nitric oxide (NO), and water (H_2_O) (WHO 1978, 2011b).