# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Human Health Sciences, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology and Human Health Sciences, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-57, Atlanta, Georgia 30329-4027.

## Nitrate Acute/Intermediate/Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Nitrate
CAS Numbers: | 14797-55-8
Date: | July 2017
Profile Status: | Final
Route: | [ ] Inhalation [x] Oral
Duration: | [x] Acute [x] Intermediate [x] Chronic
Graph Key: | 3 (Acute), 15 (Intermediate), 53 (Chronic)
Species: | Human

[underlined: Minimal Risk Level]: 4 [x] mg/kg/day [ ] ppm

[underlined: Reference]: Walton G. 1951. Survey of literature relating to infant methemoglobinemia due to nitrate-contaminated water. Am J Public Health 41:986–996.

[underlined: Experimental design]: Walton (1951) reviewed available literature and found 278 reported cases of infant methemoglobinemia in a total of 14 U.S. states from which information was available. Cases were grouped by state according to ranges of nitrate levels in drinking water sources.

[underlined: Effect noted in study and corresponding doses]: Among methemoglobinemia cases for which nitrate levels in water sources used to prepare infant formula were available, 173 cases were associated with >50 mg nitrate-nitrogen/L (220 mg nitrate/L), 36 cases with 21–50 mg nitrate-nitrogen/L (92–220 mg nitrate/L), and 5 cases with 11–20 mg nitrate-nitrogen (48–88 mg nitrate/L). None of the methemoglobinemia cases were associated with drinking water sources measuring <10 mg nitrate-nitrogen/L (<44 mg nitrate/L). Limitations of the contributing studies include lack of information regarding the actual ages of the infants, total nitrate doses, and other water source contaminants (e.g., bacterial levels).

Following ingestion of relatively large amounts of nitrate by healthy normal individuals, blood methemoglobin levels increase rapidly, followed by a return to normal within several hours following intake. Repeated ingestion for intermediate- or chronic-duration time periods would be expected to result in changes in methemoglobin levels similar to those elicited from a single exposure. Therefore, the acute-, intermediate-, and chronic-duration oral MRL values are equivalent.

[underlined: Dose and end point used for MRL derivation]: 4.33 mg nitrate/kg/day

[x] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [ ] 10 for extrapolation from animals to humans
- [x] 1 for human variability

A total uncertainty factor of 1 is justified because the point of departure is a NOAEL for nitrate-induced effects on methemoglobin in a particularly sensitive human subpopulation (i.e., <3-month-old infants, which in many cases may have been at increased risk of methemoglobinemia due to microbial contamination and associated gastrointestinal infection).

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Nitrate may be expressed in terms of ionic concentration (i.e., mg nitrate/L), or elemental concentration (i.e., mg nitrate-nitrogen/L or mg nitrogen as nitrate/L). A concentration of nitrate expressed in elemental concentration (mg nitrogen per liter from nitrate source) can be converted to its ionic concentration (mg NO_3_^−^) according to the following relationship: 1 mg nitrate-nitrogen = 4.4 mg nitrate (i.e., the proportion of N in NO_3_^−^ is 14 [atomic mass of N] ÷ 62 [molecular mass of NO_3_^−^] = 0.226).

Table A-1 presents estimated nitrate doses to infants (birth–<3 months of age) calculated using estimated mean values for drinking water ingestion rates (Kahn and Stralka 2009) and body weight (EPA 2008) and assuming a drinking water level of 44 mg nitrate/L as a concentration not expected to cause methemoglobinemia; the calculated doses of 4.31–4.34 mg nitrate/kg/day represent NOAELs for the age ranges. The TWA-based calculated dose of 4.33 mg nitrate/kg/day for the age range of birth–<3 months is selected as the point of departure for deriving acute-, intermediate-, and chronic-duration oral MRLs for nitrate.

Table A-1 Estimated Nitrate Dose to Infants of Selected Age Ranges Assuming a Drinking Water Level of 44 mg Nitrate/L^a^

Age range | Water intake (L/day)^b^ | Body weight (kg)^c^ | Nitrate dose (mg/kg/day)^d^
Birth–<1 month | 0.470 | 4.8 | 4.31
1–<3 months | 0.552 | 5.6 | 4.34
Birth–<3 months | 0.525^e^ | 5.33^e^ | 4.33

a Considered a no-adverse-effect concentration for nitrate intake by infants up to 6 months of age, based on weight- of-evidence analysis of available human data.

b Estimated mean water intake (combined direct intake [ingested largely as a beverage] and indirect intake [added in preparation of food or beverages]) from community water; data from Table 3-14 of EPA (2008) and Table 2 of Kahn and Stralka (2009).

c Estimated mean body weight; data from Table 8-1 of EPA (2008).

d Nitrate dose = 44 mg nitrate/L (NOAEL) × water intake (L/day) / body weight (kg).

e Calculated TWA for birth–<1 month and 1–<3 months (e.g., TWA water intake for birth–<3 months = (0.470 L/day × 1 month) + (0.552 L/day × 2 months)/3 months = 0.525 L/day.

EPA = Environmental Protection Agency; NOAEL = no-observed-adverse-effect level; TWA = time-weighted average

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? Not applicable.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: Methemoglobinemia is a condition in which increased methemoglobin as a percentage of total hemoglobin results in the expression of clinical signs that increase in severity with increasing percent methemoglobin (ATSDR 2013a; Bloom et al. 2013; Denshaw-Burke et al. 2013; Haymond et al. 2005). In normal healthy individuals, methemoglobin levels are <1% of total hemoglobin. Discoloration (e.g., pale, gray blue) of the skin is often observed at methemoglobin levels in the range of 3–15%; most patients tolerate methemoglobin levels <10%. Tachycardia, weakness, and other signs of tissue hypoxia may be observed at 10–20% methemoglobin levels. Effects on the central nervous system (e.g., headache, dizziness, fatigue) and dyspnea and nausea appear at >20% methemoglobin; the severity of symptoms increases with increasing methemoglobin level. High risk of mortality occurs at levels >70% methemoglobin.

Proposed explanations for increased susceptibility of infants to methemoglobinemia following ingestion of nitrate include: (1) increased reduction of nitrate to nitrite in the newborn, (2) increased tendency for nitrite-induced methemoglobin formation by fetal hemoglobin compared to adult hemoglobin, (3) lower levels of NADH-dependent methemoglobin reductase (the major enzyme responsible for reduction of methemoglobin to normal hemoglobin; also termed NADH-diaphorase, a soluble form of cytochrome-b5 reductase) in the newborn compared to older infants and adults, and (4) incompletely developed hepatic microsomal enzyme system in the infant and consequent lower rate of hepatic reduction of circulating nitrite compared to that of older children and adults. A portion of ingested nitrate is reduced to nitrite by commensal bacteria in the mouth; however, the acid environment of the normal stomach does not support the growth of such bacteria and most of the nitrate that reaches the stomach passes to the small intestine from which it is nearly completely absorbed into the blood. Although Kanady et al. (2012) reported little or no bacterial conversion of nitrate to nitrite in the saliva of a group of 10 infants during the first 2 postnatal months (considered mainly due to lower numbers of major nitrate-reducing oral bacteria than adults), a higher pH in the stomach of the newborn may favor growth of nitrate-reducing bacteria, resulting in increased reduction of nitrate to nitrite and increased plasma methemoglobin. Most hemoglobin in the newborn is in the form of fetal hemoglobin, which appears to be more readily oxidized to methemoglobin than adult hemoglobin; fetal hemoglobin is replaced by adult hemoglobin during early postnatal life. Levels of NADH-dependent methemoglobin reductase in the newborn increase approximately 2-fold during the first 4 months of postnatal life to reach adult levels. During the period of relatively lower methemoglobin reductase levels, methemoglobin would not be expected to be as readily reduced, resulting in increased susceptibility to methemoglobinemia. In apparent contrast, Ibrahim et al. (2012) reported that blood nitrite levels in newborns approximately 1–2 days of age were 35–55% lower than that of adults. However, one study that evaluated reduction rates of methemoglobin in human adult blood and cord blood from term newborns estimated methemoglobin half-lives of 162 and 210 minutes, respectively, indicating that methemoglobin reduction occurs more slowly in newborns than adults (Power et al. 2007). Although specific mechanisms have not been elucidated, the increased susceptibility to nitrite-induced methemoglobinemia in infants is well-documented.

Bosch et al. (1950) evaluated 139 reported cases of cyanosis among infants in Minnesota (90% were <2 months of age; range 8 days to 5 months). Samples from 129 wells that served as water sources to the cases revealed nitrate-nitrogen concentrations >100 mg/L (>440 mg nitrate/L) in 49 wells, 50–100 mg/L (220–440 mg nitrate/L) in 53 wells, 21–50 mg/L (92–220 mg nitrate/L) in 25 wells, and 10–20 mg/L (44–88 mg nitrate/L) in the other 2 wells. A major limitation of this study was the detection of coliform organisms in 45 of 51 well water samples tested for bacterial contamination.

A nested case-control study included 26 cases of infants diagnosed with methemoglobinemia at ≤2 months of age and 45 age-matched controls (Zeman et al. 2002). Nitrate exposure levels were categorized as low (<0.5 ppm), medium (1–10 ppm), or high (>10 ppm) according to estimated nitrate levels reconstructed from parental responses to dietary questionnaires and environmental sampling. Numbers of methemoglobinemia cases in the low, medium, and high exposure categories were 0/26, 4/26, and 22/26, respectively, and estimated dietary nitrate intake ranged from 2.83 to 451.20 mg/kg/day (mean 103.6 mg nitrate/kg/day). Diarrheal disease was reported for 14/26 methemoglobinemia cases. Numbers of controls in the low, medium, and high exposure categories were 21/45, 11/45, and 13/45, respectively, and estimated dietary nitrate intake ranged from 0 to 182 mg/kg/day (mean 11.2 mg nitrate/kg/day) for the controls; diarrheal disease was reported for 13/45 controls. Univariate and multifactorial analysis of risk factors for methemoglobinemia indicated that methemoglobinemia was most strongly associated with dietary exposure to nitrate/nitrite (p=0.0318), but also significantly associated with diarrheal disease (p=0.0376). Controls in the high exposure category were less likely than high exposure methemoglobinemia cases to have experienced severe diarrhea and were more likely to have been breastfed for >2 weeks. Major limitations to the study include the collection of information contributing to the exposure estimates several years following the occurrences of methemoglobinemia and reliance on parental recollection of infant nutritional intake.

Results from other studies suggest an association between nitrate in drinking water sources and elevated methemoglobin among infants. Average methemoglobin levels of 1.0, 1.3, and 2.9% during the first postnatal trimester (0–3 months of age) were reported among groups healthy infants with water sources that were nitrate-free or contained 50–100 mg nitrate/L or >100 mg nitrate/L, respectively (Simon et al. 1964). At the end of the second trimester (6 months), methemoglobin averaged 0.7–0.8% for each group. Super et al. (1981) reported mean methemoglobin levels of 1.54% among infants ingesting ≤2.93 mg nitrate/kg/day and 3.03% among infants ingesting >2.93 mg nitrate/kg/day.

Limited data are available regarding administration of controlled amounts of nitrate and methemoglobin levels. Cornblath and Hartmann (1948) administered sodium nitrate in the formula fed to four infants (ages 11 days to 11 months) for 2–18 days at a concentration resulting in a dose of 50 mg nitrate/kg/day. The highest observed level of methemoglobin was 5.3% of total hemoglobin; there was no evidence of cyanosis. Among four other infants (ages 2 days to 6 months) similarly treated at 100 mg nitrate/kg/day for 6–9 days, the only reported effect was that of 7.5% methemoglobin in a 10-day-old infant following 8 days of treatment in the absence of clinical cyanosis. Gruener and Toeplitz (1975) fed 104 infants (1 week to 10 months of age) for 1 day with formula prepared using water containing 15 mg nitrate/L (~0.8–1.5 mg nitrate/kg, based on age-specific values for water consumption [Kahn and Stralka 2009] and body weight [EPA 2008]), increased to 108 mg nitrate/L for the next 3 days (~5.5–10.6 mg nitrate/kg/day, based on age-specific values for water consumption [Kahn and Stralka 2009] and body weight [EPA 2008], and returned to 15 mg nitrate/L for 1 additional day. Mean methemoglobin levels were 0.89% after the first day of feeding, 1.3, 0.91, and 0.93% after days 2, 3, and 4, and dropped to 0.8% on the fifth day. Among three of these infants (ages not specified), methemoglobin levels reached 6.9, 13.9, and 15.9% during the high-dose days. Limitations of this study include the use of a wide range of ages and the fact that only 57 of the 104 infants supplied blood samples on all 5 treatment days.

[underlined: Agency Contacts (Chemical Managers)]: Carolyn Harper, Ph.D.

## Nitrite Acute/Intermediate/Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Nitrite
CAS Numbers: | 14797-65-0
Date: | July 2017
Profile Status: | Final
Route: | [ ] Inhalation [x] Oral
Duration: | [x] Acute [x] Intermediate [x] Chronic
Graph Key: | 4 (Acute), 16 (Intermediate), 54 (Chronic)
Species: | Human

[underlined: Minimal Risk Level]: 0.1 [x] mg/kg/day [ ] ppm

[underlined: Reference]: Walton G. 1951. Survey of literature relating to infant methemoglobinemia due to nitrate-contaminated water. Am J Public Health 41:986–996.

[underlined: Experimental design]: Walton (1951) reviewed available literature and found 278 reported cases of infant methemoglobinemia in a total of 14 U.S. states from which information was available. Cases were grouped by state according to ranges of nitrate levels in drinking water sources.

[underlined: Effect noted in study and corresponding doses]: Among methemoglobinemia cases for which nitrate levels in water sources used to prepare infant formula were available, 173 cases were associated with >50 mg nitrate-nitrogen/L (220 mg nitrate/L), 36 cases with 21–50 mg nitrate-nitrogen/L (92–220 mg nitrate/L), and 5 cases with 11–20 mg nitrate-nitrogen (48–88 mg nitrate/L). None of the methemoglobinemia cases were associated with drinking water sources measuring <10 mg nitrate-nitrogen/L (<44 mg nitrate/L). Limitations of the contributing studies include lack of information regarding the actual ages of the infants, total nitrate doses, and other water source contaminants (e.g., bacterial levels).

Following ingestion of relatively large amounts of nitrate by healthy normal individuals, blood methemoglobin levels increase rapidly, followed by a return to normal within several hours following intake. Repeated ingestion of nitrate or nitrite for intermediate- or chronic-duration time periods would be expected to result in changes in methemoglobin levels similar to those elicited from a single exposure. Therefore, the acute-, intermediate-, and chronic-duration oral MRL values are equivalent.

[underlined: Dose and end point used for MRL derivation]: 0.2 mg nitrite/kg/day. The ingestion of nitrate results in the formation of nitrite, which is the moiety responsible for methemoglobinemia. On average, approximately 25% of an ingested dose of nitrate enters the saliva of an adult where a portion (ca. 20% g/g) is reduced by commensal bacteria to nitrite (i.e., approximately 5% g/g of ingested nitrate is reduced to nitrite in the saliva of an adult (Spiegelhalder et al. 1976); most salivary nitrite is absorbed into the blood in the small intestine. Therefore, the ingestion of 0.2 mg nitrite/kg/day by an adult would be expected to result in a nitrite blood level similar to that achieved following ingestion of 4 mg nitrate/kg/day, based on essentially 100% absorption of the ingested dose of nitrite (i.e., 0.2 mg nitrite/kg/day is 5% of an oral dose of nitrate at the oral MRL of 4 mg nitrate/kg/day).

[x] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [ ] 10 for extrapolation from animals to humans
- [x] 1 for human variability

A total uncertainty factor of 1 is justified because the point of departure is a NOAEL for nitrate-induced effects on methemoglobin in a particularly sensitive human subpopulation (i.e., <3-month-old infants, which in many cases may have been at increased risk of methemoglobinemia due to microbial contamination and associated gastrointestinal infection).

[underlined: Modifying factor used in MRL derivation]:

- [x] 2 because young infants exhibit increased susceptibility to methemoglobinemia following nitrate ingestion; the modifying factor assumes that the effective methemoglobin level from a given intake of nitrate by an infant is up to twice that of an adult; however, quantitative data regarding conversion of nitrate to nitrite in the infant are lacking.

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Nitrate may be expressed in terms of ionic concentration (i.e., mg nitrate/L), or elemental concentration (i.e., mg nitrate-nitrogen/L or mg nitrogen as nitrate/L). A concentration of nitrate expressed in elemental concentration (mg nitrogen per liter from nitrate source) can be converted to its ionic concentration (mg NO_3_^−^) according to the following relationship: 1 mg nitrate-nitrogen = 4.4 mg nitrate (i.e., the proportion of N in NO_3_^−^ is 14 [atomic mass of N] ÷ 62 [molecular mass of NO_3_^−^] = 0.226).

A concentration of 44 mg nitrate/L (10 mg nitrate-nitrogen/L) in drinking water used to prepare infant formula represents a NOAEC for infants <3 months of age. Table A-1 presents estimated nitrate doses to infants (birth–<3 months of age) calculated using estimated mean values for drinking water ingestion rates (Kahn and Stralka 2009) and body weight (EPA 2008) and assuming a drinking water level of 44 mg nitrate/L as a concentration not expected to cause methemoglobinemia; the calculated doses of 4.31–4.34 mg nitrate/kg/day represent NOAELs for the age ranges. The TWA-based calculated dose of 4.33 mg nitrate/kg/day for the age range of birth–<3 months is selected as the point of departure for deriving acute-, intermediate-, and chronic-duration oral MRLs for nitrite.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? Not applicable.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: Methemoglobinemia is a condition in which increased methemoglobin as a percentage of total hemoglobin results in the expression of clinical signs that increase in severity with increasing percent methemoglobin (ATSDR 2013a; Bloom et al. 2013; Denshaw-Burke et al. 2013; Haymond et al. 2005). In normal healthy individuals, methemoglobin levels are <1% of total hemoglobin. Discoloration (e.g., pale, gray blue) of the skin is often observed at methemoglobin levels in the range of 3–15%; most patients tolerate methemoglobin levels <10%. Tachycardia, weakness, and other signs of tissue hypoxia may be observed at 10–20% methemoglobin levels. Effects on the central nervous system (e.g., headache, dizziness, fatigue) and dyspnea and nausea appear at >20% methemoglobin; the severity of symptoms increases with increasing methemoglobin level. High risk of mortality occurs at levels >70% methemoglobin.

Proposed explanations for increased susceptibility of infants to methemoglobinemia following ingestion of nitrate include: (1) increased reduction of nitrate to nitrite in the newborn, (2) increased tendency for nitrite-induced methemoglobin formation by fetal hemoglobin compared to adult hemoglobin, (3) lower levels of NADH-dependent methemoglobin reductase (the major enzyme responsible for reduction of methemoglobin to normal hemoglobin; also termed NADH-diaphorase, a soluble form of cytochrome-b5 reductase) in the newborn compared to older infants and adults, and (4) incompletely developed hepatic microsomal enzyme system in the infant and consequent lower rate of hepatic reduction of circulating nitrite compared to that of older children and adults. A portion of ingested nitrate is reduced to nitrite by commensal bacteria in the mouth; however, the acid environment of the normal stomach does not support the growth of such bacteria and most of the nitrate that reaches the stomach passes to the small intestine from which it is nearly completely absorbed into the blood. Although Kanady et al. (2012) reported little or no bacterial conversion of nitrate to nitrite in the saliva of a group of 10 infants during the first 2 postnatal months (considered mainly due to lower numbers of major nitrate-reducing oral bacteria than adults), a higher pH in the stomach of the newborn may favor growth of nitrate-reducing bacteria, resulting in increased reduction of nitrate to nitrite and increased plasma methemoglobin. Most hemoglobin in the newborn is in the form of fetal hemoglobin, which appears to be more readily oxidized to methemoglobin than adult hemoglobin; fetal hemoglobin is replaced by adult hemoglobin during early postnatal life. Levels of NADH-dependent methemoglobin reductase in the newborn increase approximately 2-fold during the first 4 months of postnatal life to reach adult levels. During the period of relatively lower methemoglobin reductase levels, methemoglobin would not be expected to be as readily reduced, resulting in increased susceptibility to methemoglobinemia. In apparent contrast, Ibrahim et al. (2012) reported that blood nitrite levels in newborns approximately 1–2 days of age were 35–55% lower than that of adults. However, one study that evaluated reduction rates of methemoglobin in human adult blood and cord blood from term newborns estimated methemoglobin half-lives of 162 and 210 minutes, respectively, indicating that methemoglobin reduction occurs more slowly in newborns than adults (Power et al. 2007). Although specific mechanisms have not been elucidated, the increased susceptibility to nitrite-induced methemoglobinemia in infants is well-documented.

Bosch et al. (1950) evaluated 139 reported cases of cyanosis among infants in Minnesota (90% were <2 months of age; range 8 days to 5 months). Samples from 129 wells that served as water sources to the cases revealed nitrate-nitrogen concentrations >100 mg/L (>440 mg nitrate/L) in 49 wells, 50–100 mg/L (220–440 mg nitrate/L) in 53 wells, 21–50 mg/L (92–220 mg nitrate/L) in 25 wells, and 10–20 mg/L (44–88 mg nitrate/L) in the other 2 wells. A major limitation of this study was the detection of coliform organisms in 45 of 51 well water samples tested for bacterial contamination.

A nested case-control study included 26 cases of infants diagnosed with methemoglobinemia at ≤2 months of age and 45 age-matched controls (Zeman et al. 2002). Nitrate exposure levels were categorized as low (<0.5 ppm), medium (1–10 ppm), or high (>10 ppm) according to estimated nitrate levels reconstructed from parental responses to dietary questionnaires and environmental sampling. Numbers of methemoglobinemia cases in the low, medium, and high exposure categories were 0/26, 4/26, and 22/26, respectively, and estimated dietary nitrate intake ranged from 2.83 to 451.20 mg/kg/day (mean 103.6 mg nitrate/kg/day). Diarrheal disease was reported for 14/26 methemoglobinemia cases. Numbers of controls in the low, medium, and high exposure categories were 21/45, 11/45, and 13/45, respectively, and estimated dietary nitrate intake ranged from 0 to 182 mg/kg/day (mean 11.2 mg nitrate/kg/day) for the controls; diarrheal disease was reported for 13/45 controls. Univariate and multifactorial analysis of risk factors for methemoglobinemia indicated that methemoglobinemia was most strongly associated with dietary exposure to nitrate/nitrite (p=0.0318), but also significantly associated with diarrheal disease (p=0.0376). Controls in the high exposure category were less likely than high exposure methemoglobinemia cases to have experienced severe diarrhea and were more likely to have been breastfed for >2 weeks. Major limitations to the study include the collection of information contributing to the exposure estimates several years following the occurrences of methemoglobinemia and reliance on parental recollection of infant nutritional intake.

Results from other studies suggest an association between nitrate in drinking water sources and elevated methemoglobin among infants. Average methemoglobin levels of 1.0, 1.3, and 2.9% during the first postnatal trimester (0–3 months of age) were reported among groups healthy infants with water sources that were nitrate-free or contained 50–100 mg nitrate/L or >100 mg nitrate/L, respectively (Simon et al. 1964). At the end of the second trimester (6 months), methemoglobin averaged 0.7–0.8% for each group. Super et al. (1981) reported mean methemoglobin levels of 1.54% among infants ingesting ≤2.93mg nitrate/kg/day and 3.03% among infants ingesting >2.93 mg nitrate/kg/day.

Limited data are available regarding administration of controlled amounts of nitrate and methemoglobin levels. Cornblath and Hartmann (1948) administered sodium nitrate in the formula fed to four infants (ages 11 days to 11 months) for 2–18 days at a concentration resulting in a dose of 50 mg nitrate/kg/day. The highest observed level of methemoglobin was 5.3% of total hemoglobin; there was no evidence of cyanosis. Among four other infants (ages 2 days to 6 months) similarly treated at 100 mg nitrate/kg/day for 6–9 days, the only reported effect was that of 7.5% methemoglobin in a 10-day-old infant following 8 days of treatment in the absence of clinical cyanosis. Gruener and Toeplitz (1975) fed 104 infants (1 week to 10 months of age) for 1 day with formula prepared using water containing 15 mg nitrate/L (~0.8–1.5 mg nitrate/kg, based on age-specific values for water consumption [Kahn and Stralka 2009] and body weight [EPA 2008]), increased to 108 mg nitrate/L for the next 3 days (~5.5–10.6 mg nitrate/kg/day, based on age-specific values for water consumption [Kahn and Stralka 2009] and body weight [EPA 2008], and returned to 15 mg nitrate/L for 1 additional day. Mean methemoglobin levels were 0.89% after the first day of feeding, 1.3, 0.91, and 0.93% after days 2, 3, and 4, and dropped to 0.8% on the fifth day. Among three of these infants (ages not specified), methemoglobin levels reached 6.9, 13.9, and 15.9% during the high-dose days. Limitations of this study include the use of a wide range of ages and the fact that only 57 of the 104 infants supplied blood samples on all 5 treatment days.

In a study designed to evaluate the oral bioavailability of sodium nitrite in healthy volunteers (seven females and two males; mean age 22.9 years), ingestion of ~2.2–2.7 mg sodium nitrite/kg (1.5–1.8 mg nitrite/kg) resulted in maximum methemoglobin concentrations ranging from 3.4 to 4.5% of total hemoglobin at approximately 0.70 hours following ingestion (Kortboyer et al. 1997b). At a higher intake (~4.4–5.4 mg sodium nitrite/kg, or 2.9–3.6 mg nitrite/kg), the maximum methemoglobin concentrations ranged from 7.7 to 10.9% of total hemoglobin at approximately 1.14 hours following ingestion.

[underlined: Agency Contacts (Chemical Managers)]: Carolyn Harper, Ph.D.