# CHAPTER 8 REFERENCES

Abudayyak M, Guzel E, Ozhan G. 2017a. Nickel oxide nanoparticles induce oxidative DNA damage and apoptosis in kidney cell line (NRK-52E). Biol Trace Elem Res 178(1):98–104. 10.1007/s12011-016-0892-z.27878512
Abudayyak M, Guzel E, Ozhan G. 2017b. Nickel oxide nanoparticles are highly toxic to SH-SY5Y neuronal cells. Neurochem Int 108:7–14. 10.1016/j.neuint.2017.01.017.28159626
Abudayyak M, Guzel E, Ozhan G. 2020. Cytotoxic, genotoxic, and apoptotic effects of nickel oxide nanoparticles in intestinal epithelial cells. Turk J Pharm Sci 17(4):446–451. 10.4274/tjps.galenos.2019.76376.32939142
Adamo P, Dudka S, Wilson MJ, . 1996. Chemical and mineralogical forms of Cu and Ni in contaminated soils from the Sudbury mining and smelting region, Canada. Environ Pollut 91(1):11–19.15091449
Adams JF, Kissel DE. 1989. Zinc, copper, and nickel availabilities as determined by soil solution and DTPA extraction of a sludge-amended soil. Commun Soil Sci Plant Anal 20(1–2):139–158. 10.1080/00103628909368074.
Adeyemi OS, Elebiyo TC. 2014. Moringa oleifera supplemented diets prevented nickel-induced nephrotoxicity in Wistar tats. J Nutr Metab 2014:958621. 10.1155/2014/958621.25295181
Adeyemi OS, Aroge CS, Akanji MA. 2017. Moringa oleifera-based diet protects against nickel-induced hepatotoxicity in rats. J Biomed Res 31(4):350–357. 10.7555/JBR.31.20160051.28808207
Adkins B, Richards JH, Gardner DE. 1979. Enhancement of experimental respiratory infection following nickel inhalation. Environ Res 20(1):33–42. 10.1016/0013-9351(79)90083-5.387408
Ahamed M. 2011. Toxic response of nickel nanoparticles in human lung epithelial A549 cells. Toxicol In Vitro 25(4):930–936. 10.1016/j.tiv.2011.02.015.21376802
Ahamed M, Akhtar MJ, Alhadlaq HA, . 2015. Comparative cytotoxic response of nickel ferrite nanoparticles in human liver HepG2 and breast MFC-7 cancer cells. Chemosphere 135:278–288. 10.1016/j.chemosphere.2015.03.079.25966046
Aherrera A, Olmedo P, Grau-Perez M, . 2017. The association of e-cigarette use with exposure to nickel and chromium: A preliminary study of non-invasive biomarkers. Environ Res 159:313–320. 10.1016/j.envres.2017.08.014.28837903
Ahlstrom MG, Midander K, Menne T, . 2019. Nickel deposition and penetration into the stratum corneum after short metallic nickel contact: An experimental study. Contact Dermatitis 80(2):86–93. 10.1111/cod.13136.30370609
Ahmad J, Alhadlaq HA, Siddiqui MA, . 2015. Concentration-dependent induction of reactive oxygen species, cell cycle arrest and apoptosis in human liver cells after nickel nanoparticles exposure. Environ Toxicol 30(2):137–148. 10.1002/tox.21879.23776134
Akasya-Hillenbrand E, Ozkaya-Bayazit E. 2002. Patch test results in 542 patients with suspected contact dermatitis in Turkey. Contact Dermatitis 46(1):17–23. 10.1034/j.1600-0536.2002.460104.x.11918582
Åkerlund E, Cappellini F, Di Bucchianico S, . 2018. Genotoxic and mutagenic properties of Ni and NiO nanoparticles investigated by comet assay, gamma-H2AX staining, Hprt mutation assay and ToxTracker reporter cell lines. Environ Mol Mutagen 59(3):211–222. 10.1002/em.22163.29243303
Åkerlund E, Islam MS, McCarrick S, . 2019. Inflammation and (secondary) genotoxicity of Ni and NiO nanoparticles. Nanotoxicology 13(8):1060–1072. 10.1080/17435390.2019.1640908.31322448
Alaraby M, Hernandez A, Marcos R. 2018. Systematic in vivo study of NiO nanowires and nanospheres: biodegradation, uptake and biological impacts. Nanotoxicology 12(9):1027–1044. 10.1080/17435390.2018.1513091.30253711
Alarifi S, Ali D, Alakhtani S, . 2014. Reactive oxygen species-mediated DNA damage and apoptosis in human skin epidermal cells after exposure to nickel nanoparticles. Biol Trace Elem Res 157(1):84–93. 10.1007/s12011-013-9871-9.24307203
Alaska Department of Environmental Conservation. 2021. Nickel in fish and shellfish caught in Alaskan waters. Anchorage, AK: State of Alaska Department of Environmental Conservation Fish Monitoring Program.
Alberici TM, Sopper WE, Storm GL, . 1989. Trace metals in soil, vegetation, and voles from mine land treated with sewage sludge. J Environ Qual 18(1):115–120. 10.2134/jeq1989.00472425001800010021x. 2021/03/29.
Ali AA. 2019. Evaluation of some biological, biochemical, and hematological aspects in male albino rats after acute exposure to the nano-structured oxides of nickel and cobalt. Environ Sci Pollut Res Int 26(17):17407–17417. 10.1007/s11356-019-05093-2.31020524
Alinaghi F, Bennike NH, Egeberg A, . 2019. Prevalence of contact allergy in the general population: A systematic review and meta analysis. Contact Dermatitis 80:77–85. 10.1111/cod.13119.30370565
Alinaghi F, Havmose M, Thyssen JP, . 2023. Contact allergy to metals in metalworkers: A systematic review and meta-analysis. Contact Dermatitis 88(1):1–9. 10.1111/cod.14232.36208426
Alsoltane HM, Altaee AA. 2020a. Histological study of pregnant albino rat treated with nickel oxide nanoparticles. Medico Legal Update 20(1):966–970. 10.37506/mlu.v20i1.496 2021/10/07.
Alsoltane HM, Altaee AA. 2020b. Hormonal and immunological study in serum of pregnant albino rats treated with nickel oxide nanoparticles. Indian J Forensic Med Toxicol 14(2):640–645. 10.37506/ijfmt.v14i2.2923. 2021/10/07.
Amacher DE, Paillet SC. 1980. Induction of trifluorothymidine-resistant mutants by metal ions in L5178Y/TK+/− cells. Mutat Res 78(3):279–288. 10.1016/0165-1218(80)90110-X.7432364
Ambrose A, Larson P, Borzelleca J, . 1976. Long term toxicologic assessment of nickel in rats and dogs. J Food Sci Technol 13:181–187.
American Biogenics Corporation. 1988. Ninety day gavage study in albino rats using nickel. Final report submitted to U.S. Environmental Protection Agency, Office of Solid Waste. Submitted by Research Triangle Institute and American Biogenics Corporation.
Andersen O. 1983. Effects of coal combustion products and metal compounds on sister chromatid exchange (SCE) in a macrophagelike cell line. Environ Health Perspect 47:239–253. 10.1289/ehp.8347239.6337826
Andersen I, Svenes KB. 1989. Determination of nickel in lung specimens of thirty-nine autopsied nickel workers. Int Arch Occup Environ Health 61(4):289–295. 10.1007/bf00381428.2722252
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York, NY: Marcel Dekker, Inc., 9–25.
Andersen A, Berge SR, Engeland A, . 1996. Exposure to nickel compounds and smoking in relation to incidence of lung and nasal cancer among nickel refinery workers. Occup Environ Med 53(10):708–713. 10.1136/oem.53.10.708.8943837
Anderson PR, Christensen TH. 1988. Distribution coefficients of Cd, Co, Ni, and Zn in soils. J Soil Sci 39:15–22.
Angerer J, Lehnert G. 1990. Occupational chronic exposure to metals. II. Nickel exposure of stainless steel welders--biological monitoring. Int Arch Occup Environ Health 62(1):7–10. 10.1007/bf00397842.2295525
Antonsen DH, Meshri DT. 2005. Nickel compounds. In: Kirk-Othmer encyclopedia of chemcial technology. Vol. 16. John Wiley & Sons, Inc. 10.1002/0471238961.1409031101142015.a01.pub2.
Anttila A, Pukkala E, Aitio A, . 1998. Update of cancer incidence among workers at a copper/nickel smelter and nickel refinery. Int Arch Occup Environ Health 71(4):245–250. 10.1007/s004200050276.9638480
Antwi SO, Eckert EC, Sabaque CV, . 2015. Exposure to environmental chemicals and heavy metals, and risk of pancreatic cancer. Cancer Causes Control 26(11):1583–1591. 10.1007/s10552-015-0652-y.26293241
Anyachor CP, Orish CN, Ezejiofor AN, . 2023. Nickel and aluminium mixture elicit memory impairment by activation of oxidative stress, COX-2, and diminution of AChE, BDNF and NGF levels in cerebral cortex and hippocampus of male albino rats. Curr Res Toxicol 5:100129. 10.1016/j.crtox.2023.100129.37841055
Arain SS, Kazi TG, Arain JB, . 2013. Simultaneous preconcentration of toxic elements in artificial saliva extract of smokeless tobacco product, mainpuri by cloud point extraction method. Ecotoxicol Environ Saf 92:289–296. 10.1016/j.ecoenv.2013.03.001.23566880
Arain SS, Kazi TG, Afridi HI, . 2015. Estimation of nickel in different smokeless tobacco products and their impact on human health of oral cancer patients. Nutr Cancer 67(7):1063–1074. 10.1080/01635581.2015.1073758.26368676
Arena VC, Sussman NB, Redmond CK, . 1998. Using alternative comparison populations to assess occupation-related mortality risk. Results for the high nickel alloys workers cohort. J Occup Environ Med 40(10):907–916. 10.1097/00043764-199810000-00012.9800177
Arlauskas A, Baker RSU, Bonin AM, . 1985. Mutagenicity of metal ions in bacteria. Environ Res 36(2):379–388. 10.1016/0013-9351(85)90032-5.3884331
Arnich N, Lanhers MC, Cunat L, . 2000. Nickel absorption and distribution from rat small intestine in situ. Biol Trace Elem Res 74(2):141–151. 10.1385/bter:74:2:141.11051588
Arrouijal FZ, Marzin D, Hildebrand HF, . 1992. Differences in genotoxic activity of alpha-Ni3S2 on human lymphocytes from nickel-hypersensitized and nickel-unsensitized donors. Mutagenesis 7(3):183–187. 10.1093/mutage/7.3.183.1602972
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry. Federal Register 54(174):37618–37634. https://www.govinfo.gov/content/pkg/FR-1989-09-11/pdf/FR-1989-09-11.pdf. October 4, 2023.
ATSDR. 2022. Nickel and nickel compounds. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/SPL/resources/index.html. March 24, 2024.
Babaahmadifooladi M, Jacxsens L, Van de Wiele T, . 2021. Assessment of bioaccessible and dialyzable fractions of nickel in food products and their impact on the chronic exposure of Belgian population to nickel. Food Chem 342:128210. 10.1016/j.foodchem.2020.128210.33508898
Bach RO, Svendsen MT, Mose KF, . 2022. A comparison of patch testing with nickel sulfate in TRUE Test and in petrolatum at 2.5% and 5% concentrations. Contact Dermatitis 86(3):233–234. 10.1111/cod.14013.34800302
Badea M, Luzardo OP, Gonzalez-Antuna A, . 2018. Body burden of toxic metals and rare earth elements in non-smokers, cigarette smokers and electronic cigarette users. Environ Res 166:269–275. 10.1016/j.envres.2018.06.007.29908458
Bailey MR, Roy M. 1994. Annex E. Clearance of particles from the respiratory tract. Ann ICRP 24(1):301–413. 10.1016/0146-6453(94)90043-4.
Barakat MA. 2011. New trends in removing heavy metals from industrial wastewater. Arab J Chem 4(4):361–377. 10.1016/j.arabjc.2010.07.019.
Baranowska-Dutkiewicz B, Rozanska R, Dutkiewicz T. 1992. Occupational and environmental exposure to nickel in Poland. Pol J Occup Med Environ Health 5(4):335–343.1298482
Barceloux DG. 1999. Nickel. J Toxicol Clin Toxicol 37(2):239–258. 10.1081/clt-100102423.10382559
Barnes DG, Dourson M. 1988. Reference dose (RfD): description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486. 10.1016/0273-2300(88)90047-5.3222488
Barr. 2019. Re: Permit to install application covering minor changes at the Eagle Mine in Michigamme Township, Michigan (SRN: N7581). Grand Rapids, MI: Barr Engineering Company. https://www.michigan.gov/egle/-/media/Project/Websites/egle/Documents/Permits/AQD/PTI/applications-of-interest/eagle-mine/APP-2023-0306-Humboldt-Mill-PTI-Support-2023-11-22.pdf. April 26, 2024.
Barr. 2023. Re: Permit to install application covering a proposed modification at the Eagle Mine, LLC in Champion, Michigan (SRN: N0934). Grand Rapids, MI: Barr Engineering Company. https://www.michigan.gov/egle/-/media/Project/Websites/egle/Documents/Permits/AQD/PTI/applications-of-interest/eagle-mine/PTI-50-06D-Eagle-Mine-Application-2019-06-19.pdf. April 26, 2024.
Barwari L, Rustemeyer T, Franken SM, . 2023. Patch test results in a Dutch paediatric population with suspected contact allergy: A retrospective cohort study. Contact Dermatitis 88(2):120–128. 10.1111/cod.14231.36183152
Bavazzano P, Bolognesi R, Cassinelli C, . 1994. Skin contamination and low airborne nickel exposure of electroplaters. Sci Total Environ 155(1):83–86. 10.1016/0048-9697(94)90363-8.7973613
Beck M, Rombouts C, Moreels M, . 2014. Modulation of gene expression in endothelial cells in response to high LET nickel ion irradiation. Int J Mol Med 34(4):1124–1132. 10.3892/ijmm.2014.1893.25118949
Becker N. 1999. Cancer mortality among arc welders exposed to fumes containing chromium and nickel. Results of a third follow-up: 1989-1995. J Occup Environ Med 41(4):294–303. 10.1097/00043764-199904000-00012.10224596
Bell ML, Belanger K, Ebisu K, . 2010. Prenatal exposure to fine particulate matter and birth weight: variations by particulate constituents and sources. Epidemiology 21(6):884–891. 10.1097/EDE.0b013e3181f2f405.20811286
Belliardo C, Di Giorgio C, Chaspoul F, . 2018. Direct DNA interaction and genotoxic impact of three metals: Cadmium, nickel and aluminum. J Chem Thermodyn 125:271–277. 10.1016/j.jct.2018.05.028.
Bencko V, Wagner V, Wagnerová M, . 1983. Immuno-biochemical findings in groups of individuals occupationally and non-occupationally exposed to emissions containing nickel and cobalt. J Hyg Epidemiol Microbiol Immunol 27(4):387–394.
Bencko V, Wagner V, Wagnerová M, . 1986. Human exposure to nickel and cobalt: biological monitoring and immunobiochemical response. Environ Res 40(2):399–410. 10.1016/s0013-9351(86)80115-3.3732211
Bennett BG. 1984. Environmental nickel pathways to man. IARC Sci Publ (53):487–495.
Benson JM, Carpenter RL, Hahn FF, . 1987. Comparative inhalation toxicity of nickel subsulfide to F344/N rats and B6C3F1 mice exposed for 12 days. Fundam Appl Toxicol 9(2):251–265. 10.1016/0272-0590(87)90047-9.3653567
Benson JM, Burt DG, Carpenter RL, . 1988. Comparative inhalation toxicity of nickel sulfate to F344/N rats and B6C3F1 mice exposed for twelve days. Fundam Appl Toxicol 10(1):164–178. 10.1016/0272-0590(88)90261-8.3350225
Benson JM, Barr EB, Bechtold WE, . 1994. Fate of inhaled nickel oxide and nickel subsulfide in F344/N rats. Inhal Toxicol 6(2):167–183.
Benson JM, Chang IY, Cheng YS, . 1995a. Particle clearance and histopathology in lungs of F344/N rats and B6C3F1 mice inhaling nickel oxide or nickel sulfate. Fundam Appl Toxicol 28(2):232–244. 10.1006/faat.1995.1164.8835233
Benson JM, Cheng YS, Eidson AF, . 1995b. Pulmonary toxicity of nickel subsulfide in F344/N rats exposed for 1-22 days. Toxicology 103(1):9–22. 10.1016/0300-483x(95)03098-z.8525492
Berge SR, Skyberg K. 2003. Radiographic evidence of pulmonary fibrosis and possible etiologic factors at a nickel refinery in Norway. J Environ Monit 5(4):681–688. 10.1039/b209623b.12948249
Bernacki EJ, Parsons GE, Sunderman FW, Jr. 1978. Investigation of exposure to nickel and lung cancer mortality: case control study at aircraft engine factory. Ann Clin Lab Sci 8(3):190–194.655607
Bernacki EJ, Zygowicz E, Sunderman FW, Jr. 1980. Fluctuations of nickel concentrations in urine of electroplating workers. Ann Clin Lab Sci 10(1):33–39.7362196
Berniyanti T, Palupi R, Kriswandini IL, . 2020. Suitability of MDA, 8-OHdG and wild-type p53 as genotoxic biomarkers in metal (Co, Ni and Cr) exposed dental technicians: a cross-sectional study. BMC Oral Health 20:65. 10.1186/s12903-020-1049-1.32138726
Biedermann KA, Landolph JR. 1987. Induction of anchorage independence in human diploid foreskin fibroblasts by carcinogenic metal salts. Cancer Res 47(14):3815–3823. https://cancerres.aacrjournals.org/content/canres/47/14/3815.full.pdf.3594439
Biggart NW, Costa M. 1986. Assessment of the uptake and mutagenicity of nickel chloride in Salmonella tester strains. Mutat Res Lett 175(4):209–215. 10.1016/0165-7992(86)90056-4.
Biggart NW, Murphy EC, Jr. 1988. Analysis of metal-induced mutations altering the expression or structure of a retroviral gene in a mammalian cell line. Mutat Res 198(1):115–129. 10.1016/0027-5107(88)90047-4.2832750
Biggart NW, Gallick GE, Murphy EC. 1987. Nickel-induced heritable alterations in retroviral transforming gene expression. J Virol 61(8):2378. http://jvi.asm.org/content/61/8/2378.abstract.3037102
Bingham E, Barkley W, Zerwas M, . 1972. Responses of alveolar macrophages to metals. I. Inhalation of lead and nickel. Arch Environ Health 25(6):406–414. 10.1080/00039896.1972.10666195.5086909
Birge WJ, Black JA. 1980. Aquatic toxicology of nickel. In: Nriagu JO, ed. Nickel in the environment. John Wiley & Sons, 354–355.
Bogen KT, Tsuji JS, Taylor MD, . 2021. Human biokinetic model for soluble nickel addressing inter-individual variation. Hum Ecol Risk Assess 27(8):2015–2037.
Bolek EC, Erden A, Kulekci C, . 2017. Rare occupational cause of nasal septum perforation: Nickel exposure. Int J Occup Med Environ Health 30(6):963–967. 10.13075/ijomeh.1896.01019.28839290
Borg K, Tjälve H. 1989. Uptake of 63Ni2+ in the central and peripheral nervous system of mice after oral administration: effects of treatments with halogenated 8-hydroxyquinolines. Toxicology 54(1):59–68. 10.1016/0300-483x(89)90078-4.2916242
Borská L, Fiala Z, Smejkalová J, . 2003. Health risk of occupational exposure in welding processes I. Genotoxic risk. Acta Medica (Hradec Kralove) 46(1):25–29.12747536
Bowman RS, Essington ME, O’Connor GA. 1981. Soil sorption of nickel: influence of solution composition. Soil Sci Soc Am J 45:860–865.
Bowman N, Caravati EM, Horowitz BZ, . 2018. Acute pneumonitis associated with nickel carbonyl exposure in the workplace. Clin Toxicol (Phila) 56(3):223–225. 10.1080/15563650.2017.1355057.28753074
Bradley RW, Morris JR. 1986. Heavy metals in fish from a series of metal-contaminated lakes near Sudbury, Ontario. Water Air Soil Pollut 27(3–4):341–354. 10.1007/bf00649416.
Brera S, Nicolini A. 2005. Respiratory manifestations due to nickel. Acta Otorhinolaryngol Ital 25(2):113–115.16116834
Brito G, Díaz C, Galindo L, . 1990. Levels of metals in canned meat products: intermetallic correlations. Bull Environ Contam Toxicol 44(2):309–316. 10.1007/bf01700152.2322673
Brix KV, Schlekat CE, Garman ER. 2017. The mechanisms of nickel toxicity in aquatic environments: An adverse outcome pathway analysis. Environ Toxicol Chem 36(5):1128–1137. 10.1002/etc.3706.27935089
Brown PH, Welch RM, Cary EE. 1987. Nickel: A micronutrient essential for higher plants. Plant Physiol 85(3):801–803. 10.1104/pp.85.3.801.16665780
Bukhari S, Maqsood J, Baig MQ, . 2015. Comparison of characteristics - lead acid, nickel based, lead crystal and lithium based batteries. In: 17th UKSim-AMSS international conference on modelling and simulation (UKSim). Cambridge, UK: IEEE, 444–450. 10.1109/UKSim.2015.69.
Burrows D, Creswell S, Merrett JD. 1981. Nickel, hands and hip prostheses. Br J Dermatol 105(4):437–443. 10.1111/j.1365-2133.1981.tb00775.x.7295555
Burton GA, Jr., Hudson ML, Huntsman P, . 2019. Weight-of-evidence approach for assessing removal of metals from the water column for chronic environmental hazard classification. Environ Toxicol Chem 38(9):1839–1849. 10.1002/etc.4470.31099932
Buxton S, Garman E, Heim KE, . 2019. Concise review of nickel human health toxicology and ecotoxicology. Inorganics 7(7):89. https://www.mdpi.com/2304-6740/7/7/89.
Buxton S, Voges Y, Donath C, . 2020. Gene (HPRT) and chromosomal (MN) mutations of nickel metal powder in V79 Chinese hamster cells. Mutat Res 819–820:111688. 10.1016/j.mrfmmm.2020.111688.
Buxton S, Taylor MD, Weinberg JT, . 2021. A T-dependent antibody response evaluation in CD-1 mice after an acute whole-body inhalation exposure to nickel (II) chloride hexahydrate. J Immunotoxicol 18(1):144–153. 10.1080/1547691X.2021.1984618.34644513
Cabrera-Vique C, Mesias M, Bouzas PR. 2011. Nickel levels in convenience and fast foods: in vitro study of the dialyzable fraction. Sci Total Environ 409(8):1584–1588. 10.1016/j.scitotenv.2010.12.035.21295328
Cahill TA. 1989. Monitoring of atmospheric particles and ozone in Sequoia National Park: 1985-1987. Sacramento: California State Air Resources Board. PB90157512.
Cai X, Smirnova L, Ma Z, . 2021. Allergic contact dermatitis and associated allergic dermatoses: epidemiological, allergic, and immunological characteristics. Postepy Dermatol Alergol 38(6):1058–1064. 10.5114/ada.2021.104692.35126015
Cao Z, Fang Y, Lu Y, . 2016. Exposure to nickel oxide nanoparticles induces pulmonary inflammation through NLRP3 inflammasome activation in rats. Int J Nanomedicine 11:3331–3346. 10.2147/IJN.S106912.27524893
Capasso L, Camatini M, Gualtieri M. 2014. Nickel oxide nanoparticles induce inflammation and genotoxic effect in lung epithelial cells. Toxicol Lett 226(1):28–34. 10.1016/j.toxlet.2014.01.040.24503009
Caruso RV, O’Connor RJ, Stephens WE, . 2013. Toxic metal concentrations in cigarettes obtained from U.S. smokers in 2009: results from the International Tobacco Control (ITC) United States survey cohort. Int J Environ Res Public Health 11(1):202–217. 10.3390/ijerph110100202.24452255
Carvalho SM, Ziemer PL. 1982. Distribution and clearance of 63Ni administered as 63NiCl2 in the rat: intratracheal study. Arch Environ Contam Toxicol 11(2):245–248. 10.1007/bf01054903.7092328
Castorina A, Giunta S. 2014. Mucin 1 (MUC1) signalling contributes to increase the resistance to cell death in human bronchial epithelial cells exposed to nickel acetate. Biometals 27(6):1149–1158. 10.1007/s10534-014-9776-x.25053108
Cavallari JM, Eisen EA, Fang SC, . 2008. PM2.5 metal exposures and nocturnal heart rate variability: a panel study of boilermaker construction workers. Environ Health 7:36. 10.1186/1476-069x-7-36.18613971
Cavallo D, Ursini CL, Setini A, . 2003. Evaluation of oxidative damage and inhibition of DNA repair in an in vitro study of nickel exposure. Toxicol In Vitro 17(5–6):603–607. 10.1016/s0887-2333(03)00138-3.14599451
CDC. 2024. Urinary nickel (creatinine corrected) (2017 - 2018): CAS number 7440-02-0. Metals and metalloids. National Health and Nutrition Examination Survey (updated data tables March 2024). Centers for Disease Control and Prevention. https://www.cdc.gov/exposurereport/report/pdf/Metals%20and%20Metalloids%20NHANES-p.pdf. August 27, 2024.
CEMP. 2023. Monitoring scorecard and reports: Includes all prior monitoring periods: 2023: Q2. Community Environmental Monitoring Program. https://swpcemp.org/monitoring-results/. April 26, 2024.
Cempel M, Nikel G. 2006. Nickel: a review of its sources and environmental toxicology. Pol J Environ Stud 15:375–382.
Chan WH, Tang AJS, Chung DHS, . 1986. Concentration and deposition of trace metals in Ontario-1982. Water Air Soil Pollut 29(4):373–389. 10.1007/BF00283444.
Chang X, Zhu A, Liu F, . 2017. Role of NF-kappaB activation and Th1/Th2 imbalance in pulmonary toxicity induced by nano NiO. Environ Toxicol 32(4):1354–1362. 10.1002/tox.22329.27464988
Chashschin VP, Artunina GP, Norseth T. 1994. Congenital defects, abortion and other health effects in nickel refinery workers. Sci Total Environ 148(2–3):287–291. 10.1016/0048-9697(94)90405-7.8029704
Chen CY, Wang YF, Huang WR, . 2003. Nickel induces oxidative stress and genotoxicity in human lymphocytes. Toxicol Appl Pharmacol 189(3):153–159. 10.1016/s0041-008x(03)00086-3.12791300
Chen CY, Lin TK, Chang YC, . 2010. Nickel(II)-induced oxidative stress, apoptosis, G2/M arrest, and genotoxicity in normal rat kidney cells. J Toxicol Environ Health A 73(8):529–539. 10.1080/15287390903421250.20391133
Chen CS, Yuan TH, Shie RH, . 2017. Linking sources to early effects by profiling urine metabolome of residents living near oil refineries and coal-fired power plants. Environ Int 102:87–96. 10.1016/j.envint.2017.02.003.28238459
Cheng Z, Cheng N, Shi D, . 2019. The relationship between Nkx2.1 and DNA oxidative damage repair in nickel smelting workers: Jinchang cohort study. Int J Environ Res Public Health 16(1):120. 10.3390/ijerph16010120.30621196
Cherry N, Galarneau JM. 2021. Occupational dermatitis in welding: does nickel exposure account for higher rates in women? Analysis of a Canadian cohort. Ann Work Expo Health 65(2):183–195. 10.1093/annweh/wxaa049.32430497
Chin YE, Snow ET, Christie NT. 1994. The stimulatory effect of nickel chloride on DNA replication in human HeLa cells and Escherichia coli. Carcinogenesis 15(5):1013–1016. 10.1093/carcin/15.5.1013.8200062
Christensen OB, Möller H. 1975. External and internal exposure to the antigen in the hand eczema of nickel allergy. Contact Dermatitis 1(3):136–141. 10.1111/j.1600-0536.1975.tb05354.x.797515
Christensen OB, Lagesson V. 1981. Nickel concentration of blood and urine after oral administration. Ann Clin Lab Sci 11(2):119–125.7259086
Clary JJ. 1975. Nickel chloride-induced metabolic changes in the rat and guinea pig. Toxicol Appl Pharmacol 31:55–65.1129789
Clemens F, Landolph JR. 2003. Genotoxicity of samples of nickel refinery dust. Toxicol Sci 73(1):114–123. 10.1093/toxsci/kfg070.12657748
Cleveland Clinic. 2018. Nickel allergy. Cleveland Clinic. https://my.clevelandclinic.org/health/diseases/17842-nickel-allergy. February 14, 2023.
Clewell HJ. 1995. The application of physiologically based pharmacokinetic modeling in human health risk assessment of hazardous substances. Toxicol Lett 79(1–3):207–217. 10.1016/0378-4274(95)03372-r.7570658
Conway K, Costa M. 1989. Nonrandom chromosomal alterations in nickel-transformed Chinese hamster embryo cells. Cancer Res 49(21):6032. http://cancerres.aacrjournals.org/content/49/21/6032.abstract.2790817
Cornell RG. 1984. Mortality patterns around stainless-steel workers. IARC Sci Publ 53:65–71.
Cornell RG, Landis JR. 1984. Mortality patterns among nickel/chromium alloy foundry workers. IARC Sci Publ 53:87–93.
Correia L, Marrocos P, Montalván Olivares DM, . 2018. Bioaccumulation of nickel in tomato plants: risks to human health and agro-environmental impacts. Environ Monit Assess 190:317. 10.1007/s10661-018-6658-7.29717353
Coşgun S, Polat U, Kaya M, . 2023. Nickel sensitivity in patients with irritable bowel syndrome. Cureus 15(9):e45196. 10.7759/cureus.45196.37842435
Costa M, Mollenhauer HH. 1980. Carcinogenic activity of particulate nickel compounds is proportional to their cellular uptake. Science 209(4455):515. 10.1126/science.7394519.7394519
Costa M, Heck JD. 1982. Specific nickel compounds as carcinogens. Trends Pharmacol Sci 3:408–410. 10.1016/0165-6147(82)91207-X.
Costa M, Heck JD, Robison SH. 1982. Selective phagocytosis of crystalline metal sulfide particles and DNA strand breaks as a mechanism for the induction of cellular transformation. Cancer Res 42(7):2757–2763.7083166
Costello DM, Hammerschmidt CR, Burton GA. 2016. Nickel partitioning and toxicity in sediment during aging: Variation in toxicity related to stability of metal partitioning. Environ Sci Technol 50(20):11337–11345. 10.1021/acs.est.6b04033.27636118
Cox JE, Doll R, Scott WA, . 1981. Mortality of nickel workers: experience of men working with metallic nickel. Br J Ind Med 38(3):235–239. 10.1136/oem.38.3.235.7272235
Cragle DL, Hollis DR, Newport TH, . 1984. A retrospective cohort study among workers occupationally exposed to metallic nickel powder at the Oak Ridge Gaseous Diffusion Plant. IARC Sci Publ 53:57–64.
Cronin E, DiMichiel AD, Brown SS. 1980. Oral challenge in nickel-sensitive women with hand eczema. In: Brown SS, Sunderman FW, eds. Nickel toxicology. New York, NY: Academic Press, 149–152.
Cross DP, Ramachandran G, Wattenberg EV. 2001. Mixtures of nickel and cobalt chlorides induce synergistic cytotoxic effects: implications for inhalation exposure modeling. Ann Occup Hyg 45(5):409–418.11418091
Cuevas AK, Liberda EN, Gillespie PA, . 2010. Inhaled nickel nanoparticles alter vascular reactivity in C57BL/6 mice. Inhal Toxicol 22(Suppl 2):100–106. 10.3109/08958378.2010.521206.21142798
Dahdouh F, Attalah S, Djabar MR, . 2016. Effect of the joint supplementation of vitamin C and vitamin E on nickel heamatotoxicity and nephrotoxicity in male Swiss albino mice. Int J Pharm Pharm Sci 8(6):234–239.
Daldrup T, Haarhoff K, Szathmary SC. 1983. [Fatal nickel sulfate poisoning]. Beitr Gerichtl Med 41:141–144. (German)6639578
Danadevi K, Rozati R, Saleha Banu B, . 2004. In vivo genotoxic effect of nickel chloride in mice leukocytes using comet assay. Food Chem Toxicol 42(5):751–757. 10.1016/j.fct.2003.12.013.15046821
Danielsen TE, Langård S, Andersen A. 1996. Incidence of cancer among Norwegian boiler welders. Occup Environ Med 53(4):231–234. 10.1136/oem.53.4.231.8664959
Davidson CI. 1980. Dry deposition of nickel from the atmosphere. In: Nriagu JO, ed. Nickel in the environment. New York: John Wiley & Sons, 137–149.
De Carli RF, Chaves DDS, Cardozo TR, . 2018. Evaluation of the genotoxic properties of nickel oxide nanoparticles in vitro and in vivo. Mutat Res Genet Toxicol Environ Mutagen 836(Pt B):47–53. 10.1016/j.mrgentox.2018.06.003.
de Foy B, Smyth AM, Thompson SL, . 2012. Sources of nickel, vanadium and black carbon in aerosols in Milwaukee. Atmos Environ 59:294–301. 10.1016/j.atmosenv.2012.06.002.
Dede E, Tindall MJ, Cherrie JW, . 2018. Physiologically-based pharmacokinetic and toxicokinetic models for estimating human exposure to five toxic elements through oral ingestion. Environ Toxicol Pharmacol 57:104–114. 10.1016/j.etap.2017.12.003.29253785
Deknudt G, Léonard A. 1982. Mutagenicity tests with nickel salts in the male mouse. Toxicology 25(4):289–292. 10.1016/0300-483x(82)90106-8.7157405
DeKoven JG, Warshaw EM, Reeder MJ, . 2023. North American contact dermatitis group patch test results: 2019-2020. Dermatitis 34(2):90–104. 10.1089/derm.2022.29017.jdk.36917520
Demirjian YA, Westman TR, Joshi AM, . 1984. Land treatment of contaminated sludge with wastewater irrigation. J Water Pollut Control Fed 56(4):370–377.
Denays R, Kumba C, Lison D, . 2005. First epileptic seizure induced by occupational nickel poisoning. Epilepsia 46(6):961–962. 10.1111/j.1528-1167.2005.70004.x.15946340
Deng C, Lee HH, Xian H, . 1988. Chromosomal aberrations and sister chromatid exchanges of peripheral blood lymphocytes in Chinese electroplating workers: Effect of nickel and chromium. J Trace Elem Exp Med 1(1):57–62.
Dhir H, Agarwal K, Sharma A, . 1991. Modifying role of Phyllanthus emblica and ascorbic acid against nickel clastogenicity in mice. Cancer Lett 59(1):9–18. 10.1016/0304-3835(91)90129-6.1878862
Di Bucchianico S, Gliga AR, Åkerlund E, . 2018. Calcium-dependent cyto- and genotoxicity of nickel metal and nickel oxide nanoparticles in human lung cells. Part Fibre Toxicol 15(1):32. 10.1186/s12989-018-0268-y.30016969
Di Pietro A, Visalli G, Munaò F, . 2009. Oxidative damage in human epithelial alveolar cells exposed in vitro to oil fly ash transition metals. Int J Hyg Environ Health 212(2):196–208. 10.1016/j.ijheh.2008.05.005.18667355
Diamond GL, Goodrum PE, Felter SP, . 1998. Gastrointestinal absorption of metals. Drug Chem Toxicol 21(2):223–251. 10.3109/01480549809011649.9598302
Dieter MP, Jameson CW, Tucker AN, . 1988. Evaluation of tissue disposition, myelopoietic, and immunologic responses in mice after long-term exposure to nickel sulfate in the drinking water. J Toxicol Environ Health 24(3):357–372. 10.1080/15287398809531167.3398077
Ding AL, Hu H, Xu FP, . 2021. Pregnancy complications effect on the nickel content in maternal blood, placenta blood and umbilical cord blood during pregnancy. World J Clin Cases 9(28):8340–8348. 10.12998/wjcc.v9.i28.8340.34754843
DiPaolo JA, Casto BC. 1979. Quantitative studies of in vitro; morphological transformation of Syrian hamster cells by inorganic metal salts. Cancer Res 39(3):1008–1013. http://cancerres.aacrjournals.org/content/39/3/1008.abstract.427740
DOE. 2003. Nickel speciation of urban particulate matter. Pittsburgh, PA: U.S. Department of Energy. 2003-EERC-10-04. https://www.osti.gov/servlets/purl/823014. March 28, 2024.
DOE. 2018a. Table 3: Protective action criteria (PAC) rev. 29a based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. June 2018. U.S. Department of Energy. https://edms3.energy.gov/pac/docs/Revision_29A_Table3.pdf. July 6, 2022.
DOE. 2018b. Protective action criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29A, June 2018. U.S. Department of Energy. https://edms3.energy.gov/pac/. July 6, 2022.
DOE. 2023. Notice of final determination on 2023 DOE critical materials list. Department of Energy. Federal Register 88(149):51792–51798.
Doig LE, Liber K. 2007. Nickel speciation in the presence of different sources and fractions of dissolved organic matter. Ecotoxicol Environ Saf 66(2):169–177. 10.1016/j.ecoenv.2005.12.011.16497376
Dolovich J, Evans SL, Nieboer E. 1984. Occupational asthma from nickel sensitivity: I. Human serum albumin in the antigenic determinant. Br J Ind Med 41(1):51–55. 10.1136/oem.41.1.51.6197989
Domshlak MG, Elakov AL, Osipov AN. 2005. Genetic effects induced by nickel sulfate in germline and somatic cells of WR mice. Genetika 41(7):728–734.
Donat JR, Lao KA, Bruland KW. 1994. Speciation of dissolved copper and nickel in South San Francisco Bay: a multi-method approach. Anal Chim Acta 284:547–571.
Doreswamy K, Shrilatha B, Rajeshkumar T, . 2004. Nickel-induced oxidative stress in testis of mice: evidence of DNA damage and genotoxic effects. J Androl 25(6):996–1003. 10.1002/j.1939-4640.2004.tb03173.x.15477375
Dostal LA, Hopfer SM, Lin SM, . 1989. Effects of nickel chloride on lactating rats and their suckling pups, and the transfer of nickel through rat milk. Toxicol Appl Pharmacol 101(2):220–231. 10.1016/0041-008x(89)90271-8.2479122
Dotterud LK, Falk ES. 1994. Metal allergy in north Norwegian schoolchildren and its relationship with ear piercing and atopy. Contact Dermatitis 31(5):308–313. 10.1111/j.1600-0536.1994.tb02025.x.7867328
Dressler RL, Storm GL, Tzilkowski WM, . 1986. Heavy metals in cottontail rabbits on mined lands treated with sewage sludge. J Environ Qual 15(3):278–281.
Duan WX, He MD, Mao L, . 2015. NiO nanoparticles induce apoptosis through repressing SIRT1 in human bronchial epithelial cells. Toxicol Appl Pharmacol 286(2):80–91. 10.1016/j.taap.2015.03.024.25840356
Duce RA, Liss PS, Merrill JT, . 1991. The atmospheric input of trace species to the world ocean. Global Biogeochem Cycles 5(3):193–259. 10.1029/91GB01778.
Dugonik A, Dugonik B, Podgorelec V, . 2020. Associated positive patch test reactions to standard contact allergens: 10-year data from the Slovenian E-Surveillance System. Contact Dermatitis 85(1):17–25. 10.1111/cod.13767.
Duke JM. 1980a. Nickel in rocks and ores. In: Nriagu JO, ed. Nickel in the environment. John Wiley & Sons, 27–50.
Duke JM. 1980b. Production and uses of nickel. In: Nriagu JO, ed. Nickel in the environment. John Wiley & Sons, 52–65.
Dumala N, Mangalampalli B, Grover P. 2019a. In vitro genotoxicity assessment of nickel(II) oxide nanoparticles on lymphocytes of human peripheral blood. J Appl Toxicol 39(7):955–965. 10.1002/jat.3784.30763980
Dumala N, Mangalampalli B, Chinde S, . 2017. Genotoxicity study of nickel oxide nanoparticles in female Wistar rats after acute oral exposure. Mutagenesis 32(4):417–427. 10.1093/mutage/gex007.28387869
Dumala N, Mangalampalli B, Kalyan Kamal SS, . 2018. Biochemical alterations induced by nickel oxide nanoparticles in female Wistar albino rats after acute oral exposure. Biomarkers 23(1):33–43. 10.1080/1354750X.2017.1360943.28748734
Dumala N, Mangalampalli B, Kalyan Kamal SS, . 2019b. Repeated oral dose toxicity study of nickel oxide nanoparticles in Wistar rats: a histological and biochemical perspective. J Appl Toxicol 39(7):1012–1029. 10.1002/jat.3790.30843265
Dunnick JK, Benson JM, Hobbs CH, . 1988. Comparative toxicity of nickel oxide, nickel sulfate hexahydrate, and nickel subsulfide after 12 days of inhalation exposure to F344/N rats and B6C3F1 mice. Toxicology 50(2):145–156. 10.1016/0300-483x(88)90087-x.3388435
Dunnick JK, Elwell MR, Benson JM, . 1989. Lung toxicity after 13-week inhalation exposure to nickel oxide, nickel subsulfide, or nickel sulfate hexahydrate in F344/N rats and B6C3F1 mice. Fundam Appl Toxicol 12(3):584–594. 10.1016/0272-0590(89)90031-6.2731671
Dunnick JK, Elwell MR, Radovsky AE, . 1995. Comparative carcinogenic effects of nickel subsulfide, nickel oxide, or nickel sulfate hexahydrate chronic exposures in the lung. Cancer Res 55(22):5251–5256.7585584
Eagle Mine. 2023. 2022 Annual mining and reclamation report mine permit MP 01 2007. Eagle Mine. https://www.michigan.gov/egle/-/media/Project/Websites/egle/Documents/Reports/OGMD/2022-Eagle-Mine-Annual-Report.pdf. April 26, 2024.
Ebisu K, Bell ML. 2012. Airborne PM2.5 chemical components and low birth weight in the northeastern and mid-Atlantic regions of the United States. Environ Health Perspect 120(12):1746–1752. 10.1289/ehp.1104763.23008268
Ebling AM, Landing WM, Deming JW. 2017. Trace elements in the sea surface microlayer: rapid responses to changes in aerosol deposition. Elementa 5:42. 10.1525/elementa.237.
EC. 2008. Nickel (CAS No: 7440-02-0, EINECS No: 23-111-4): Risk assessment. European Union Risk Assessment Report. Denmark: European Commission.
Efremenko AY, Campbell JL, Jr., Dodd DE, . 2014. Time- and concentration-dependent genomic responses of the rat airway to inhaled nickel subsulfide. Toxicol Appl Pharmacol 279(3):441–454. 10.1016/j.taap.2014.06.007.24952340
Efremenko AY, Campbell JL, Dodd DE, . 2017a. Time- and concentration-dependent genomic responses of the rat airway to inhaled nickel sulfate. Environ Mol Mutagen 58(8):607–618. 10.1002/em.22139.28862355
Efremenko AY, Campbell JL, Dodd DE, . 2017b. Supplemental material: Time- and concentration-dependent genomic responses of the rat airway to inhaled nickel sulfate. Environ Mol Mutagen 58(8). 10.1002/em.22139.
EFSA. 2020. Update of the risk assessment of nickel in food and drinking water. European Food Safety Authority. EFSA J 18(11):e06268. 10.2903/j.efsa.2020.6268.33193868
Egedahl R, Carpenter M, Lundell D. 2001. Mortality experience among employees at a hydrometallurgical nickel refinery and fertiliser complex in Fort Saskatchewan, Alberta (1954-95). Occup Environ Med 58(11):711–715. 10.1136/oem.58.11.711.11600726
El Safty AMK, Samir AM, Mekkawy MK, . 2018. Genotoxic effects due to exposure to chromium and nickel among electroplating workers. Int J Toxicol 37(3):234–240. 10.1177/1091581818764084.29554825
El-Habit OH, Abdel Moneim AE. 2014. Testing the genotoxicity, cytotoxicity, and oxidative stress of cadmium and nickel and their additive effect in male mice. Biol Trace Elem Res 159(1–3):364–372. 10.1007/s12011-014-0016-6.24859853
Elias Z, Mur JM, Pierre F, . 1989. Chromosome aberrations in peripheral blood lymphocytes of welders and characterization of their exposure by biological samples analysis. J Occup Med 31(5):477–483.2715858
El-Masri HA, Mumtaz MM, Yushak ML. 2004. Application of physiologically-based pharmacokinetic modeling to investigate the toxicological interaction between chlorpyrifos and parathion in the rat. Environ Toxicol Pharmacol 16(1–2):57–71. 10.1016/j.etap.2003.10.002.21782694
El-Sekily NMA, Ayad AEAE, El-Homosany NM, . 2020. Skeletal congenital abnormalities induced by nickel chloride hexahydrate on Balb/C albino mice embryos during organogenetic period. Toxicol Environ Health Sci 12(2):157–167. 10.1007/s13530-020-00047-5.
Emmett EA, Risby TH, Jiang L, . 1988. Allergic contact dermatitis to nickel: bioavailability from consumer products and provocation threshold. J Am Acad Dermatol 19(2 Pt 1):314–322. 10.1016/s0190-9622(88)70178-4.3170796
English JC, Parker RD, Sharma RP, . 1981. Toxicokinetics of nickel in rats after intratracheal administration of a soluble and insoluble form. Am Ind Hyg Assoc J 42(7):486–492. 10.1080/15298668191420125.7246426
Enterline PE, Marsh GM. 1982. Mortality among workers in a nickel refinery and alloy manufacturing plant in West Virginia. J Natl Cancer Inst 68(6):925–933. 10.1093/jnci/68.6.925.6953273
EPA. 1981. Data base for influent heavy metals in publicly owned treatment works. Cincinnati, OH: U.S. Environmental Protection Agency. EPA500S281220.
EPA. 1983. Fetotoxic effects of nickel in drinking water in mice. U.S. Environmental Protection Agency. EPA600183007. PB83225383. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P100R6N9.txt. April 9, 2024.
EPA. 1988a. Two-generation reproduction and fertility study of nickel chloride administered to CD rats in the drinking water: Fertility and reproductive performance of the P0 generation. Final study report (II of III). Research Triangle Park, NC: U.S. Environmental Protection Agency.
EPA. 1988b. Two-generation reproduction and fertility study of nickel chloride administered to CD rats in the drinking water: Fertility and reproductive performance of the F1 generation. Final study report (III of III). Research Triangle Park, NC: U.S. Environmental Protection Agency.
EPA. 1994. Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry. Washington DC: U.S. Environmental Protection Agency. EPA600890066F.
EPA. 1999. Compendium of methods for the determination of inorganic compounds in ambient air. Compendium Method IO-3.3. Determination of metals in ambient particulate matter using x-ray fluorescence (XRF) spectroscopy. Cincinnati, OH: U.S. Environmental Protection Agency. EPA625R96010a.
EPA. 2000. National air pollutant emission trends, 1900-1998. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA454R00002.
EPA. 2003. Title 40 - Protection of environment. Subchapter N - Effluent guidelines & standards. Section 401.15 Toxic pollutants. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 401.15.
EPA. 2007. Fundamentals of urban runoff management: Technical and institutional issues. U.S. Environmental Protection Agency. North American Lake Management Society. 2.15-14.107. https://yosemite.epa.gov/oa/eab_web_docket.nsf/Attachments%20By%20ParentFilingId/77FFADF0D8FEB2E485257C62005376F2/$FILE/Att%2013%20%20Fundamentals%20of%20Urban%20Runoff.pdf. May 22, 2024.
EPA. 2009. National primary drinking water regulations. U.S. Environmental Protection Agency. EPA816F09004. https://www.epa.gov/sites/default/files/2016-06/documents/npwdr_complete_table.pdf. May 27, 2023.
EPA. 2010. Title 40 - Protection of environment. Subchapter N - Effluent guidelines & standards. Section 401.12 Law authorizing establishment of effluent limitations guidelines for existing sources, standards of performance for new sources and pretreatment standards of new and existing sources. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 401.12.
EPA. 2018a. 2018 Edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency. EPA822F18001. https://www.epa.gov/system/files/documents/2022-01/dwtable2018.pdf. June 15, 2022.
EPA. 2018b. Compiled AEGL values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2018-08/documents/compiled_aegls_update_27jul2018.pdf. April 12, 2020.
EPA. 2018c. About acute exposure guideline levels (AEGLs). U.S. Environmental Protection Agency. https://www.epa.gov/aegl/about-acute-exposure-guideline-levels-aegls. July 26, 2018.
EPA. 2020a. National emission inventory (NEI) data. U.S. Environmental Protection Agency. https://www.epa.gov/air-emissions-inventories/2020-national-emissions-inventory-nei-data. April 29, 2024.
EPA. 2020b. Fish bioconcentration data requirement: guidance for selection of number of treatment concentrations. U.S. Environmental Protection Agency. EPA705G20203708. https://www.epa.gov/sites/default/files/2020-07/documents/bcf-study-july-15-2020.pdf. July 13, 2020.
EPA. 2022a. Toxic chemical release inventory reporting forms and instructions: Revised 2021 version. U.S. Environmental Protection Agency. EPA740B22002. https://ordspub.epa.gov/ords/guideme_ext/guideme_ext/guideme/file/ry_2021_rfi.pdf. August 22, 2023.
EPA. 2022b. Metals cooperative research and development agreement (CRADA) phase I report: Development of an overarching bioavailability modeling approach to support US EPA’s aquatic life water quality criteria for metals. U.S. Environmental Protection Agency. EPA822R22001. https://www.epa.gov/wqc/metals-crada-phase-1-report. May 22, 2024.
EPA. 2024. Annual summary data: Nickel. Air quality system (AQS): Concentration by monitor. U.S. Environmental Protection Agency. https://www.epa.gov/aqs. April 24, 2024.
Eun HC, Marks R. 1990. Dose-response relationships for topically applied antigens. Br J Dermatol 122(4):491–499. 10.1111/j.1365-2133.1990.tb14726.x.2186775
Evans JE, Miller ML, Andringa A, . 1995. Behavioral, histological, and neurochemical effects of nickel (II) on the rat olfactory system. Toxicol Appl Pharmacol 130(2):209–220. 10.1006/taap.1995.1026.7871534
FDA. 2020a. Metals used in medical devices. U.S. Food and Drug Administration.
FDA. 2020b. Elemental analysis manual for food and related products. 4.7 Inductively coupled plasma-mass spectrometric determination of arsenic, cadmium, chromium, lead, mercury, and other elements in food using microwave assisted digestion. U.S. Food and Drug Administration.
FDA. 2022. Beverages. Subpart B - Requirements for specific standardized beverages. Bottled water. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 165.110. https://www.govinfo.gov/content/pkg/CFR-2022-title21-vol2/pdf/CFR-2022-title21-vol2-sec165-110.pdf. January 4, 2023.
FDA. 2023a. Direct food substances affirmed as generally recognized as safe. Subpart B - Listing of specific substances affirmed as GRAS. Nickel. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 184.1537. https://www.govinfo.gov/content/pkg/CFR-2023-title21-vol3/pdf/CFR-2023-title21-vol3-sec184-1537.pdf. March 4, 2024.
FDA. 2023b. Indirect food additives: Paper and paperboard components. Subpart B - Substances for use only as components of paper and paperboard. Components of paper and paperboard in contact with dry food. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 176.180. https://www.govinfo.gov/content/pkg/CFR-2023-title21-vol3/pdf/CFR-2023-title21-vol3-sec176-180.pdf. March 4, 2024.
FDA. 2023c. Total diet study. Elements results summary statistics. Market baskets 2018 through 2020. College Park, MD: U.S. Food and Drug Administration. https://www.fda.gov/food/fda-total-diet-study-tds/fda-total-diet-study-tds-results. May 22, 2024.
Feng X, Melander AP, Klaue B. 2000. Contribution of municipal waste incineration to trace metal deposition on the vicinity. Water Air Soil Pollut 119(1):295–316. 10.1023/A:1005211320637.
Filon FL, D’Agostin F, Crosera M, . 2009. In vitro absorption of metal powders through intact and damaged human skin. Toxicol In Vitro 23(4):574–579. 10.1016/j.tiv.2009.01.015.19490843
Fischer T, Rystedt I. 1983. Cobalt allergy in hard metal workers. Contact Dermatitis 9(2):115–121. 10.1111/j.1600-0536.1983.tb04316.x.6221862
Fischer LA, Menne T, Johansen JD. 2005. Experimental nickel elicitation thresholds--a review focusing on occluded nickel exposure. Contact Dermatitis 52(2):57–64. 10.1111/j.0105-1873.2005.00523.x.15725281
Fischer LA, Menne T, Johansen JD. 2007. Dose per unit area - a study of elicitation of nickel allergy. Contact Dermatitis 56(5):255–261. 10.1111/j.1600-0536.2007.01096.x.17441846
Fisher GL, Chrisp CE, McNeill DA. 1986. Lifetime effects of intratracheally instilled nickel subsulfide on B6C3F1 mice. Environ Res 40(2):313–320. 10.1016/S0013-9351(86)80106-2.3732203
Fishwick D, Bradshaw L, Slater T, . 2004. Respiratory symptoms and lung function change in welders: are they associated with workplace exposures? N Z Med J 117(1193):U872.15133522
Fletcher GG, Rossetto FE, Turnbull JD, . 1994. Toxicity, uptake, and mutagenicity of particulate and soluble nickel compounds. Environ Health Perspect 102(Suppl 3):69–79. 10.1289/ehp.94102s369.
Flint GN, Packirisamy S. 1995. Systemic nickel: the contribution made by stainless-steel cooking utensils. Contact Dermatitis 32(4):218–224. 10.1111/j.1600-0536.1995.tb00672.x.7600777
Font A, de Hoogh K, Leal-Sanchez M, . 2015. Using metal ratios to detect emissions from municipal waste incinerators in ambient air pollution data. Atmos Environ 113:177–186. 10.1016/j.atmosenv.2015.05.002.
Francis AJ, Dodge CJ. 1990. Anaerobic microbial remobilization of toxic metals coprecipitated with iron oxide. Environ Sci Technol 24:373–378.
Frankild S, Andersen KE, Nielsen GD. 1995. Effect of sodium lauryl sulfate (SLS) on in vitro percutaneous penetration of water, hydrocortisone and nickel. Contact Dermatitis 32(6):338–345. 10.1111/j.1600-0536.1995.tb00622.x.7554880
Freitas M, Gomes A, Porto G, . 2010. Nickel induces oxidative burst, NF-jB activation and interleukin-8production in human neutrophils. J Biol Inorg Chem 15:1275–1283. 10.1007/s00775-010-0685-3.20632048
Frenkel K, Karkoszka J, Cohen B, . 1994. Occupational exposures to Cd, Ni, and Cr modulate titers of antioxidized DNA base autoantibodies. Environ Health Perspect 102(Suppl 3):221–225. 10.1289/ehp.94102s3221.
Fresquez MR, Pappas RS, Watson CH. 2013. Establishment of toxic metal reference range in tobacco from US cigarettes. J Anal Toxicol 37(5):298–304. 10.1093/jat/bkt021.23548667
Fuichtjohann L, Jakubowski N, Gladtke D, . 2001. Speciation of nickel in airborne particulate matter by means of sequential extraction in a micro flow system and determination by graphite furnace atomic absorption spectrometry and inductively coupled plasma mass spectrometry. J Environ Monit 3(6):681–687. 10.1039/b107010j.11785645
Fullerton A, Andersen JR, Hoelgaard A, . 1986. Permeation of nickel salts through human skin in vitro. Contact Dermatitis 15(3):173–177. 10.1111/j.1600-0536.1986.tb01320.x.3780218
Funakoshi T, Inoue T, Shimada H, . 1997. The mechanisms of nickel uptake by rat primary hepatocyte cultures: role of calcium channels. Toxicology 124(1):21–26. 10.1016/s0300-483x(97)00131-5.9392452
Galbreath KC, Zygarlicke CJ. 2004. Formation and chemical speciation of arsenic-, chromium-, and nickel-bearing coal combustion PM2.5. Fuel Process Technol 85(6):701–726. 10.1016/j.fuproc.2003.11.015.
Gawkrodger DJ, Cook SW, Fell GS, . 1986. Nickel dermatitis: the reaction to oral nickel challenge. Br J Dermatol 115(1):33–38. 10.1111/j.1365-2133.1986.tb06217.x.
Genchi G, Carocci A, Lauria G, . 2020. Nickel: Human health and environmental toxicology. Int J Environ Res Public Health 17(3):679. 10.3390/ijerph17030679.31973020
Gérin M, Fletcher AC, Gray C, . 1993. Development and use of a welding process exposure matrix in a historical prospective study of lung cancer risk in European welders. Int J Epidemiol 22(Suppl 2):S22–28. 10.1093/ije/22.supplement_2.s22.8132388
Gerritse RG, Vriesema R, Dalenberg JW, . 1982. Effect of sewage sludge on trace element mobility in soils. J Environ Qual 11(3):359–364.
Ghezzi I, Baldasseroni A, Sesana G, . 1989. Behaviour of urinary nickel in low-level occupational exposure. Med Lav 80(3):244–250.2796834
Giusti L, Yang YL, Hewitt CN, . 1993. The solubility and partitioning of atmospherically derived trace metals in artificial and natural waters: A review. Atmos Environ 27(10):1567–1578. 10.1016/0960-1686(93)90156-S.
Gladney ES, Gordon GE, Zoller WH. 1978. Coal combustion: Source of toxic elements in urban air? J Environ Sci Health A 13(7):481–491. 10.1080/10934527809374827.
Gliga AR, Di Bucchianico S, Åkerlund E, . 2020. Transcriptome profiling and toxicity following long-term, low dose exposure of human lung cells to Ni and NiO nanoparticles-comparison with NiCl(2). Nanomaterials (Basel) 10(4):649. 10.3390/nano10040649.32244462
Godbold JH, Jr., Tompkins EA. 1979. A long-term mortality study of workers occupationally exposed to metallic nickel at the Oak Ridge Gaseous Diffusion Plant. J Occup Med 21(12):799–806.556270
Goebeler M, Meinardus-Hager G, Roth J, . 1993. Nickel chloride and cobalt chloride, two common contact sensitizers, directly induce expression of intercellular adhesion molecule-1 (ICAM-1), vascular cell adhesion molecule-1 (VCAM-1), and endothelial leukocyte adhesion molecule (ELAM-1) by endothelial cells. J Invest Dermatol 100(6):759–765. 10.1111/1523-1747.ep12476328.7684425
Golomb D, Ryan D, Eby N, . 1997. Atmospheric deposition of toxics onto Massachusetts Bay—I. Metals. Atmos Environ 31(9):1349–1359. 10.1016/S1352-2310(96)00276-2.
Goniewicz ML, Knysak J, Gawron M, . 2014. Levels of selected carcinogens and toxicants in vapour from electronic cigarettes. Tob Control 23(2):133–139. 10.1136/tobaccocontrol-2012-050859.23467656
Goodman JE, Prueitt RL, Thakali S, . 2011. The nickel ion bioavailability model of the carcinogenic potential of nickel-containing substances in the lung. Crit Rev Toxicol 41(2):142–174. 10.3109/10408444.2010.531460.21158697
Goutet M, Ban M, Binet S. 2000. Effects of nickel sulfate on pulmonary natural immunity in Wistar rats. Toxicology 145(1):15–26. 10.1016/s0300-483x(99)00216-4.10771128
Graham JA, Miller FJ, Daniels MJ, . 1978. Influence of cadmium, nickel, and chromium on primary immunity in mice. Environ Res 16(1):77–87. 10.1016/0013-9351(78)90144-5.28223
Grandjean P. 1984. Human exposure to nickel. IARC Sci Publ (53):469–485.6241927
Grashow R, Zhang J, Fang SC, . 2015. Toenail metal concentration as a biomarker of occupational welding fume exposure. J Occup Environ Hyg 11(6):397–405. 10.1080/15459624.2013.875182.
Gray LE, Jr., Kavlok RJ, Ostby J, . 1986. An evaluation of figure-eight maze activity and general behavioral development following prenatal exposure to forty chemicals: effects of cytosine arabinoside, dinocap, nitrofen, and vitamin A. Neurotoxicology 7(2):449–462.3537858
Gray N, Halstead M, Gonzalez-Jimenez N, . 2019. Analysis of toxic metals in liquid from electronic cigarettes. Int J Environ Res Public Health 16(22):4450. 10.3390/ijerph16224450.31766137
Green MHL, Muriel WJ, Bridges BA. 1976. Use of a simplified fluctuation test to detect low levels of mutagens. Mutat Res 38(1):33–42. 10.1016/0165-1161(76)90077-7.768758
Grimsrud TK, Peto J. 2006. Persisting risk of nickel related lung cancer and nasal cancer among Clydach refiners. Occup Environ Med 63(5):365–366. 10.1136/oem.2005.026336.16621856
Grimsrud TK, Berge SR, Resmann F, . 2000. Assessment of historical exposures in a nickel refinery in Norway. Scand J Work Environ Health 26(4):338–345. 10.5271/sjweh.551.10994800
Grimsrud TK, Berge SR, Haldorsen T, . 2002. Exposure to different forms of nickel and risk of lung cancer. Am J Epidemiol 156(12):1123–1132. 10.1093/aje/kwf165.12480657
Grimsrud TK, Berge SR, Martinsen JI, . 2003. Lung cancer incidence among Norwegian nickel-refinery workers 1953-2000. J Environ Monit 5(2):190–197. 10.1039/b211722n.12729252
Grimsrud TK, Berge SR, Haldorsen T, . 2005. Can lung cancer risk among nickel refinery workers be explained by occupational exposures other than nickel? Epidemiology 16(2):146–154. 10.1097/01.ede.0000152902.48916.d7.15703528
Guarneri F, Costa C, Cannavo SP, . 2017. Release of nickel and chromium in common foods during cooking in 18/10 (grade 316) stainless steel pots. Contact Dermatitis 76(1):40–48. 10.1111/cod.12692.27804135
Guillamet E, Creus A, Farina M, . 2008. DNA-damage induction by eight metal compounds in TK6 human lymphoblastoid cells: results obtained with the alkaline Comet assay. Mutat Res 654(1):22–28. 10.1016/j.mrgentox.2008.04.005.18534899
Habre R, Coull B, Moshier E, . 2014. Sources of indoor air pollution in New York City residences of asthmatic children. J Expo Sci Environ Epidemiol 24(3):269–278. 10.1038/jes.2013.74.24169876
Hack CE, Covington TR, Lawrence G, . 2007. A pharmacokinetic model of the intracellular dosimetry of inhaled nickel. J Toxicol Environ Health A 70(5):445–464. 10.1080/15287390600870726.17454569
Hafez HS, Selim EM, Kamel Eid FH, . 2011. Cytotoxicity, genotoxicity, and metal release in patients with fixed orthodontic appliances: A longitudinal in-vivo study. Am J Orthod Dentofacial Orthop 140(3):298–308. 10.1016/j.ajodo.2010.05.025.21889074
Hale B, Gopalapillai Y, Pellegrino A, . 2017. Validation of site-specific soil Ni toxicity thresholds with independent ecotoxicity and biogeochemistry data for elevated soil Ni. Environ Pollut 231(Pt 1):165–172. 10.1016/j.envpol.2017.08.008.28800485
Haley PJ, Shopp GM, Benson JM, . 1990. The immunotoxicity of three nickel compounds following 13-week inhalation exposure in the mouse. Toxicol Sci 15(3):476–487. 10.1093/toxsci/15.3.476. 2/17/2021.
Halim M, Conte P, Piccolo A. 2003. Potential availability of heavy metals to phytoextraction from contaminated soils induced by exogenous humic substances. Chemosphere 52:265–275.12729711
Hamann D, Thyssen JP, Hamann CR, . 2015. Jewellery: alloy composition and release of nickel, cobalt and lead assessed with the EU synthetic sweat method. Contact Dermatitis 73(4):231–238. 10.1111/cod.12434.26230312
Hamilton-Koch W, Snyder RD, Lavelle JM. 1986. Metal-induced DNA damage and repair in human diploid fibroblasts and Chinese hamster ovary cells. Chem Biol Interact 59(1):17–28. 10.1016/s0009-2797(86)80052-7.3757145
Han I, Richner D, An Han H, . 2020. Evaluation of metal aerosols in four communities adjacent to metal recyclers in Houston, Texas, USA. J Air Waste Manag Assoc 70(5):568–579. 10.1080/10962247.2020.1755385.32315255
Hansen LD, Fisher GL. 1980. Elemental distribution in coal fly ash particles. Environ Sci Technol 14(9):1111–1117. 10.1021/es60169a015.
Hansen K, Stern RM. 1984. Toxicity and transformation potency of nickel compounds in BHK cells in vitro. IARC Sci Publ 53:193–200.
Hansen KS, Lauritsen JM, Skytthe A. 1996. Cancer incidence among mild steel and stainless steel welders and other metal workers. Am J Ind Med 30(4):373–382. 10.1002/(sici)1097-0274(199610)30:4<373::Aid-ajim1>3.0.Co;2-x.8892541
Harasim P, Filipek T. 2015. Nickel in the environment. J Elem 20(2):525–534. 10.5601/jelem.2014.19.3.651.
Hargitai L. 1989. The role of humus status of soils in binding toxic elements and compounds. Sci Total Environ 81/82:634–651.
Hariyani N, Berniyanti T, Setyowati D. 2015. Effects of occupational environmental controls on the level of Co, Ni and Cr among dental technicians. Int J Environ Sci Dev 6(9):643–647.
Haro RT, Furst A, Falk HL. 1968. Studies on the acute toxicity of nickelocene. Proc West Pharmacol Soc 11:39–42.5734480
Hartwig A, Beyersmann D. 1989. Enhancement of UV-induced mutagenesis and sister-chromatid exchanges by nickel ions in V79 cells: evidence for inhibition of DNA repair. Mutat Res 217(1):65–73. 10.1016/0921-8777(89)90037-2.2911267
Hassler E, Lind B, Nilsson B, . 1983. Urinary and fecal elimination of nickel in relation to air-borne nickel in a battery factory. Ann Clin Lab Sci 13(3):217–224.6870185
Haynes WM, Lide DR, Bruno TJ, eds.,. 2015. [Nickel and compounds]. In: CRC handbook of chemistry and physics: A ready-reference book of chemical and physical data. 95th ed. Boca Raton, FL: CRC Press, 3-408,3-409
He MD, Xu SC, Zhang X, . 2013. Disturbance of aerobic metabolism accompanies neurobehavioral changes induced by nickel in mice. Neurotoxicology 38:9–16. 10.1016/j.neuro.2013.05.011.23727075
Hedberg Y, Mazinanian N, Wallinder IO. 2014. Compliance tests of stainless steel as a food contact material using the CoE test guideline. Stockholm, Sweden: Worldsteel Association. KTH Royal Institute of Technology. 10.13140/RG.2.2.36150.42564.
Heim KE, Bates HK, Rush RE, . 2007. Oral carcinogenicity study with nickel sulfate hexahydrate in Fischer 344 rats. Toxicol Appl Pharmacol 224(2):126–137. 10.1016/j.taap.2007.06.024.17692353
Hendel RC, Sunderman FW, Jr. 1972. Species variations in the proportions of ultrafiltrable and protein-bound serum nickel. Res Commun Chem Pathol Pharmacol 4(1):141–146.4671994
Henderson RG, Durando J, Oller AR, . 2012. Acute oral toxicity of nickel compounds. Regul Toxicol Pharmacol 62(3):425–432. 10.1016/j.yrtph.2012.02.002.22333739
Hess CA, Olmedo P, Navas-Acien A, . 2017. E-cigarettes as a source of toxic and potentially carcinogenic metals. Environ Res 152:221–225. 10.1016/j.envres.2016.09.026.27810679
Hindsén M, Bruze M, Christensen OB. 1997. The significance of previous allergic contact dermatitis for elicitation of delayed hypersensitivity to nickel. Contact Dermatitis 37(3):101–106. 10.1111/j.1600-0536.1997.tb00312.x.9330814
Hindsén M, Bruze M, Christensen OB. 2001. Flare-up reactions after oral challenge with nickel in relation to challenge dose and intensity and time of previous patch test reactions. J Am Acad Dermatol 44(4):616–623. 10.1067/mjd.2001.110873.11260535
Hirano S, Shimada T, Osugi J, . 1994. Pulmonary clearance and inflammatory potency of intratracheally instilled or acutely inhaled nickel sulfate in rats. Arch Toxicol 68(9):548–554. 10.1007/s002040050112.7998820
Ho W, Furst A. 1973. Nickel excretion by rats following a single treatment. Proc West Pharmacol Soc 16:245–248.
Holmes A, The T, Thompson K, . 2013. Chronic exposure to particulate nickel induces neoplastic transformation in human lung epithelial cells. Toxics 1(1):46–59. 10.3390/toxics1010046.
Horak E, Sunderman FW, Jr., Sarkar B. 1976. Comparisons of antidotal efficacy of chelating drugs upon acute toxicity of Ni(II) in rats. Res Commun Chem Pathol Pharmacol 14(1):153–165.180577
Horie A, Tanaka I, Haratake J, . 1985. Electron microscopy of pulmonary lesions including carcinoma, induced by inhalation exposure of rats to nickel oxide aerosol. In: Brown SS, Sunderman FW, eds. Progress in nickel toxicology. Proceedings of the 3rd international congress on nickel metabolism and toxicology. Oxford, UK: Blackwell, 41–44.
Horie M, Fukui H, Endoh S, . 2012. Comparison of acute oxidative stress on rat lung induced by nano and fine-scale, soluble and insoluble metal oxide particles: NiO and TiO2. Inhal Toxicol 24(7):391–400. 10.3109/08958378.2012.682321.22642288
Hostýnek JJ, Dreher F, Nakada T, . 2001a. Human stratum corneum adsorption of nickel salts. Investigation of depth profiles by tape stripping in vivo. Acta Derm Venereol 81(Suppl 212):11–18. 10.1080/000155501753279587.
Hostýnek JJ, Dreher F, Pelosi A, . 2001b. Human stratum corneum penetration by nickel. In vivo study of depth distribution after occlusive application of the metal as powder. Acta Derm Venereol 81(Suppl 212):5–10. 10.1080/000155501753279578.
Hsie AW, Johnson NP, Couch DB, . 1979. Quantitative mammalian cell mutagenesis and a preliminary study of the mutagenic potential of metallic compounds. In: Kharasch N, ed. Trace metals in health and disease. New York, NY: Raven Press, 55–69.
Hsieh TH, Yu CP, Oberdörster G. 1999a. A dosimetry model of nickel compounds in the rat lung. Inhal Toxicol 11(3):229–248. 10.1080/089583799197168.10380168
Hsieh TH, Yu CP, Oberdörster G. 1999b. Modeling of deposition and clearance of inhaled Ni compounds in the human lung. Regul Toxicol Pharmacol 30(1):18–28. 10.1006/rtph.1999.1313.10464043
Hsieh T, Yu CP, Oberdorster G. 1999c. Deposition and clearance models of Ni compounds in the mouse lung and comparisons with the rat models. Aerosol Sci Technol 31:358–372.
Hsieh SH, Chiu TP, Huang WS, . 2019. Cadmium (Cd) and nickel (Ni) distribution on size-fractioned soil humic substance (SHS). Int J Environ Res Public Health 16(18):3398. 10.3390/ijerph16183398.31540224
Hsu SI, Ito K, Kendall M, . 2012. Factors affecting personal exposure to thoracic and fine particles and their components. J Expo Sci Environ Epidemiol 22(5):439–447. 10.1038/jes.2012.23.22760443
Hu W, Yu Z, Gao X, . 2020. Study on the damage of sperm induced by nickel nanoparticle exposure. Environ Geochem Health 42(6):1715–1724. 10.1007/s10653-019-00364-w.31278585
Hueper WC. 1958. Experimental studies in metal cancerigenesis. IX. Pulmonary lesions in guinea pigs and rats exposed to prolonged inhalation of powdered metallic nickel. AMA Arch Pathol 65(6):600–607.13532113
Huggins FE, Galbreath KC, Eylands KE, . 2011. Determination of nickel species in stack emissions from eight residual oil-fired utility steam-generating units. Environ Sci Technol 45(14):6188–6195. 10.1021/es200823a.21711052
Hughson GW, Galea KS, Heim KE. 2010. Characterization and assessment of dermal and inhalable nickel exposures in nickel production and primary user industries. Ann Occup Hyg 54(1):8–22. 10.1093/annhyg/mep068.19759172
Huntsman P, Beaudoin R, Rader KJ, . 2019. Method development for determining the removal of metals from the water column under transformation/dissolution conditions for chronic hazard classification. Environ Toxicol Chem 38(9):2032–2042. 10.1002/etc.4471.31099935
Hussain MF, Naeem Ashiq M, Gulsher M, . 2020. Exposure to variable doses of nickel oxide nanoparticles disturbs serum biochemical parameters and oxidative stress biomarkers from vital organs of albino mice in a sex-specific manner. Biomarkers 25(8):719–724. 10.1080/1354750X.2020.1841829.33095078
IARC. 1990. Nickel and nickel compounds. IARC monographs on the evaluation of carcinogenic risks to humans. Volume 49. Lyon, France: International Agency for Research on Cancer, World Health Organization. 257–445. https://publications.iarc.fr/67. June 23, 2003.
IARC. 2012. Nickel and nickel compounds. IARC Monographs on the evaluation of carcinogenic risks to humans. Volume 100C. Arsenic, metals, fibres, and dusts. Lyon, France: International Agency for Research on Cancer. 169–218. https://publications.iarc.fr/120. March 4, 2024.
IARC. 2018. IARC monographs on the evaluation of carcinogenic risks to humans. Volume 118: Welding, molybdenum trioxide, and indium tin oxide. Lyon, France: International Agency for Research on Cancer. https://publications.iarc.fr/67. March 4, 2024.
IARC. 2021. Agents classifed by the IARC monographs, volumes 1-129. International Agency for Research on Cancer, World Health Organization. https://monographs.iarc.who.int/list-of-classifications. March 29, 2021.
Iarmarcovai G, Sari-Minodier I, Chaspoul F, . 2005. Risk assessment of welders using analysis of eight metals by ICP-MS in blood and urine and DNA damage evaluation by the comet and micronucleus assays; influence of XRCC1 and XRCC3 polymorphisms. Mutagenesis 20(6):425–432. 10.1093/mutage/gei058.16234265
ICRP. 1994. Human respiratory tract model for radiological protection. Pergamon Press. International Commission on Radiological Protection. ICRP Publication 66. https://journals.sagepub.com/doi/pdf/10.1177/ANIB_24_1-3. December 6, 2023.
IEA. 2023. Global EV outlook: catching up with climate ambitions. International Energy Agency. https://www.iea.org/reports/global-ev-outlook-2023. May 22, 2024.
Ilbäck NG, Fohlman J, Friman G. 1992. A common viral infection can change nickel target organ distribution. Toxicol Appl Pharmacol 114(1):166–170. 10.1016/0041-008x(92)90110-e.1585370
Ilbäck NG, Fohlman J, Friman G. 1994. Changed distribution and immune effects of nickel augment viral-induced inflammatory heart lesions in mice. Toxicology 91(2):203–219. 10.1016/0300-483x(93)02776-d.8059443
Institute of Medicine. 2001. Arsenic, boron, nickel, silicon, and vanadium. In: Dietary reference intakes for vitamin A, vitamin K, arsenic, boron, chromium, copper, iodine, iron, manganese, molybdenum, nickel, silicon, vanadium, and zinc. Washington, DC: National Academies Press, 502–553. https://www.ncbi.nlm.nih.gov/books/NBK222322/.
International Committee on Nickel Carcinogenesis in Man. 1990. Report of the International Committee on Nickel Carcinogenesis in Man. Scand J Work Environ Health 16(1 Spec No):1–82. 10.5271/sjweh.1813.2185539
IRIS. 1987a. Chemical assessment summary. Nickel refinery dust; no CASRN. Integrated risk information system (IRIS). U.S. Environmental Protection Agency, National Center for Environmental Assessment. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0272_summary.pdf.
IRIS. 1987b. Chemical assessment summary. Nickel subsulfide; CASRN 12035-72-2. Integrated risk information system (IRIS). U.S. Environmental Protection Agency, National Center for Environmental Assessment. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0273_summary.pdf.
IRIS. 1994. Chemical assessment summary. Nickel, soluble salts; CASRN Various. Integrated risk information system (IRIS). U.S. Environmental Protection Agency, National Center for Environmental Assessment. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0271_summary.pdf. March 21, 2024.
IRIS. 2002. Chemical assessment summary. Nickel subsulfide; CASRN 12035-72-2. Integrated risk information system (IRIS). U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0273_summary.pdf. March 4, 2024.
IRIS. 2006. Chemical assessment summary. Nickel refinery dust; no CASRN. Integrated risk information system (IRIS). U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0272_summary.pdf. March 4, 2024.
Isaksson M, Hagvall L, Glas B, . 2021. Suitable test concentration of cobalt and concomitant reactivity to nickel and chromium: A multicentre study from the Swedish Contact Dermatitis Research Group. Contact Dermatitis 84(3):153–158. 10.1111/cod.13710.32996589
Ishimatsu S, Kawamoto T, Matsuno K, . 1995. Distribution of various nickel compounds in rat organs after oral administration. Biol Trace Elem Res 49(1):43–52. 10.1007/bf02789001.7577320
Iyaka YA. 2011. Nickel in soils: A review of its distribution and impacts. Sci Res Essays 6(33):6774–6777. 10.5897/srex11.035.
Jakobsson K, Mikoczy Z, Skerfving S. 1997. Deaths and tumours among workers grinding stainless steel: a follow up. Occup Environ Med 54(11):825–829. 10.1136/oem.54.11.825.9538356
James AC, Stahlhofen W, Rudolf G, . 1994. Annexe D. Deposition of inhaled particles. Annals of the ICRP 24(1):231–299. 10.1016/0146-6453(94)90042-6.
Jasim S, Tjälve H. 1986. Effect of zinc pyridinethione on the tissue disposition of nickel and cadmium in mice. Acta Pharmacol Toxicol (Copenh) 59(3):204–208. 10.1111/j.1600-0773.1986.tb00155.x.3799198
Jensen CS, Menné T, Lisby S, . 2003. Experimental systemic contact dermatitis from nickel: a dose-response study. Contact Dermatitis 49(3):124–132. 10.1111/j.0105-1873.2003.00157.x.14678208
Jensen P, Hamann D, Hamann CR, . 2014. Nickel and cobalt release from children’s toys purchased in Denmark and the United States. Dermatitis 25(6):356–365. 10.1097/DER.0000000000000084.25384229
Jia J, Chen J. 2008. Chronic nickel-induced DNA damage and cell death: the protection role of ascorbic acid. Environ Toxicol 23(3):401–406. 10.1002/tox.20346.18214889
Johansson A, Camner P, Jarstrand C, . 1980. Morphology and function of alveolar macrophages after long-term nickel exposure. Environ Res 23(1):170–180. 10.1016/0013-9351(80)90103-6.7428755
Johansson A, Lundborg M, Skog S, . 1987. Lysozyme activity in ultrastructurally defined fractions of alveolar macrophages after inhalation exposure to nickel. Br J Ind Med 44(1):47–52. 10.1136/oem.44.1.47.3814534
Johansson A, Wiernik A, Lundborg M, . 1988a. Alveolar macrophages in rabbits after combined exposure to nickel and trivalent chromium. Environ Res 46(2):120–132. 10.1016/s0013-9351(88)80026-4.3402403
Johansson A, Curstedt T, Jarstrand C, . 1988b. Effects on the rabbit lung of combined exposure to nickel and trivalent chromium. J Aerosol Sci 19(7):1075–1078. 10.1016/0021-8502(88)90105-X.
Johansson A, Curstedt T, Robertson B, . 1989. Lung lesions after experimental combined exposure to nickel and trivalent chromium. Environ Res 50(1):103–119. 10.1016/s0013-9351(89)80052-0.2792055
Johnson H, Yu J. 2023. Patch testing results from the Massachusetts General Hospital Occupational and Contact Dermatitis Clinic, 2017-2022. Dermatitis 34(6). 10.1089/derm.2023.0085.
Jordan WP, Jr., King SE. 1979. Nickel feeding in nickel-sensitive patients with hand eczema. J Am Acad Dermatol 1(6):506–508. 10.1016/s0190-9622(79)80093-6.393731
Journeay WS, Goldman RH. 2014. Occupational handling of nickel nanoparticles: a case report. Am J Ind Med 57(9):1073–1076. 10.1002/ajim.22344.24809594
Julander A, Skare L, Mulder M, . 2010. Skin deposition of nickel, cobalt, and chromium in production of gas turbines and space propulsion components. Ann Occup Hyg 54(3):340–350. 10.1093/annhyg/meq002.20150401
Kaaber K, Veien NK, Tjell JC. 1978. Low nickel diet in the treatment of patients with chronic nickel dermatitis. Br J Dermatol 98(2):197–201. 10.1111/j.1365-2133.1978.tb01622.x.629873
Kadoya C, Lee BW, Ogami A, . 2016. Analysis of pulmonary surfactant in rat lungs after inhalation of nanomaterials: Fullerenes, nickel oxide and multi-walled carbon nanotubes. Nanotoxicology 10(2):194–203. 10.3109/17435390.2015.1039093.25950198
Käkelä R, Käkelä A, Hyvärinen H. 1999. Effects of nickel chloride on reproduction of the rat and possible antagonistic role of selenium. Comp Biochem Physiol C Pharmacol Toxicol Endocrinol 123(1):27–37. 10.1016/s0742-8413(99)00006-7.10390053
Kalahasthi RB, Rajmohan HR, Rajanb K. 2006. Assessment of functional integrity of liver among workers exposed to soluble nickel compounds during nickel plating. Indian J Occup Environ Med 10(2):78–81.
Kamal M, Tamara S, Shaban D. 2012. Investigation of antioxidant system activity in rats liver exposed to ammonium metavanadate and/ or nickel sulfate. Adv Environ Biol 6(1):24–32.
Kamerud KL, Hobbie KA, Anderson KA. 2013. Stainless steel leaches nickel and chromium into foods during cooking. J Agric Food Chem 61(39):9495–9501. 10.1021/jf402400v.23984718
Kanematsu N, Hara M, Kada T. 1980. Rec assay and mutagenicity studies on metal compounds. Mutat Res 77(2):109–116. 10.1016/0165-1218(80)90127-5.6769036
Kang GS, Gillespie PA, Gunnison A, . 2011a. Comparative pulmonary toxicity of inhaled nickel nanoparticles; role of deposited dose and solubility. Inhal Toxicol 23(2):95–103. 10.3109/08958378.2010.543440.
Kang GS, Gillespie PA, Gunnison A, . 2011b. Long-term inhalation exposure to nickel nanoparticles exacerbated atherosclerosis in a susceptible mouse model. Environ Health Perspect 119(2):176–181. 10.1289/ehp.1002508.20864429
Karjalainen S, Kerttula R, Pukkala E. 1992. Cancer risk among workers at a copper/nickel smelter and nickel refinery in Finland. Int Arch Occup Environ Health 63(8):547–551. 10.1007/bf00386344.1587630
Kaschl A, Romheld V, Chen Y. 2002. The influence of soluble organic matter from municipal solid waste compost on trace metal leaching n calcareous soils. Sci Total Environ 291:45–57.12150442
Kasprzak KS, Waalkes MP, Poirier LA. 1986. Effects of magnesium acetate on the toxicity of nickelous acetate in rats. Toxicology 42(1):57–68. 10.1016/0300-483x(86)90092-2.3798459
Kazan D, Odyakmaz-Demirsoy E, Eloglu H, . 2023. Evaluation of patch test results in paediatric patients in a tertiary dermatology clinic. Indian J Dermatol 68(3):354. 10.4103/ijd.ijd_152_23.
Keczkes K, Basheer AM, Wyatt EH. 1982. The persistence of allergic contact sensitivity: a 10-year follow-up in 100 patients. Br J Dermatol 107(4):461–465. 10.1111/j.1365-2133.1982.tb00389.x.7126452
Kerfoot DGE. 2012. Nickel. In: Ullmann’s encyclopedia of industrial chemistry. Vol. 24. Weinheim: Wiley-VCH Verlag GmbH & Co., 37–101. 10.1002/14356007.a17_157.
Kettelarij JA, Liden C, Axen E, . 2014. Cobalt, nickel and chromium release from dental tools and alloys. Contact Dermatitis 70(1):3–10. 10.1111/cod.12111.23844864
Kettelarij J, Nilsson S, Midander K, . 2016. Snapshot of cobalt, chromium and nickel exposure in dental technicians. Contact Dermatitis 75(6):370–376. 10.1111/cod.12681.27633504
Keyhani E, Abdi-Oskouei F, Attar F, . 2006. DNA strand breaks by metal-induced oxygen radicals in purified Salmonella typhimurium DNA. Ann N Y Acad Sci 1091:52–64. 10.1196/annals.1378.054.17341602
Khandelwal S, Tandon SK. 1984. Effect of cadmium pretreatment on nickel toxicity. IARC Sci Publ (53):293–300.6532985
Khoshgoftarmanesh AH, Aghili F, Sanaeiostovar A. 2009. Daily intake of heavy metals and nitrate through greenhouse cucumber and bell pepper consumption and potential health risks for human. Int J Food Sci Nutr 60(Suppl 1):199–208. 10.1080/09637480902755087.19330637
Kilburn KH, Warshaw R, Boylen CT, . 1990. Cross-shift and chronic effects of stainless-steel welding related to internal dosimetry of chromium and nickel. Am J Ind Med 17(5):607–615. 10.1002/ajim.4700170506.2337084
Kim HL, Seo YR. 2011. Synergistic genotoxic effect between gene and environmental pollutant: Oxidative DNA damage induced by thioredoxin reductase 1 silencing under nickel treatment. Mol Cell Toxicol 7(3):251. 10.1007/s13273-011-0031-z.
Kim HL, Seo YR. 2012. Molecular and genomic approach for understanding the gene-environment interaction between Nrf2 deficiency and carcinogenic nickel-induced DNA damage. Oncol Rep 28(6):1959–1967. 10.3892/or.2012.2057.23023193
Kim JY, Mukherjee S, Ngo LC, . 2004. Urinary 8-hydroxy-2’-deoxyguanosine as a biomarker of oxidative DNA damage in workers exposed to fine particulates. Environ Health Perspect 112(6):666–671. 10.1289/ehp.6827.15121508
Kim K-H, Shon Z-H, Mauulida PT, . 2014. Long-term monitoring of airborne nickel (Ni) pollution in association with some potential source processes in the urban environment. Chemosphere 111:312–319. 10.1016/j.chemosphere.2014.03.138.24997934
Klein CB, Costa M. 1997. DNA methylation, heterochromatin and epigenetic carcinogens. Mutat Res 386(2):163–180. 10.1016/s1383-5742(96)00052-x.9113117
Kodama Y, Ishimatsu S, Matsuno K, . 1985a. Pulmonary deposition and clearance of a nickel oxide aerosol by inhalation. Biol Trace Elem Res 7(1):1–9. 10.1007/bf02916542.24258870
Kodama Y, Tanaka I, Matsuno K, . 1985b. Pulmonary deposition and clearance of inhaled nickel oxide aerosol. In: Brown SS, Sunderman FW, eds. Nickel toxicology. Oxford, UK: Blackwell, 81–84.
Kolberg L, Forster F, Gerlich J, . 2020. Nickel allergy is associated with wheezing and asthma in a cohort of young German adults: results from the SOLAR study. ERJ Open Res 6(1):00178–02019. 10.1183/23120541.00178-2019.
Kollmeier H, Seemann JW, Müller KM, . 1987. Increased chromium and nickel content in lung tissue and bronchial carcinoma. Am J Ind Med 11(6):659–669. 10.1002/ajim.4700110607.3605103
Kong L, Gao X, Zhu J, . 2016. Mechanisms involved in reproductive toxicity caused by nickel nanoparticle in female rats. Environ Toxicol 31(11):1674–1683. 10.1002/tox.22288.27257140
Kong L, Hu W, Lu C, . 2019. Mechanisms underlying nickel nanoparticle induced reproductive toxicity and chemo-protective effects of vitamin C in male rats. Chemosphere 218:259–265. 10.1016/j.chemosphere.2018.11.128.30472609
Kong L, Tang M, Zhang T, . 2014. Nickel nanoparticles exposure and reproductive toxicity in healthy adult rats. Int J Mol Sci 15(11):21253–21269. 10.3390/ijms151121253.25407529
Koumaki D, Koumaki V, Rovithi E, . 2020. Patch testing in southern Greece: A retrospective study. Contact Dermatitis 82(6):407–408. 10.1111/cod.13489.32037596
Krachler M, Mohl C, Emons H, . 2003. Atmospheric deposition of V, Cr, and Ni since the late glacial: effects of climatic cycles, human impacts, and comparison with crustal abundances. Environ Sci Technol 37(12):2658–2667. 10.1021/es0263083.12854702
Kuligowski J, Halperin KM. 1992. Stainless steel cookware as a significant source of nickel, chromium, and iron. Arch Environ Contam Toxicol 23(2):211–215. 10.1007/bf00212277.1514841
Kulkami P, Agrawal S, Bansal A, . 2016. Assessment of nickel release from various dental appliances used routinely in pediatric dentistry. Indian J Dent 7(2):81–85.27433051
Kunimasa K, Arita M, Tachibana H, . 2011. Chemical pneumonitis and acute lung injury caused by inhalation of nickel fumes. Intern Med 50(18):2035–2038. 10.2169/internalmedicine.50.5557.21921392
LaBauve JM, Kotuby-Amacher J, Gambrell RP. 1988. The effect of soil properties and a synthetic municipal landfill leachate on the retention of Cd, Ni, Pb, and Zn in soil and sediment materials. J Water Pollut Control Fed 60:379–385.
Lai CH, Ho SC, Pan CH, . 2021. Chronic exposure to metal fume PM(2.5) on inflammation and stress hormone cortisol in shipyard workers: A repeat measurement study. Ecotoxicol Environ Saf 215:112144. 10.1016/j.ecoenv.2021.112144.33743405
Landing WM, Perry JJ, Guentzel JL, . 1995. Relationships between the atmospheric deposition of trace elements, major ions, and mercury in Florida: The FAMS project (1992–1993). Water Air Soil Pollut 80(1):343–352. 10.1007/BF01189684.
Larese F, Gianpietro A, Venier M, . 2007. In vitro percutaneous absorption of metal compounds. Toxicol Lett 170(1):49–56. 10.1016/j.toxlet.2007.02.009.17382494
Larramendy ML, Popescu NC, Dipaolo JA. 1981. Induction by inorganic metal salts of sister chromatid exchanges and chromosome aberrations in human and Syrian hamster cell strains. Environ Mutagen 3(6):597–606. 10.1002/em.2860030602.
Larsson-Stymne B, Widström L. 1985. Ear piercing--a cause of nickel allergy in schoolgirls? Contact Dermatitis 13(5):289–293. 10.1111/j.1600-0536.1985.tb02580.x.4092451
Lascelles K, Morgan LG, Nicholls D, . 2019. Nickel compounds. In: Ullmann’s encyclopedia of industrial chemistry. Weinheim: Wiley-VCH Verlag GmbH & Co. 10.1002/14356007.a17_235.
Latvala S, Hedberg J, Di Bucchianico S, . 2016. Nickel release, ROS generation and toxicity of Ni and NiO micro- and nanoparticles. PLoS One 11(7):e0159684. 10.1371/journal.pone.0159684.27434640
Latvala S, Vare D, Karlsson HL, . 2017. In vitro genotoxicity of airborne Ni-NP in air-liquid interface. J Appl Toxicol 37(12):1420–1427. 10.1002/jat.3510.28815640
Lechner JF, Tokiwa T, McClendon IA, . 1984. Effects of nickel sulfate on growth and differentiation of normal human bronchial epithelial cells. Carcinogenesis 5(12):1697–1703. 10.1093/carcin/5.12.1697.6333938
Lee RE, Goranson SS, Enrione RE, . 1972. National air surveillance cascade impactor network. II. Size distribution measurements of trace metal components. Environ Sci Technol 6(12):1025–1030. 10.1021/es60071a002.
Lee RE, Crist HL, Riley AE, . 1975. Concentration and size of trace metal emissions from a power plant, a steel plant, and a cotton gin. Environ Sci Technol 9(7):643–647. 10.1021/es60105a012.
Lee S, Hwang SH, Jeong J, . 2016. Nickel oxide nanoparticles can recruit eosinophils in the lungs of rats by the direct release of intracellular eotaxin. Part Fibre Toxicol 13(1):30. 10.1186/s12989-016-0142-8.27283431
Lee YS, Sung JH, Song KS, . 2019. Derivation of occupational exposure limits for multi-walled carbon nanotubes and graphene using subchronic inhalation toxicity data and a multi-path particle dosimetry model. Toxicol Res (Camb) 8(4):580–586. 10.1039/c9tx00026g.31367339
Li HB, Wang JY, Chen XQ, . 2020a. Geogenic nickel exposure from food consumption and soil ingestion: A bioavailability based assessment. Environ Pollut 265(Pt B):114873. 10.1016/j.envpol.2020.114873.32502920
Li Z, Liu H, Qian Y, . 2020b. Influence of metals from e-waste dismantling on telomere length and mitochondrial DNA copy number in people living near recycling sites. Environ Int 140:105769. 10.1016/j.envint.2020.105769.32387852
Liberda EN, Cuevas AK, Qu Q, . 2014. The acute exposure effects of inhaled nickel nanoparticles on murine endothelial progenitor cells. Inhal Toxicol 26(10):588–597. 10.3109/08958378.2014.937882.25144474
Lloyd GK. 1980. Dermal absorption and conjugation of nickel in relation to the induction of allergic contact dermatitis-Preliminary results. In: Brown SS, Sunderman FW, eds. Nickel toxicology. London, United Kingdom: Academic Press, 145–148.
Lottermoser B. 2002. Exposure assessment of naturally metal enriched topsoils, Port Macquarie, Australia. Environ Geochem Health 24:183–190.
Lou J, Jin L, Wu N, . 2013. DNA damage and oxidative stress in human B lymphoblastoid cells after combined exposure to hexavalent chromium and nickel compounds. Food Chem Toxicol 55:533–540. 10.1016/j.fct.2013.01.053.23410589
Lucassen E, Smolders AJP, Roelofs JGM. 2002. Potential sensitivity of mires to drought, acidification and mobilisation of heavy metals: the sediment S/(Ca + Mg) ratio as diagnostic tool. Environ Pollut 120:635–646.12442787
Lyons-Darden T, Blum JL, Schooley MW, . 2023. An assessment of the oral and inhalation acute toxicity of nickel oxide nanoparticles in rats. Nanomaterials (Basel) 13(2):261. 10.3390/nano13020261.36678015
Magaye R, Gu Y, Wang Y, . 2016. In vitro and in vivo evaluation of the toxicities induced by metallic nickel nano and fine particles. J Mol Histol 47(3):273–286. 10.1007/s10735-016-9671-6.27010930
Mahmoud KE, Shalahmetova T, Deraz S, . 2011. Combined effect of vanadium and nickel on lipid peroxidation and selected parameters of antioxidant system in liver and kidney of male rat. Afr J Biotechnol 10(79):18319–18325. 10.5897/ajb11.2949.
Manceau A, Tamura N, Celestre RS, . 2003. Molecular-scale speciation of Zn and Ni in soil ferromanganese nodules from loess soils of the Mississippi Basin. Environ Sci Technol 37:75–80.12542293
Mandal R, Hassan NM, Murimboh J, . 2002. Chemical speciation and toxicity of nickel species in natural waters from the Sudbury area (Canada). Environ Sci Technol 36(7):1477–1484. 10.1021/es015622e.11999054
Mannetje A, Bencko V, Brennan P, . 2011. Occupational exposure to metal compounds and lung cancer. Results from a multi-center case-control study in Central/Eastern Europe and UK. Cancer Causes Control 22(12):1669–1680. 10.1007/s10552-011-9843-3.21960145
Marsh GM, Buchanich JM, Zimmerman S, . 2017a. Mortality among hardmetal production workers: US cohort and nested case-control studies. J Occup Environ Med 59(12):e306–e326. 10.1097/jom.0000000000001075.29215485
Marsh GM, Buchanich JM, Zimmerman S, . 2017b. Mortality among hardmetal production workers: Pooled analysis of cohort data from an international investigation. J Occup Environ Med 59(12):e342–e364. 10.1097/jom.0000000000001151.29215487
Marzin DR, Phi HV. 1985. Study of the mutagenicity of metal derivatives with Salmonella typhimurium TA102. Mutat Res 155(1–2):49–51. 10.1016/0165-1218(85)90024-2.3881664
Marzouk A, Sunderman FW. 1985. Biliary excretion of nickel in rats. Toxicol Lett 27(1–3):65–71. 10.1016/0378-4274(85)90121-3.4060186
Mas A, Peligero MJ, Arola L, . 1986. Distribution and kinetics of injected nickel in the pregnant rat. Clin Exp Pharmacol Physiol 13(2):91–96. 10.1111/j.1440-1681.1986.tb00321.x.3708918
Mastromatteo E. 1986. Yant memorial lecture. Nickel. Am Ind Hyg Assoc J 47(10):589–601. 10.1080/15298668691390304.3535467
Matheys J, Timmermans J-M, Van Autenboer W, . 2006. Comparison of the environmental impact of 5 electric vehicle battery technologies using LCA. In: Duflou J, Dewulf W, eds. Proceedings of the 13th CIRP international conference on life cycle engineering: Held at the Katholieke Universiteit Leuven, Belguim, Mai 31st - June 2nd 2006. Leuven, Belgium: Katholieke Universiteit Leuven, 97–102.
Mathur AK, Gupta BN. 1994. Dermal toxicity of nickel and chromium in guinea pigs. Vet Hum Toxicol 36(2):131–132.8197712
Mathur AK, Datta KK, Tandon SK, . 1977. Effect of nickel sulphate on male rats. Bull Environ Contam Toxicol 17(2):241–248. 10.1007/bf01685557.843642
Mathur AK, Dikshith TS, Lal MM, . 1978. Distribution of nickel and cytogenetic changes in poisoned rats. Toxicology 10(2):105–113.684755
Mathur AK, Agarwal C, Singh A, . 1988. Effect of sodium lauryl sulphate and nickel alone and in combination on the skin of guinea pigs. Toxicol Lett 42(3):249–256. 10.1016/0378-4274(88)90109-9.3176054
Mathur AK, Gupta BN, Singh S, . 1992. Cutaneous toxicity of sodium lauryl sulphate, nickel, and their combination in guinea pigs: Biochemical and histopathological observations. Bull Environ Contam Toxicol 49(6):871–878. 10.1007/BF00203161.1450568
May TW, Wiedmeyer RH, Gober J, . 2001. Influence of mining-related activities on concentrations of metals in water and sediment from streams of the Black Hills, South Dakota. Arch Environ Contam Toxicol 40(1):1–9. 10.1007/s002440010142.11116335
Mayer C, Klein RG, Wesch H, . 1998. Nickel subsulfide is genotoxic in vitro but shows no mutagenic potential in respiratory tract tissues of BigBlue rats and Muta Mouse mice in vivo after inhalation. Mutat Res 420(1–3):85–98. 10.1016/s1383-5718(98)00140-5.9838057
M’Bemba-Meka P, Lemieux N, Chakrabarti SK. 2005. Nickel compound-induced DNA single-strand breaks in chromosomal and nuclear chromatin in human blood lymphocytes in vitro: role of oxidative stress and intracellular calcium. Mutat Res 586(2):124–137. 10.1016/j.mrgentox.2005.06.001.16099703
M’Bemba-Meka P, Lemieux N, Chakrabarti SK. 2007. Role of oxidative stress and intracellular calcium in nickel carbonate hydroxide-induced sister-chromatid exchange, and alterations in replication index and mitotic index in cultured human peripheral blood lymphocytes. Arch Toxicol 81(2):89–99. 10.1007/s00204-006-0128-7.16826409
McConnell LH, Fink JN, Schlueter DP, . 1973. Asthma caused by nickel sensitivity. Ann Intern Med 78(6):888–890. 10.7326/0003-4819-78-6-888.4197371
McGeer JC, Brix KV, Skeaff JM, . 2003. Inverse relationship between bioconcentration factor and exposure concentration for metals: implications for hazard assessment of metals in the aquatic environment. Environ Toxicol Chem 22(5):1017–1037.12729211
McGregor DB, Brown A, Cattanach P, . 1988. Responses of the L5178Y tk+/tk− mouse lymphoma cell forward mutation assay: III. 72 coded chemicals. Environ Mol Mutagen 12(1):85–154. 10.1002/em.2860120111.3383842
McIlveen WD, Negusanti JJ. 1994. Nickel in the terrestrial environment. Sci Total Environ 148(2–3):109–138. 10.1016/0048-9697(94)90390-5.8029689
McNeill DA, Chrisp CE, Fisher GL. 1990. Tumorigenicity of nickel subsulfide in Strain A/J mice. Drug Chem Toxicol 13(1):71–86. 10.3109/01480549009011070.2379474
MDEQ. 2013. Public notice: Permit No. GW1810162: Eagle Mine. Michigan Department of Environmental Quality.
Medinsky MA, Benson JM, Hobbs CH. 1987. Lung clearance and disposition of 63Ni in F344/N rats after intratracheal instillation of nickel sulfate solutions. Environ Res 43(1):168–178. 10.1016/s0013-9351(87)80068-3.3582305
Meijer C, Bredberg M, Fischer T, . 1995. Ear piercing, and nickel and cobalt sensitization, in 520 young Swedish men doing compulsory military service. Contact Dermatitis 32(3):147–149. 10.1111/j.1600-0536.1995.tb00804.x.7774185
Meir KS, Leitersdorf E. 2004. Atherosclerosis in the apolipoprotein-E-deficient mouse: a decade of progress. Arterioscler Thromb Vasc Biol 24(6):1006–1014. 10.1161/01.ATV.0000128849.12617.f4.15087308
Melo DR, Leggett RW. 2017. A biokinetic model for systemic nickel. Health Phys 112(1):18–27. 10.1097/HP.0000000000000579.27906784
Menné T, Calvin G. 1993. Concentration threshold of non-occluded nickel exposure in nickel-sensitive individuals and controls with and without surfactant. Contact Dermatitis 29(4):180–184. 10.1111/j.1600-0536.1993.tb03533.x.8281779
Menné T, Brandup F, Thestrup-Pedersen K, . 1987. Patch test reactivity to nickel alloys. Contact Dermatitis 16(5):255–259. 10.1111/j.1600-0536.1987.tb01448.x.3621926
Menzel DB, Deal DL, Tayyeb MI, . 1987. Pharmacokinetic modeling of the lung burden from repeated inhalation of nickel aerosols. Toxicol Lett 38(1–2):33–43. 10.1016/0378-4274(87)90108-1.3629632
Michalak I, Mikulewicz M, Chojnacka K, . 2012. Exposure to nickel by hair mineral analysis. Environ Toxicol Pharmacol 34:727–734. 10.1016/j.etap.2012.09.015.23121872
Middag R, de Baar HJW, Bruland KW, . 2020. The distribution of nickel in the West-Atlantic Ocean, its relationship with phosphate and a comparison to cadmium and zinc. Front Marine Sci 7:105. 10.3389/fmars.2020.00105.
Minigalieva IA, Katsnelson BA, Privalova LI, . 2015. Attenuation of combined nickel(II) oxide and manganese(II, III) oxide nanoparticles’ adverse effects with a complex of bioprotectors. Int J Mol Sci 16(9):22555–22583. 10.3390/ijms160922555.26393577
Minigaliyeva IA, Katsnelson BA, Privalova LI, . 2014. Toxicodynamic and toxicokinetic descriptors of combined chromium (VI) and nickel toxicity. Int J Toxicol 33(6):498–505. 10.1177/1091581814555915.25355735
Misra M, Athar M, Hasan SK, . 1988. Alleviation of nickel-induced biochemical alterations by chelating agents. Fundam Appl Toxicol 11(2):285–292. 10.1016/0272-0590(88)90153-4.3220207
Miura T, Patierno SR, Sakuramoto T, . 1989. Morphological and neoplastic transformation of C3H/10T1/2 Cl 8 mouse embryo cells by insoluble carcinogenic nickel compounds. Environ Mol Mutagen 14(2):65–78. 10.1002/em.2850140202.2548861
Miyaki M, Akamatsu N, Ono T, . 1979. Mutagenicity of metal cations in cultured cells from Chinese hamster. Mutat Res 68(3):259–263. 10.1016/0165-1218(79)90157-5.514305
Mizuguchi Y, Myojo T, Oyabu T, . 2013. Comparison of dose-response relations between 4-week inhalation and intratracheal instillation of NiO nanoparticles using polimorphonuclear neutrophils in bronchoalveolar lavage fluid as a biomarker of pulmonary inflammation. Inhal Toxicol 25(1):29–36. 10.3109/08958378.2012.751470.23293971
Mo Y, Jiang M, Zhang Y, . 2019. Comparative mouse lung injury by nickel nanoparticles with differential surface modification. J Nanobiotechnology 17(1):2. 10.1186/s12951-018-0436-0.30616599
Mohammad AB, Mohammad SHK, Mohammad MK, . 2019. Quantification of trace elements in different dokha and shisha tobacco products using EDXRF. J Anal Toxicol 43(4):e7–e22. 10.1093/jat/bky095.
Möller H. 1984. Attempts to induce contact allergy to nickel in the mouse. Contact Dermatitis 10(2):65–68. 10.1111/j.1600-0536.1984.tb00337.x.6713842
Morgan LG, Rouge PJ. 1984. Biological monitoring in nickel refinery workers. IARC Sci Publ (53):507–520.6532992
Morimoto Y, Nambu Z, Tanaka I, . 1995. Effects of nickel oxide on the production of tumor necrosis factor by alveolar macrophages of rats. Biol Trace Elem Res 48(3):287–296. 10.1007/bf02789410.9398948
Morimoto Y, Ogami A, Todoroki M, . 2010. Expression of inflammation-related cytokines following intratracheal instillation of nickel oxide nanoparticles. Nanotoxicology 4(2):161–176. 10.3109/17435390903518479.20795893
Morimoto Y, Oyabu T, Ogami A, . 2011. Investigation of gene expression of MMP-2 and TIMP-2 mRNA in rat lung in inhaled nickel oxide and titanium dioxide nanoparticles. Ind Health 49(3):344–352. 10.2486/indhealth.ms1218.21372438
Morimoto Y, Izumi H, Yoshiura Y, . 2016. Comparison of pulmonary inflammatory responses following intratracheal instillation and inhalation of nanoparticles. Nanotoxicology 10(5):607–618. 10.3109/17435390.2015.1104740.26558952
Morita T, Asano N, Awogi T, . 1997. Evaluation of the rodent micronucleus assay in the screening of IARC carcinogens (groups 1, 2A and 2B) the summary report of the 6th collaborative study by CSGMT/JEMS MMS. Collaborative study of the Micronucleus Group Test. Mammalian Mutagenicity Study Group. Mutat Res 389(1):3–122. 10.1016/s1383-5718(96)00070-8.9062586
Moulin JJ, Portefaix P, Wild P, . 1990. Mortality study among workers producing ferroalloys and stainless steel in France. Br J Ind Med 47(8):537–543. 10.1136/oem.47.8.537.2393634
Moulin JJ, Wild P, Mantout B, . 1993. Mortality from lung cancer and cardiovascular diseases among stainless-steel producing workers. Cancer Causes Control 4(2):75–81. 10.1007/bf00053147.8386949
Moulin JJ, Clavel T, Roy D, . 2000. Risk of lung cancer in workers producing stainless steel and metallic alloys. Int Arch Occup Environ Health 73(3):171–180. 10.1007/s004200050024.10787132
Mouvet C, Bourg ACM. 1983. Speciation (including adsorbed species) of copper, lead, nickel and zinc in the Meuse River. Water Res 17(6):641–649.
Mozzanica N, Rizzolo L, Veneroni G, . 1990. HLA-A, B, C and DR antigens in nickel contact sensitivity. Br J Dermatol 122(3):309–313. 10.1111/j.1365-2133.1990.tb08278.x.2322496
Muir DC, Julian J, Jadon N, . 1993. Prevalence of small opacities in chest radiographs of nickel sinter plant workers. Br J Ind Med 50(5):428–431. 10.1136/oem.50.5.428.8507595
Mukovozov IM, Kashetsky N, de Gannes G. 2022. Prevalence of contact allergy to nickel: a retrospective chart review. Dermatitis 33(5):355–361. 10.1097/der.0000000000000812.36113000
Müller-Fassbender M, Elsenhans B, McKie AT, . 2003. Different behaviour of 63Ni and 59Fe during absorption in iron-deficient and iron-adequate jejunal rat segments ex vivo. Toxicology 185(1):141–153. 10.1016/S0300-483X(02)00600-5.12505452
Mumtaz MM, Ray M, Crowell SR, . 2012a. Translational research to develop a human PBPK models tool kit-volatile organic compounds (VOCs). J Toxicol Environ Health A 75(1):6–24. 10.1080/15287394.2012.625546.22047160
Mumtaz M, Fisher J, Blount B, . 2012b. Application of physiologically based pharmacokinetic models in chemical risk assessment. J Toxicol 2012:904603. 10.1155/2012/904603.22523493
NAS/NRC. 2006. Human biomonitoring for environmental chemicals. Washington, DC: The National Academies Press, National Research Council. 10.17226/11700.
NASEM. 2019. Dietary reference intakes for sodium and potassium. Washington, DC: National Academies of Sciences Engineering, and Medicine. National Academies Press. 10.17226/25353.
Ni W, Huang Y, Wang X, . 2014. Associations of neonatal lead, cadmium, chromium and nickel co-exposure with DNA oxidative damage in an electronic waste recycling town. Sci Total Environ 472:354–362. 10.1016/j.scitotenv.2013.11.032.24295751
Nielsen FH. 1980. Effect of form of iron on the interaction between nickel and iron in rats: growth and blood parameters. J Nutr 110(5):965–973. 10.1093/jn/110.5.965.7373441
Nielsen FH. 1990. Other trace elements. In: Brown ML, ed. Present knowledge in nutrition. 6th ed. Washington, DC: International Life Sciences Institute Press, 294–307.
Nielsen GD, Flyvholm M. 1984. Risks of high nickel intake with diet. IARC Sci Publ (53):333–338.6532987
Nielsen FH, Hunt CD, Uthus EO. 1980. Interactions between essential trace and ultratrace elements. Ann N Y Acad Sci 355:152–164. 10.1111/j.1749-6632.1980.tb21335.x.6940472
Nielsen GD, Jepsen LV, Jørgensen PJ, . 1990. Nickel-sensitive patients with vesicular hand eczema: oral challenge with a diet naturally high in nickel. Br J Dermatol 122(3):299–308. 10.1111/j.1365-2133.1990.tb08277.x.2322495
Nielsen GD, Søderberg U, Jørgensen PJ, . 1999. Absorption and retention of nickel from drinking water in relation to food intake and nickel sensitivity. Toxicol Appl Pharmacol 154(1):67–75. 10.1006/taap.1998.8577.9882593
Nielsen NH, Linneberg A, Menné T, . 2002. Incidence of allergic contact sensitization in Danish adults between 1990 and 1998; the Copenhagen Allergy Study, Denmark. Br J Dermatol 147(3):487–492. 10.1046/j.1365-2133.2002.04668.x.12207588
Nieminen TM, Ukonmaanaho L, Rausch N, . 2007. Biogeochemistry of nickel and its release into the environment. In: Nickel and its surprising impact in nature. John Wiley & Sons, Ltd, 1–29. 10.1002/9780470028131.ch1.
Nightingale HI. 1987. Water quality beneath urban runoff water management basins. Water Resour Bull 23(2):197–205.
NIOSH. 2013. Current intelligence bulletin 65: Occupational exposure to carbon nanotubes and nanofibers. Atlanta, GA: National Institute for Occupational Safety and Health. DHHS (NIOSH) Publication Number 2013-145. https://www.cdc.gov/niosh/docs/2013-145/pdfs/2013-145.pdf. April 2, 2024.
NIOSH. 2019. Nickel metal and other compounds (as Ni). CDC NIOSH pocket guide to chemical hazards. Atlanta, GA: The National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. https://www.cdc.gov/niosh/npg/npgd0445.html. March 29, 2021.
NLM. 2024a. PubChem compound summary: Nickel. National Library of Medicine. National Center for Biotechnology Information. https://pubchem.ncbi.nlm.nih.gov/compound/935. May 23, 2024.
NLM. 2024b. PubChem compound summary: Nickel acetate. National Library of Medicine. National Center for Biotechnology Information. https://pubchem.ncbi.nlm.nih.gov/compound/9756. May 23, 2024.
NLM. 2024c. PubChem compound summary: Nickel ammonium sulfate. National Library of Medicine. National Center for Biotechnology Information. https://pubchem.ncbi.nlm.nih.gov/compound/27455. May 23, 2024.
NLM. 2024d. PubChem compound summary: Nickel carbonate. National Library of Medicine. National Center for Biotechnology Information. https://pubchem.ncbi.nlm.nih.gov/compound/18746. May 23, 2024.
NLM. 2024e. PubChem compound summary: Nickel chloride. National Library of Medicine. National Center for Biotechnology Information. https://pubchem.ncbi.nlm.nih.gov/compound/24385. May 23, 2024.
NLM. 2024f. PubChem compound summary: Nickel(II) cyanide. National Library of Medicine. National Center for Biotechnology Information. https://pubchem.ncbi.nlm.nih.gov/compound/6093189. May 23, 2024.
NLM. 2024g. PubChem compound summary: Nickel oxide. National Library of Medicine. National Center for Biotechnology Information. https://pubchem.ncbi.nlm.nih.gov/compound/14805. May 23, 2024.
NLM. 2024h. PubChem compound summary: Nickel nitrate. National Library of Medicine. National Center for Biotechnology Information. https://pubchem.ncbi.nlm.nih.gov/compound/25736. May 23, 2024.
NLM. 2024i. PubChem compound summary: Trinickel disulphide. National Library of Medicine. National Center for Biotechnology Information. https://pubchem.ncbi.nlm.nih.gov/compound/22833473. May 23, 2024.
NLM. 2024j. PubChem compound summary: Nickel sulfamate. National Library of Medicine. National Center for Biotechnology Information. https://pubchem.ncbi.nlm.nih.gov/compound/83720. May 23, 2024.
NLM. 2024k. PubChem compound summary: Nickel sulfate. National Library of Medicine. National Center for Biotechnology Information. https://pubchem.ncbi.nlm.nih.gov/compound/24586. May 23, 2024.
NLM. 2024l. PubChem compound summary: Nickel sulfate hexahydrate. National Library of Medicine. National Center for Biotechnology Information. https://pubchem.ncbi.nlm.nih.gov/compound/5284429. May 23, 2024.
Norgaard O. 1955. Investigations with radioactive Ni 57 into the resorption of nickel through the skin in normal and in nickel-hypersensitive persons. Acta Derm Venereol 35(2):111–117.13248415
Norgaard O. 1957. Investigations with radioactive nickel, cobalt and sodium on the resorption through the skin in rabbits, guinea-pigs and man. Acta Derm Venereol 37(6):440–445.13497509
Novey HS, Habib M, Wells ID. 1983. Asthma and IgE antibodies induced by chromium and nickel salts. J Allergy Clin Immunol 72(4):407–412. 10.1016/0091-6749(83)90507-9.6413567
Nriagu JO, Lawson G, Wong HKT, . 1996. Dissolved trace metals in Lakes Superior, Erie, and Ontario. Environ Sci Technol 30(1):178–187. 10.1021/es950221i.
NTP. 1996a. NTP technical report on the toxicology and carcinogenesis studies of nickel oxide (CAS No. 1313-99-1) in F344/N rats and B6C3F1 mice (inhalation studies). Research Triangle Park, NC: National Toxicology Program. NTP TR 451. https://ntp.niehs.nih.gov/publications/reports/tr/400s/tr451. April 11, 2024.
NTP. 1996b. NTP technical report on the toxicology and carcinogenesis studies of nickel subsulfide (CAS No. 12035-72-2) in F344/N rats and B6C3F1 mice (inhalation studies). Research Triangle Park, NC: National Toxicology Program. NTP TR 453. https://ntp.niehs.nih.gov/publications/reports/tr/400s/tr453. April 11, 2024.
NTP. 1996c. NTP technical report on the toxicology and carcinogenesis studies of nickel sulfate hexahydrate (CAS No. 10101-97-0) in F344/N rats and B6C3F1 mice (inhalation studies). Research Triangle Park, NC: National Toxicology Program. NTP TR 454. https://ntp.niehs.nih.gov/publications/reports/tr/400s/tr454. April 11, 2024.
NTP. 2013. Draft OHAT approach for systematic review and evidence integration for literature-based health assessments – February 2013. National Toxicology Program, Office of Health Assessment and Translation. https://ntp.niehs.nih.gov/ntp/ohat/evaluationprocess/draftohatapproach_february2013.pdf. October 4, 2023.
NTP. 2015. OHAT risk of bias rating tool for human and animal studies. National Toxicology Program, Office of Health Assessment and Translation. https://ntp.niehs.nih.gov/ntp/ohat/pubs/riskofbiastool_508.pdf. March 19, 2019.
NTP. 2016. Nickel compounds and metallic nickel. In: Report on carcinogens, fourteenth edition. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service. https://ntp.niehs.nih.gov/ntp/roc/content/profiles/nickel.pdf.
NTP. 2021. Nickel compounds and metallic nickel. In: Report on carcinogens. 15th ed. National Toxicology Program. https://ntp.niehs.nih.gov/sites/default/files/ntp/roc/content/profiles/nickel.pdf. March 4, 2024.
Oberdörster G, Oberdörster E, Oberdörster J. 2005. Nanotoxicology: an emerging discipline evolving from studies of ultrafine particles. Environ Health Perspect 11(7)3:823–839. 10.1289/ehp.7339.
Obone E, Chakrabarti SK, Bai C, . 1999. Toxicity and bioaccumulation of nickel sulfate in Sprague-Dawley rats following 13 weeks of subchronic exposure. J Toxicol Environ Health A 57(6):379–401. 10.1080/009841099157593.10478821
Ogami A, Morimoto Y, Myojo T, . 2009. Pathological features of different sizes of nickel oxide following intratracheal instillation in rats. Inhal Toxicol 21(10):812–818. 10.1080/08958370802499022.19225964
Ogawa HI, Shibahara T, Iwata H, . 1994. Genotoxic activities in vivo of cobaltous chloride and other metal chlorides as assayed in the Drosophila wing spot test. Mutat Res 320(1–2):133–140. 10.1016/0165-1218(94)90065-5.7506380
Ogunbileje JO, Sadagoparamanujam VM, Anetor JI, . 2013. Lead, mercury, cadmium, chromium, nickel, copper, zinc, calcium, iron, manganese and chromium (VI) levels in Nigeria and United States of America cement dust. Chemosphere 90(11):2743–2749. 10.1016/j.chemosphere.2012.11.058.23261125
Ohanian EV. 1986. Health effects of corrosion products in drinking water. Annual conference on trace substances in environmental health 20:122–138. https://www.osti.gov/biblio/6013999.
Ohno H, Hanaoka F, Yamada M-A. 1982. Inducibility of sister-chromatid exchanges by heavy-metal ions. Mutat Res Lett 104(1):141–145. 10.1016/0165-7992(82)90135-X.
Ohshima S. 2003. Induction of genetic instability and chromosomal instability by nickel sulfate in V79 Chinese hamster cells. Mutagenesis 18(2):133–137. 10.1093/mutage/18.2.133. 3/22/2021.12621068
Oliveira JP, de Siqueira ME, da Silva CS. 2000. Urinary nickel as bioindicator of workers’ Ni exposure in a galvanizing plant in Brazil. Int Arch Occup Environ Health 73(1):65–68. 10.1007/pl00007940.10672494
Oller AR, Erexson G. 2007. Lack of micronuclei formation in bone marrow of rats after repeated oral exposure to nickel sulfate hexahydrate. Mutat Res 626(1–2):102–110. 10.1016/j.mrgentox.2006.09.001.17052950
Oller AR, Oberdorster G, Seilkop SK. 2014. Derivation of PM10 size-selected human equivalent concentrations of inhaled nickel based on cancer and non-cancer effects on the respiratory tract. Inhal Toxicol 26(9):559–578. 10.3109/08958378.2014.932034.25055843
Oller AR, Kirkpatrick DT, Radovsky A, . 2008. Inhalation carcinogenicity study with nickel metal powder in Wistar rats. Toxicol Appl Pharmacol 233(2):262–275. 10.1016/j.taap.2008.08.017.18822311
Oller AR, Buxton S, March TH, . 2023. Comparative pulmonary and genotoxic responses to inhaled nickel subsulfide and nickel sulfate in F344 rats. J Appl Toxicol 43(5):734–751. 10.1002/jat.4422.36482046
Olsen I, Jonsen J. 1982. Whole-body autoradiography of 204Tl in embryos, fetuses and placentas of mice. Toxicology 23(4):353–358. 10.1016/0300-483x(82)90073-7.7123568
Olsson A, Togawa K, Schüz J, . 2018. Parental occupational exposure to solvents and heavy metals and risk of developing testicular germ cell tumors in sons (NORD-TEST Denmark). Scand J Work Environ Health 44(6):658–669. 10.5271/sjweh.3732.29877553
Onyije FM, Olsson A, Erdmann F, . 2022. Parental occupational exposure to combustion products, metals, silica and asbestos and risk of childhood leukaemia: Findings from the Childhood Cancer and Leukaemia International Consortium (CLIC). Environ Int 167:107409. 10.1016/j.envint.2022.107409.35908390
O’Rourke MK, Van de Water PK, Jin S, . 1999. Evaluations of primary metals from NHEXAS Arizona: distributions and preliminary exposures. J Expo Anal Environ Epidemiol 9:435–445.10554146
OSHA. 2021a. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z-2. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. https://www.govinfo.gov/content/pkg/CFR-2021-title29-vol6/pdf/CFR-2021-title29-vol6-sec1910-1000.pdf. August 28, 2022.
OSHA. 2021b. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. https://www.govinfo.gov/content/pkg/CFR-2021-title29-vol7/pdf/CFR-2021-title29-vol7-sec1915-1000.pdf. August 28, 2022.
OSHA. 2021c. Safety and health regulations for construction. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55. https://www.govinfo.gov/content/pkg/CFR-2021-title29-vol8/pdf/CFR-2021-title29-vol8-sec1926-55.pdf. August 28, 2022.
Ottolenghi AD, Haseman JK, Payne WW, . 1975. Inhalation studies of nickel sulfide in pulmonary carcinogenesis of rats. J Natl Cancer Inst 54(5):1165–1172. 10.1093/jnci/54.5.1165.165308
Oyabu T, Ogami A, Morimoto Y, . 2007. Biopersistence of inhaled nickel oxide nanoparticles in rat lung. Inhal Toxicol 19(Suppl 1):55–58. 10.1080/08958370701492995.17886051
Ozaki K, Haseman JK, Hailey JR, . 2002. Association of adrenal pheochromocytoma and lung pathology in inhalation studies with particulate compounds in the male F344 rat--the National Toxicology Program experience. Toxicol Pathol 30(2):263–270. 10.1080/019262302753559605.11950170
Pacyna JM, Ottar B. 1985. Transport and chemical composition of the summer aerosol in the Norwegian Arctic. Atmos Environ 19(12):2109–2120. 10.1016/0004-6981(85)90118-0.
Pacyna JM, Pacyna EG. 2001. An assessment of global and regional emissions of trace metals to the atmosphere from anthropogenic sources worldwide. Environ Rev 9(4):269–298. 10.1139/a01-012.
Pandey R, Srivastava SP. 2000. Spermatotoxic effects of nickel in mice. Bull Environ Contam Toxicol 64(2):161–167. 10.1007/s001289910025.10656880
Pandey R, Kumar R, Singh SP, . 1999. Male reproductive effect of nickel sulphate in mice. Biometals 12(4):339–346. 10.1023/a:1009291816033.10816734
Pang D, Burges DC, Sorahan T. 1996. Mortality study of nickel platers with special reference to cancers of the stomach and lung, 1945-93. Occup Environ Med 53(10):714–717. 10.1136/oem.53.10.714.8943838
Pappas RS, Stanfill SB, Watson CH, . 2008. Analysis of toxic metals in commercial moist snuff and Alaskan Iqmik. J Anal Toxicol 32:281–291. 10.1093/jat/32.4.281.18430295
Pappas RS, Gray N, Halstead M, . 2020. Toxic metal-containing particles in aerosols from pod-type electronic cigarettes. J Anal Toxicol 45(4):337–347. 10.1093/jat/bkaa088.
Paquin PR, Gorsuch JW, Apte S, . 2002. The biotic ligand model: a historical overview. Comp Biochem Physiol C Toxicol Pharmacol 133(1–2):3–35. 10.1016/s1532-0456(02)00112-6.12428632
Parent ME, Turner MC, Lavoué J, . 2017. Lifetime occupational exposure to metals and welding fumes, and risk of glioma: A 7-country population-based case-control study. Environ Health 16(1):90. 10.1186/s12940-017-0300-y.28841833
Patierno SR, Costa M. 1985. DNA-protein cross-links induced by nickel compounds in intact cultured mammalian cells. Chem Biol Interact 55(1–2):75–91. 10.1016/s0009-2797(85)80121-6.4064195
Patriarca M, Lyon TD, Fell GS. 1997. Nickel metabolism in humans investigated with an oral stable isotope. Am J Clin Nutr 66(3):616–621. 10.1093/ajcn/66.3.616.9280182
Pavela M, Uitti J, Pukkala E. 2017. Cancer incidence among copper smelting and nickel refining workers in Finland. Am J Ind Med 60(1):87–95. 10.1002/ajim.22662.27747921
Pedersen M, Gehring U, Beelen R, . 2016. Elemental constituents of particulate matter and newborn’s size in eight European cohorts. Environ Health Perspect 124(1):141–150. 10.1289/ehp.1409546.26046983
Peltier RE, Lippmann M. 2010. Residual oil combustion: 2. Distributions of airborne nickel and vanadium within New York City. J Expo Sci Environ Epidemiol 20(4):342–350. 10.1038/jes.2009.28.19440185
Peralta-Videa JR, Gardea-Torresdey JL, Gomez E, . 2002. Effect of mixed cadmium, copper, nickel and zinc at different pHs upon alfalfa growth and heavy metal uptake. Environ Pollut 119:291–301.12166663
Pereira AMPT, Silva LJG, Simões BDF, . 2020. Exposure to nickel through commercial premade baby foods: Is there any risk? J Food Compos Anal 92:103541. 10.1016/j.jfca.2020.103541.
Peric A, Vukomanovic Durdevic B. 2020. Nasal polyp epithelial atypia and exposure to nickel and copper. Occup Med (Lond) 70(1):72–74. 10.1093/occmed/kqz123.31587045
Pesch B, Kendzia B, Pohlabeln H, . 2019. Exposure to welding fumes, hexavalent chromium, or nickel and risk of lung cancer. Am J Epidemiol 188(11):1984–1993. 10.1093/aje/kwz187.31504103
Petersen TH, Geisler C, Bonefeld CM. 2018. Aquired immunity in metal allergy: T cell responses. In: Chen JK, Thyssen JP, eds. Metal allergy. Cham: Springer, 85–95. 10.1007/978-3-319-58503-1_9.
Phillips JI, Green FY, Davies JC, . 2010. Pulmonary and systemic toxicity following exposure to nickel nanoparticles. Am J Ind Med 53(8):763–767. 10.1002/ajim.20855.20623660
Pikálek P, Necásek J. 1983. The mutagenic activity of nickel in Corynebacterium sp. Folia Microbiol (Praha) 28(1):17–21. 10.1007/bf02877379.6832655
Polednak AP. 1981. Mortality among welders, including a group exposed to nickel oxides. Arch Environ Health 36(5):235–242. 10.1080/00039896.1981.10667630.7294887
Pool-Zobel BL, Lotzmann N, Knoll M, . 1994. Detection of genotoxic effects in human gastric and nasal mucosa cells isolated from biopsy samples. Environ Mol Mutagen 24(1):23–45. 10.1002/em.2850240105.7519553
Poulton DJ, Simpson KJ, Barton DR, . 1988. Trace metals and benthic invertebrates in sediments of nearshore Lake Ontario at Hamilton Harbour. J Great Lakes Res 14(1):52–65.
Qiao Y, Ma L. 2013. Quantification of metal ion induced DNA damage with single cell array based assay. Analyst 138(19):5713–5718. 10.1039/C3AN00967J.23892322
Rai D, Zachara JM. 1984. Nickel. In: Chemical attenuation rates, coefficients, and constants in leachate migration. Vol. 1. Battelle Pacific Northwest Laboratories, 18.1–18.8.
Raithel HJ, Schaller KH, Akslen LA, . 1989. Analyses of chromium and nickel in human pulmonary tissue. Investigations in lung cancer patients and a control population under special consideration of medical expertise aspects. Int Arch Occup Environ Health 61(8):507–512. 10.1007/bf00683120.2807568
Rao MV, Jhala DD, Patel A, . 2008. Cytogenetic alteration induced by nickel and chromium in human blood cultures and its amelioration by curcumin. Int J Hum Genet 8(3):301–305. 10.1080/09723757.2008.11886044.
Rasmuson Å. 1985. Mutagenic effects of some water-soluble metal compounds in a somatic eye-color test system in Drosophila melanogaster. Mutat Res 157(2):157–162. 10.1016/0165-1218(85)90111-9.3927160
Rausch N, Nieminen T, Ukonmaanaho L, . 2005. Comparison of atmospheric deposition of copper, nickel, cobalt, zinc, and cadmium recorded by Finnish peat cores with monitoring data and emission records. Environ Sci Technol 39(16):5989–5998. 10.1021/es050260m.16173555
Redmond CK. 1984. Site-specific cancer mortality among workers involved in the production of high nickel alloys. IARC Sci Publ (53):73–86.
Rehm S, White TE, Zahalka EA, . 2008. Effects of food restriction on testis and accessory sex glands in maturing rats. Toxicol Pathol 36:687–694. 10.1177/0192623308320275.18648097
Reith AK, Reichborn-Kjennerud S, Aubele M, . 1994. Biological monitoring of chemical exposure in nickel workers by imaging cytometry (ICM) of nasal smears. Anal Cell Pathol 6(1):9–21.8130134
Rendall RE, Phillips JI, Renton KA. 1994. Death following exposure to fine particulate nickel from a metal arc process. Ann Occup Hyg 38(6):921–930. 10.1093/annhyg/38.6.921.7825932
RePORTER. 2024. Nickel and compounds. Research Portfolio Online Reporting Tools. National Institutes of Health. https://reporter.nih.gov/. March 24, 2024.
Rezuke WN, Knight JA, Sunderman FW. 1987. Reference values for nickel concentrations in human tissues and bile. Am J Ind Med 11(4):419–426. 10.1002/ajim.4700110404.3578294
Rice KC. 1999. Trace-element concentrations in streambed sediment across the conterminous United States. Environ Sci Technol 33(15):2499–2504. 10.1021/es990052s.
Richter RO, Theis TL. 1980. Nickel speciation in a soil/water system. In: Nriagu JO, ed. Nickel in the environment. John Wiley & Sons, 189–202.
Rivera-Rivera DM, Escobedo-Urías DC, Jonathan MP, . 2020. Evidence of natural and anthropogenic impacts on rainwater trace metal geochemistry in Central Mexico: A statistical approach. Water 12(1):192. 10.3390/w12010192.
Rizzi A, Chini R, Inchingolo R, . 2020. Nickel allergy in lipid transfer protein sensitized patients: Prevalence and clinical features. Int J Immunopathol Pharmacol 34:2058738420974895. 10.1177/2058738420974895.33242297
Roberts RS, Julian JA, Muir DC, . 1989a. A study of mortality in workers engaged in the mining, smelting, and refining of nickel. II: Mortality from cancer of the respiratory tract and kidney. Toxicol Ind Health 5(6):975–993. 10.1177/074823378900500606.2626765
Rodríguez-Arnaiz R, Ramos P. 1986. Mutagenicity of nickel sulphate in Drosophila melanogaster. Mutat Res 170(3):115–117. 10.1016/0165-1218(86)90023-6.3086713
Rohr RP, Saavedra S, Bascompte J. 2014b. On the structural stability of mutualistic systems. Science 345(6195):1253497. 10.1126/science.1253497.25061214
Rohr AC, Habre R, Godbold J, . 2014a. Asthma exacerbation is associated with particulate matter source factors in children in New York City. Air Qual Atmos Health 7(2):239–250. 10.1007/s11869-013-0230-y.
Rooney AA, Boyles AL, Wolfe MS, . 2014. Systematic review and evidence integration for literature-based environmental health science assessments. Environ Health Perspect 122(7):711–718. 10.1289/ehp.1307972.24755067
Rossides M, Mogensen H, Kampitsi CE, . 2023. Parental occupational exposure to metals and risk of cancer in the offspring: A register-based case-control study from Sweden. Eur J Cancer 191:113243. 10.1016/j.ejca.2023.113243.37562074
Rudd T, Lake DL, Mehrotra I, . 1988. Characterisation of metal forms in sewage sludge by chemical extraction and progressive acidification. Sci Total Environ 74:149–175. 10.1016/0048-9697(88)90135-0.
Ruiz P, Ray M, Fisher J, . 2011. Development of a human physiologically based pharmacokinetic (PBPK) toolkit for environmental pollutants. Int J Mol Sci 12(11):7469–7480. 10.3390/ijms12117469.22174611
Sadiq M, Enfield CG. 1984a. Solid phase formation and solution chemistry of nickel in soils: 1. Theoretical. Soil Sci 138(4):262–270.
Sadiq M, Enfield CG. 1984b. Solid phase formation and solution chemistry of nickel in soils: 2. Experimental. Soil Sci 138(5):335–340.
Sahu S, Sethy M, Besra L, . 2022. Clinico-epidemiological profile of allergic contact dermatitis and its correlation with patch testing in a tertiary care center in Eastern India. Cureus 14(12):e32119. 10.7759/cureus.32119.36601177
Saini S, Nair N, Saini MR. 2013. Embryotoxic and teratogenic effects of nickel in Swiss albino mice during organogenetic period. Biomed Res Int 2013:701439. 10.1155/2013/701439.23936836
Saini S, Nair N, Saini MR. 2014a. Prenatal exposure to nickel on pregnant Swiss albino mice and fetal development. Toxicol Environ Chem 96(4):650–659. 10.1080/02772248.2014.957483.
Saini S, Nair N, Saini M. 2014b. Effects of gestational administration of nickel on postnatal development in Swiss albino mice. Hum Exp Toxicol 33(12):1199–1208. 10.1177/0960327114527627.24648242
Saito M, Arakaki R, Yamada A, . 2016. Molecular mechanisms of nickel allergy. Int J Mol Sci 17(2):202. 10.3390/ijms17020202.26848658
Salcedo-Bellido I, Gutierrez-Gonzalez E, Garcia-Esquinas E, . 2021. Toxic metals in toenails as biomarkers of exposure: A review. Environ Res 197:111028. 10.1016/j.envres.2021.111028.33753073
Salnikow K, Li X, Lippmann M. 2004. Effect of nickel and iron co-exposure on human lung cells. Toxicol Appl Pharmacol 196(2):258–265. 10.1016/j.taap.2004.01.003.15081272
Sanford WE, Nieboer E. 1992. Renal toxicity of nickel in humans. In: Nieboer E, Nriagu JO, eds. Nickel and human health: Current perspectives: Proceedings of the fourth international conference on nickel metabolism and toxicology; September 1988, Helsinki, Finland. New York: John Wiley & Sons, Inc., 123–134.
Santore RC, Croteau K, Ryan AC, . 2021. A review of water quality factors that affect nickel bioavailability to aquatic organisms: Refinement of the biotic ligand model for nickel in acute and chronic exposures. Environ Toxicol Chem 40(8):2121–2134. 10.1002/etc.5109.33945644
Santucci B, Manna F, Cannistraci C, . 1994. Serum and urine concentrations in nickel-sensitive patients after prolonged oral administration. Contact Dermatitis 30(2):97–101. 10.1111/j.1600-0536.1994.tb00571.x.8187509
Sañudo-Wilhelmy SA, Gill GA. 1999. Impact of the Clean Water Act on the levels of toxic metals in urban estuaries: The Hudson River Estuary revisited. Environ Sci Technol 33(20):3477–3481. 10.1021/es981130z.
Saquib Q, Attia SM, Ansari SM, . 2017. p53, MAPKAPK-2 and caspases regulate nickel oxide nanoparticles induce cell death and cytogenetic anomalies in rats. Int J Biol Macromol 105(Pt 1):228–237. 10.1016/j.ijbiomac.2017.07.032.28690165
Saquib Q, Siddiqui MA, Ahmad J, . 2018. Nickel oxide nanoparticles induced transcriptomic alterations in HepG2 cells. Adv Exp Med Biol 1048:163–174. 10.1007/978-3-319-72041-8_10.29453538
Sarkar B. 1984. Nickel metabolism. IARC Sci Publ (53):367–384.6398287
Sax SN, Bennett DH, Chillrud SN, . 2006. A cancer risk assessment of inner-city teenagers living in New York City and Los Angeles. Environ Health Perspect 114(10):1558–1566. 10.1289/ehp.8507.17035143
Saxholm HJ, Reith A, Brøgger A. 1981. Oncogenic transformation and cell lysis in C3H/10T 1/2 cells and increased sister chromatid exchange in human lymphocytes by nickel subsulfide. Cancer Res 41(10):4136–4139.7285017
Saylor DM, Craven BA, Chandrasekar V, . 2018. Predicting patient exposure to nickel released from cardiovascular devices using multi-scale modeling. Acta Biomater 70:304–314. 10.1016/j.actbio.2018.01.024.29408403
Sazakli E, Leotsinidis M. 2017. Hair biomonitoring and health status of a general population exposed to nickel. J Trace Elem Med Biol 43:161–168. 10.1016/j.jtemb.2017.02.001.28215719
Schachter EN, Rohr A, Habre R, . 2020. Indoor air pollution and respiratory health effects in inner city children with moderate to severe asthma. Air Qual Atmos Health 13(2):247–257. 10.1007/s11869-019-00789-3.
Schroeder HA, Mitchener M. 1971. Toxic effects of trace elements on the reproduction of mice and rats. Arch Environ Health 23(2):102–106. 10.1080/00039896.1971.10665963.5558140
Schroeder HA, Balassa JJ, Vinton WH. 1964. Chromium, lead, cadmium, nickel and titanium in mice: Effect on mortality, tumors and tissue levels. J Nutr 83(3):239–250. 10.1093/jn/83.3.239. 2/22/2021.14191424
Schroeder HA, Mitchener M, Nason AP. 1974. Life-term effects of nickel in rats: survival, tumors, interactions with trace elements and tissue levels. J Nutr 104(2):239–243. 10.1093/jn/104.2.239. 2/22/2021.4810985
Schroeder WH, Dobson M, Kane DM, . 1987. Toxic trace elements associated with airborne particulate matter: a review. JAPCA 37(11):1267–1285. 10.1080/08940630.1987.10466321.3327920
Schwerdtle T, Hartwig A. 2006. Bioavailability and genotoxicity of soluble and particulate nickel compounds in cultured human lung cells. Mater Werks 37(6):521–525. 10.1002/mawe.200600030.
Scudlark JR, Conko KM, Church TM. 1994. Atmospheric wet deposition of trace elements to Chesapeake Bay: CBAD study year 1 results. Atmos Environ 28(8):1487–1498. 10.1016/1352-2310(94)90209-7.
Sedlak DL, Phinney JT, Bedsworth WW. 1997. Strongly complexed Cu and Ni in wastewater effluents and surface runoff. Environ Sci Technol 31:3010–3016.
Seidenberg JM, Anderson DG, Becker RA. 1986. Validation of an in vivo developmental toxicity screen in the mouse. Teratog Carcinog Mutagen 6(5):361–374. 10.1002/tcm.1770060503.2878502
Sen P, Costa M. 1986. Pathway of nickel uptake influences its interaction with heterochromatic DNA. Toxicol Appl Pharmacol 84(2):278–285. 10.1016/0041-008x(86)90135-3.3715875
Sen P, Conway K, Costa M. 1987. Comparison of the localization of chromosome damage induced by calcium chromate and nickel compounds. Cancer Res 47(8):2142–2147.3829003
Senoh H, Kano H, Suzuki M, . 2017. Comparison of single or multiple intratracheal administration for pulmonary toxic responses of nickel oxide nanoparticles in rats. J Occup Health 59(2):112–121. 10.1539/joh.16-0184-OA.27980250
Serita F, Kyono H, Seki Y. 1999. Pulmonary clearance and lesions in rats after a single inhalation of ultrafine metallic nickel at dose levels comparable to the threshold limit value. Ind Health 37(4):353–363. 10.2486/indhealth.37.353.10547950
Seyedalipour B, Anoosha F, Taravati A, . 2017. An evaluation of biochemical and hematological parameters of blood in male rats after exposure to nickel and nickel chloride nanoparticles. J Babol Univ Med Sci 19(11):58–66. 10.18869/acadpub.jbums.19.11.58. 2017.
Shannon HS, Julian JA, Roberts RS. 1984a. A mortality study of 11,500 nickel workers. J Natl Cancer Inst 73(6):1251–1258. 10.1093/jnci/73.6.1251.6595436
Shannon HS, Julian JA, Muir DC, . 1984b. A mortality study of Falconbridge workers. IARC Sci Publ (53):117–124.
Shannon HS, Walsh C, Jadon N, . 1991. Mortality of 11,500 nickel workers--extended follow up and relationship to environmental conditions. Toxicol Ind Health 7(4):277–294. 10.1177/074823379100700404.1776158
Shinohara N, Zhang G, Oshima Y, . 2017. Kinetics and dissolution of intratracheally administered nickel oxide nanomaterials in rats. Part Fibre Toxicol 14(1):48. 10.1186/s12989-017-0229-x.29183341
Shirakawa T, Kusaka Y, Fujimura N, . 1990. Hard metal asthma: cross immunological and respiratory reactivity between cobalt and nickel? Thorax 45(4):267–271. 10.1136/thx.45.4.267.2356553
Shoeb M, Meier HCS, Antonini JM. 2021. Telomeres in toxicology: Occupational health. Pharmacol Ther 220:107742. 10.1016/j.pharmthera.2020.107742.33176178
Shoeb M, Kodali VK, Farris BY, . 2017. Oxidative stress, DNA methylation, and telomere length changes in peripheral blood mononuclear cells after pulmonary exposure to metal-rich welding nanoparticles. NanoImpact 5:61–69. 10.1016/j.impact.2017.01.001.30734006
Shoeb M, Meighan T, Kodali VK, . 2024. TERT-independent telomere elongation and shelterin dysregulation after pulmonary exposure to stainless-steel welding fume in-vivo. Environ Res 250:118515. 10.1016/j.envres.2024.118515.38373547
Siller GM, Seymour GJ. 1994. Kinetics and specificity of nickel hypersensitivity in the murine model. Australas J Dermatol 35(2):77–81. 10.1111/j.1440-0960.1994.tb00901.x.7702492
Simonato L, Fletcher AC, Andersen A, . 1991. A historical prospective study of European stainless steel, mild steel, and shipyard welders. Br J Ind med 48(3):145–154. 10.1136/oem.48.3.145.2015204
Singh I. 1984. Induction of gene conversion and reverse mutation by manganese sulphate and nickel sulphate in Saccharomyces cerevisiae. Mutat Res 137(1):47–49. 10.1016/0165-1218(84)90111-3.6379438
Sjövall P, Christensen OB, Möller H. 1987. Oral hyposensitization in nickel allergy. J Am Acad Dermatol 17(5, Part 1):774–778. 10.1016/S0190-9622(87)70262-X.3316317
Smith SR. 1994. Effect of soil pH on availability to crops of metals in sewage sludge-treated soils. I. Nickel, copper and zinc uptake and toxicity to ryegrass. Environ Pollut 85:321–327.15091663
Smith JC, Hackley B. 1968. Distribution and excretion of nickel-63 administered intravenously to rats. J Nutr 95(4):541–546. 10.1093/jn/95.4.541.5665656
Smith MK, George EL, Stober JA, . 1993. Perinatal toxicity associated with nickel chloride exposure. Environ Res 61(2):200–211. 10.1006/enrs.1993.1064.8495662
Sobti RC, Gill RK. 1989. Incidence of micronuclei and abnormalities in the head of spermatozoa caused by the salts of a heavy metal, nickel. Cytologia 54(2):249–253. 10.1508/cytologia.54.249.
Sokolov AV, Moiseenko TI, Gashkina NA, . 2023. Modeling and predicting the environment state in the impact area of a copper-nickel plant: a balanced model of the transformations of atmospheric deposition at the catchment and in lake. Geochem Int 61(7):768–779.
Solomons NW, Viteri F, Shuler TR, . 1982. Bioavailability of nickel in man: effects of foods and chemically-defined dietary constituents on the absorption of inorganic nickel. J Nutr 112(1):39–50. 10.1093/jn/112.1.39.6798174
Sorahan T. 2004. Mortality of workers at a plant manufacturing nickel alloys, 1958–2000. Occup Med (Lond) 54(1):28–34. 10.1093/occmed/kqg127. 2/22/2021.14963251
Sörme L, Lagerkvist R. 2002. Sources of heavy metals in urban wastewater in Stockholm. Sci Total Environ 298(1):131–145. 10.1016/S0048-9697(02)00197-3.12449334
Spiegelberg T, Kördel W, Hochrainer D. 1984. Effects of NiO inhalation on alveolar macrophages and the humoral immune systems of rats. Ecotoxicol Environ Saf 8(6):516–525. 10.1016/0147-6513(84)90011-3.6391900
Springborn Laboratories. 2000a. A one-generation reproduction range-finding study in rats with nickel sulfate hexahydrate. Spencerville, OH: Springborn Laboratories, Inc. SLI Study No. 3472.3.
Springborn Laboratories. 2000b. An oral (gavage) two-generation reproduction toxicity study in Sprague-Dawley rats with nickel sulfate hexahydrate. Final report. Volume 1 of 3. Spencerville, OH: Springborn Laboratories, Inc. SLI Study No. 3472.4.
Springborn Laboratories. 2002. A range-finding 90-day oral (gavage) toxicity study in Fischer 344 rats with nickel sulfate hexahydrate. Spencerville, OH: Springborn Laboratories, Inc. SLI Study No. 3472.6.
Spruit D, Bongaarts PJ. 1977. Nickel content of plasma, urine and hair in contact dermatitis. Dermatologica 154(5):291–300. 10.1159/000251084.863071
Srivastava RC, Husain MM, Srivastava SK, . 1995. Effect of pre-exposure to cadmium and silver on nickel induced toxic manifestations in mice: possible role of ceruloplasmin and metallothionein. Bull Environ Contam Toxicol 54(5):751–759. 10.1007/bf00206109.7780220
Stedman DH, Hikade D. 1980. Nickel toxicology. In: Brown SS, Sunderman FW, eds. Second international conference on nickel toxicology, Swansea, Wales, UK, September 3 to 5, 1980. London, UK: Academic Press, 183–186.
Stephenson T, Lawson PS, Rudd T, . 1987. Mechanism of metal removal in activated sludge. J Environ Eng 113(5):1074–1087.
Stoessel RP, Michaelis W. 1986. Wet and dry deposition of metals. In: Proceedings of the 2nd international conference on environmental contamination. Amsterdam, The Netherlands: CEP Consultants, Ltd., 85–88.
Suedel BC, Boraczek JA, Peddicord RK, . 1994. Tropic transfer and biomagnification potential of contaminants in aquatic ecosystems. Rev Environ Contam Toxicol 136:21–89.8029491
Suh M, Casteel S, Dunsmore M, . 2019. Bioaccessibility and relative oral bioavailability of cobalt and nickel in residential soil and dust affected by metal grinding operations. Sci Total Environ 660:677–689. 10.1016/j.scitotenv.2018.12.317.30641396
Sumino K, Hayakawa K, Shibata T, . 1975. Heavy metals in normal Japanese tissues. Amounts of 15 heavy metals in 30 subjects. Arch Environ Health 30(10):487–494. 10.1080/00039896.1975.10666759.1180571
Sunderman FW. 1986. Sources of exposure and biological effects of nickel. IARC Sci Publ (71):79–92.3770862
Sunderman FW. 1993. Biological monitoring of nickel in humans. Scand J Work Environ Health 19(Suppl 1):34–38.8159970
Sunderman FW, Maenza RM. 1976. Comparisons of carcinogenicities of nickel compounds in rats. Res Commun Chem Pathol Pharmacol 14(2):319–330.940963
Sunderman FW, Horak E. 1981. Biochemical indices of nephrotoxicity, exemplified by studies of nickel nephropathy. In: Brown SS, Davies DS, eds. Organ-directed toxicity: Chemical indices and mechanisms. London, UK: Pergamon Press, 52–64.
Sunderman FW, McCully KS. 1983. Effects of manganese compounds on carcinogenicity of nickel subsulfide in rats. Carcinogenesis 4(4):461–465. 10.1093/carcin/4.4.461.6839419
Sunderman FW, Oskarsson A. 1991. Nickel. In: Merian E, ed. Metals and their compounds in the environment. New York, NY: VCH Verlagsgesellschaft, 1101–1126.
Sunderman FW, Shen SK, Mitchell JM, . 1978. Embryotoxicity and fetal toxicity of nickel in rats. Toxicol Appl Pharmacol 43(2):381–390. 10.1016/0041-008x(78)90017-0.635925
Sunderman FW, Aitio A, Morgan LG, . 1986. Biological monitoring of nickel. Toxicol Ind Health 2(1):17–78. 10.1177/074823378600200102.3538498
Sunderman FW, Dingle B, Hopfer SM, . 1988. Acute nickel toxicity in electroplating workers who accidently ingested a solution of nickel sulfate and nickel chloride. Am J Ind Med 14(3):257–266. 10.1002/ajim.4700140303.3189343
Sunderman FW, Morgan LG, Andersen A, . 1989a. Histopathology of sinonasal and lung cancers in nickel refinery workers. Ann Clin Lab Sci 19(1):44–50.2537054
Sunderman FW, Hopfer SM, Sweeney KR, . 1989b. Nickel absorption and kinetics in human volunteers. Proc Soc Exp Biol Med 191(1):5–11. 10.3181/00379727-191-42881.2717626
Sutunkova MP, Solovyeva SN, Minigalieva IA, . 2019. Toxic effects of low-level long-term inhalation exposures of rats to nickel oxide nanoparticles. Int J Mol Sci 20(7):1778. 10.3390/ijms20071778.30974874
Svenes KB, Andersen I. 1998. Distribution of nickel in lungs from former nickel workers. Int Arch Occup Environ Health 71(6):424–428. 10.1007/s004200050301.9766916
Sweeney LM, Gearhart JM. 2020. Examples of physiologically based pharmacokinetic modeling applied to risk assessment. In: Fisher JW, Gearhart JM, Lin Z, eds. Physiologically based pharmacokinetic (PBPK) modeling. Academic Press: 281–299. 10.1016/B978-0-12-818596-4.00011-4.
Syurin S, Vinnikov D. 2022. Occupational disease predictors in the nickel pyrometallurgical production: a prospective cohort observation. J Occup Med Toxicol 17(1):21. 10.1186/s12995-022-00362-2.36335380
Szakmáry E, Morvai V, Náray M, . 1995. Haemodynamic effect of nickel chloride in pregnant rats. Acta Physiol Hung 83(1):3–12.7660833
Takenaka S, Hochrainer D, Oldiges H. 1985. Alveolar proteinosis induced in rats by long-term inhalation of nickel oxide. In: Brown SS, Sunderman FW, eds. Progress in nickel toxicology. Proceedings of the 3rd international congress on nickel metabolism and toxicology. Oxford, UK: Blackwell, 89–92.
Tallkvist J, Tjälve H. 1994. Nickel absorption from perfused rat jejunal and ileal segments. Pharmacol Toxicol 75(5):233–243. 10.1111/j.1600-0773.1994.tb00354.x.7870692
Tam I, Schalock PC, González E, . 2020a. Patch testing results from the Massachusetts General Hospital Contact Dermatitis Clinic, 2007-2016. Dermatitis 31(3):202–208. 10.1097/der.0000000000000593.32209868
Tam I, Yu J, Ko LN, . 2020b. Patch testing with an extended metal allergen series at the Massachusetts General Hospital (2006-2017). Dermatitis 31(6):359–366. 10.1097/der.0000000000000609.32520762
Tan YM, Chan M, Chukwudebe A, . 2020. PBPK model reporting template for chemical risk assessment applications. Regul Toxicol Pharmacol 115:104691. 10.1016/j.yrtph.2020.104691.32502513
Tanaka I, Ishimatsu S, Matsuno K, . 1985. Biological half time of deposited nickel oxide aerosol in rat lung by inhalation. Biol Trace Elem Res 8(3):203–210. 10.1007/bf02917459.24257945
Tanaka I, Horie A, Haratake J, . 1988. Lung burden of green nickel oxide aerosol and histopathological findings in rats after continuous inhalation. Biol Trace Elem Res 16(1):19–26. 10.1007/bf02795330.2484532
Tanojo H, Hostýnek JJ, Mountford HS, . 2001. In vitro permeation of nickel salts through human stratum corneum. Acta Derm Venereol 81(Suppl 212):19–23. 10.1080/000155501753279596.
Taylor GJ, Crowder AA. 1983. Accumulation of atmospherically deposited metals in wetland soils of Sudbury, Ontario. Water Air Soil Pollut 19(1):29–42. 10.1007/BF00176793.
Tedeschi RE, Sunderman FW. 1957. Nickel poisoning. V. The metabolism of nickel under normal conditions and after exposure to nickel carbonyl. AMA Arch Ind Health 16(6):486–488.13478187
Templeton DM, Sunderman FW, Jr., Herber RF. 1994. Tentative reference values for nickel concentrations in human serum, plasma, blood, and urine: evaluation according to the TRACY protocol. Sci Total Environ 148(2–3):243–251. 10.1016/0048-9697(94)90400-6.8029699
Terpilowska S, Siwicki AK. 2018. Interactions between chromium(III) and iron(III), molybdenum(III) or nickel(II): Cytotoxicity, genotoxicity and mutagenicity studies. Chemosphere 201:780–789. 10.1016/j.chemosphere.2018.03.062.29550572
Thomas KW, Pellizzari ED, Berry MR. 1999. Population-based dietary intakes and tap water concentrations for selected elements in the EPA Region V National Human Exposure Assessment Survey (NHEXAS). J Expo Anal Environ Epidemiol 9:402–413.10554143
Thyssen JP, Maibach HI. 2008. Nickel release from earrings purchased in the United States: the San Francisco earring study. J Am Acad Dermatol 58(6):1000–1005. 10.1016/j.jaad.2008.03.017.18406493
Thyssen JP, Menne T. 2010. Metal allergy--a review on exposures, penetration, genetics, prevalence, and clinical implications. Chem Res Toxicol 23(2):309–318. 10.1021/tx9002726.19831422
Thyssen JP, Johansen JD, Menne T, . 2010. Effect of tobacco smoking and alcohol consumption on the prevalence of nickel sensitization and contact sensitization. Acta Derm Venereol 90(1):27–33. 10.2340/00015555-0772.20107722
Tien JK, Howson TE. 1981. Nickel and nickel alloys. In: Kirk-Othmer encyclopedia of chemical technology. Vol. 15. John Wiley and Sons, 787–801.
Togawa K, Le Cornet C, Feychting M, . 2016. Parental occupational exposure to heavy metals and welding fumes and risk of testicular germ cell tumors in offspring: A registry-based case-control study. Cancer Epidemiol Biomarkers Prev 25(10):1426–1434. 10.1158/1055-9965.Epi-16-0328.27439405
Tola S, Kilpiö J, Virtamo M. 1979. Urinary and plasma concentrations of nickel as indicators of exposure to nickel in an electroplating shop. J Occup Med 21(3):184–188.438908
Toman R, Massanyi P, Adamkovicova M, . 2012. Quantitative histological analysis of the mouse testis after the long-term administration of nickel in feed. J Environ Sci Health A Tox Hazard Subst Environ Eng 47(9):1272–1279. 10.1080/10934529.2012.672130.22540651
Torjussen W, Andersen I. 1979. Nickel concentrations in nasal mucosa, plasma, and urine in active and retired nickel workers. Ann Clin Lab Sci 9(4):289–298.485092
Tramontana M, Bianchi L, Hansel K, . 2020. Nickel allergy: epidemiology, pathomechanism, clinical patterns, treatment and prevention programs. Endocr Metab Immune Disord Drug Targets 20(7):992–1002. 10.2174/1871530320666200128141900.31994473
TRI22. 2024. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Toxics Release Inventory, U.S. Environmental Protection Agency.
Tsao YC, Gu PW, Liu SH, . 2017. Nickel exposure and plasma levels of biomarkers for assessing oxidative stress in nickel electroplating workers. Biomarkers 22(5):455–460. 10.1080/1354750x.2016.1252964.27775433
Tuchman M, Silverberg JI, Jacob SE, . 2015. Nickel contact dermatitis in children. Clin Dermatol 33(3):320–326. 10.1016/j.clindermatol.2014.12.008.25889133
Tundermann JH, Tien JK, Howson TE. 2013. Nickel and nickel alloys. In: Kirk-Othmer encyclopedia of chemical technology. John Wiley & Sons, Inc. 10.1002/0471238961.1409031120211404.a01.
Turk JL, Parker D. 1977. Sensitization with Cr, Ni and Zr salts and allergic type granuloma formation in the guinea pig. J Invest Dermatol 68(6):341–345. 10.1111/1523-1747.ep12496465.864275
USDT. 2018. 5112. Denominations, specifications, and design of coins. U.S. Code: Title 31: Money and finance. U.S. Department of Treasury. 341–362. https://www.govinfo.gov/content/pkg/USCODE-2018-title31/pdf/USCODE-2018-title31-subtitleIV-chap51-subchapII-sec5112.pdf.
USGS. 1998. Methods of analysis by the U.S. Geological Survey National Water Quality Laboratory—Determination of elements in whole-water digests using inductively coupled plasma–optical emission spectrometry and inductively coupled plasma–mass spectrometry. Denver, CO: U.S. Geological Survey. OFR 98–165.
USGS. 2000a. Concentrations of selected trace elements in fish tissue and concentrations of selected trace elements in fish tissue and streambed sediment in the Clark Fork-Pend Oreille and Spokane River Basins, Washington, Idaho, and Montana, 1998. U.S. Geological Survey. Water-Resources Investigation Report 00-4159.
USGS. 2000b. Trace elements and organochlorine compounds in bed sediment and fish tissue at selected sites in New Jersey streams- sources and effects. U.S. Geological Survey. Water-resources investigation report 99-4235. PB2002100855.
USGS. 2000c. Concentrations of selected trace elements in fish tissue and streambed sediment in the Clark Fork-Pend Oreille and Spokane River Basins, Washington, Idaho, and Montana, 1998. U.S. Geological Survey National Water-Quality Assessment Program.
USGS. 2006. Determination of elements in natural-water, biota, sediment, and soil samples using collision/reaction cell inductively coupled plasma–mass spectrometry. Chapter 1. Section B, Methods of the national water quality laboratory. Book 5, Laboratory analysis. Reston, VA: U.S. Geological Survey.
USGS. 2011. Trace elements and radon in groundwater across the United States, 1992–2003. Scientific Investigations Report. U.S. Geological Survey. SIR 2011–5059. http://pubs.usgs.gov/sir/2011/5059. May 22, 2024.
USGS. 2012. Nickel - makes stainless steel strong. U.S. Geological Survey. Fact Sheet 2012-3024. 10.3133/fs20123024.
USGS. 2013. Geochemical and mineralogical data for soils of the conterminous United States. U.S. Geological Survey. Data Series 801. http://pubs.usgs.gov/ds/801/. May 22, 2024.
USGS. 2016. Trace elements concentrations in pore water and surface water near the sediment-water interface in the Upper Columbia River, Washington (2015). U.S. Geological Survey. 10.5066/F73N21GJ.
USGS. 2017. Table 2. Physical and chemical characterization of sediment. Physical and chemical data from an evaluation of metal-contaminated sediments and pore water from the Upper Columbia River, Washington, 2013-2014. U.S. Geological Survey. 10.5066/F72F7KPC.
USGS. 2020. Assessing the influence of natural copper-nickel-bearing bedrocks of the Duluth Complex on water quality in Minnesota, 2013–15. Scientific Investigations Report. U.S. Geological Survey. SIR 2020-5039. 10.3133/sir20205039.
USGS. 2021. Mineral commodity summaries: nickel. U.S. Geological Survey. https://pubs.usgs.gov/periodicals/mcs2021/mcs2021-nickel.pdf. February 25, 2021.
USGS. 2023. 2018 Minerals yearbook: Nickel [advance release]. U.S. Geological Survey. https://pubs.usgs.gov/myb/vol1/2018/myb1-2018-nickel.pdf. May 22, 2024.
USGS. 2024. Nickel. Mineral commodity summaries. U.S. Geological Survey. https://pubs.usgs.gov/periodicals/mcs2024/mcs2024-nickel.pdf. May 22, 2024.
Uter W, Wolter J. 2018. Nickel and cobalt release from earrings and piercing jewellery - analytical results of a German survey in 2014. Contact Dermatitis 78(5):321–328. 10.1111/cod.12941.29282733
Uter W, Pfahlberg A, Gefeller O, . 2003. Risk factors for contact allergy to nickel - results of a multifactorial analysis. Contact Dermatitis 48(1):33–38. 10.1034/j.1600-0536.46.s4.29_102.x.12641576
Uter W, Bauer A, Belloni Fortina A, . 2021. Patch test results with the European baseline series and additions thereof in the ESSCA network, 2015-2018. Contact Dermatitis 84(2):109–120. 10.1111/cod.13704.32945543
Vaktskjold A, Talykova LV, Chashchin V, . 2006. Genital malformations in newborns of female nickel-refinery workers. Scand J Work Environ Health 32(1):41–50. 10.5271/sjweh.975.16539171
Vaktskjold A, Talykova LV, Chashchin VP, . 2007. Small-for-gestational-age newborns of female refinery workers exposed to nickel. Int J Occup Med Environ Health 20(4):327–338. 10.2478/v10001-007-0034-0.18165195
Vaktskjold A, Talykova LV, Chashchin VP, . 2008a. Maternal nickel exposure and congenital musculoskeletal defects. Am J Ind Med 51(11):825–833. 10.1002/ajim.20609.18655106
Vaktskjold A, Talykova LV, Chashchin VP, . 2008b. Spontaneous abortions among nickel-exposed female refinery workers. Int J Environ Health Res 18(2):99–115. 10.1080/09603120701498295.18365800
Valentine R, Fisher GL. 1984. Pulmonary clearance of intratracheally administered 63Ni3S2 in strain A/J mice. Environ Res 34(2):328–334. 10.1016/0013-9351(84)90101-4.6745234
van Hoogstraten IM, von Blomberg BM, Boden D, . 1991. Effects of oral exposure to nickel or chromium on cutaneous sensitization. Curr Probl Dermatol 20:237–241. 10.1159/000420029.1935215
Veien NK, Menné T. 1990. Nickel contact allergy and a nickel-restricted diet. Semin Dermatol 9(3):197–205.2206919
Veien NK, Hattel T, Justesen O, . 1987. Oral challenge with nickel and cobalt in patients with positive patch tests to nickel and/or cobalt. Acta Derm Venereol 67(4):321–325.2445151
Vuskovic M, Barbuti AM, Goldsmith-Rooney E, . 2013. Plasma anti-glycan antibody profiles associated with nickel level in urine. J Proteomics Bioinform 6(12):302–312. 10.4172/jpb.1000295.24737927
Vyskocil A, Viau C, Cízková M. 1994b. Chronic nephrotoxicity of soluble nickel in rats. Hum Exp Toxicol 13(10):689–693. 10.1177/096032719401301007.7826687
Vyskocil A, Senft V, Viau C, . 1994a. Biochemical renal changes in workers exposed to soluble nickel compounds. Hum Exp Toxicol 13(4):257–261. 10.1177/096032719401300406.8204311
Waalkes MP, Kasprzak KS, Ohshima M, . 1985. Protective effects of zinc acetate toward the toxicity of nickelous acetate in rats. Toxicology 34(1):29–41. 10.1016/0300-483x(85)90076-9.3969679
Wahlberg JE. 1976. Sensitization and testing of guinea pigs with nickel sulfate. Dermatologica 152(6):321–330. 10.1159/000251278.964426
Wahlberg JE, Lidén C. 2000. Cross-reactivity patterns of cobalt and nickel studied with repeated open applications (ROATs) to the skin of guinea pigs. Am J Contact Derm 11(1):42–48. 10.1016/S1046-199X(00)90031-9.
Waksvik H, Boysen M. 1982. Cytogenetic analyses of lymphocytes from workers in a nickel refinery. Mutat Res 103(2):185–190. 10.1016/0165-7992(82)90027-6.7057794
Waksvik H, Boysen M, Høgetveit AC. 1984. Increased incidence of chromosomal aberrations in peripheral lymphocytes of retired nickel workers. Carcinogenesis 5(11):1525–1527. 10.1093/carcin/5.11.1525.6488477
Wall LM, Calnan CD. 1980. Occupational nickel dermatitis in the electroforming industry. Contact Dermatitis 6(6):414–420. 10.1111/j.1600-0536.1980.tb04985.x.6449350
Wang Z-M, Biswas P. 2000. Nickel speciation and aerosol formation during combustion of kerosene doped with nickel nitrate aerosol in a premixed burner. Aerosol Sci Technol 33(6):525–535. 10.1080/02786820050195368.
Wang P, Ding Y, Liu M, . 2019. Modeling kinetics of Ni dissociation from humic substances based on WHAM 7. Chemosphere 221:254–262. 10.1016/j.chemosphere.2019.01.012.30640008
Wang YF, Shyu HW, Chang YC, . 2012. Nickel (II)-induced cytotoxicity and apoptosis in human proximal tubule cells through a ROS- and mitochondria-mediated pathway. Toxicol Appl Pharmacol 259(2):177–186. 10.1016/j.taap.2011.12.022.22245127
Wang YX, Sun Y, Huang Z, . 2016. Associations of urinary metal levels with serum hormones, spermatozoa apoptosis and sperm DNA damage in a Chinese population. Environ Int 94:177–188. 10.1016/j.envint.2016.05.022.27258659
Wantke F, Hemmer W, Jarisch R, . 1996. Patch test reactions in children, adults and the elderly. A comparative study in patients with suspected allergic contact dermatitis. Contact Dermatitis 34(5):316–319. 10.1111/j.1600-0536.1996.tb02214.x.8807222
Warner JS. 1984. Occupational exposure to airborne nickel in producing and using primary nickel products. IARC Sci Publ 53:419–437.
Warshaw EM, Aschenbeck KA, DeKoven JG, . 2017. Piercing and metal sensitivity: extended analysis of the North American Contact Dermatitis Group data, 2007-2014. Dermatitis 28(6):333–341. 10.1097/DER.0000000000000324.29135681
Warshaw EM, Schlarbaum JP, DeKoven JG, . 2019. Occupationally related nickel reactions: A retrospective analysis of the North American Contact Dermatitis Group data 1998-2016. Dermatitis 30(5):306–313. 10.1097/der.0000000000000516.31524759
Wehner AP, Craig DK. 1972. Toxicology of inhaled NiO and CoO in Syrian golden hamsters. Am Ind Hyg Assoc J 33(3):146–155. 10.1080/0002889728506624.5074671
Weischer CH, Kördel W, Hochrainer D. 1980. Effects of NiCl2 and NiO in Wistar rats after oral uptake and inhalation exposure respectively. Zentralbl Bakteriol Mikrobiol Hyg B 171(4–5):336–351.7456854
Weng LP, Wolthoorn A, Lexmond TM, . 2004. Understanding the effects of soil characteristics on phytotoxicity and bioavailability of nickel using speciation models. Environ Sci Technol 38:156–162.14740731
Werner MA, Thomassen Y, Hetland S, . 1999. Correlation of urinary nickel excretion with observed ‘total’ and inhalable aerosol exposures of nickel refinery workers. J Environ Monit 1(6):557–562. 10.1039/a906597k.11529189
Whanger PD. 1973. Effects of dietary nickel on enzyme activities and mineral contents in rats. Toxicol Appl Pharmacol 25(3):323–331. 10.1016/0041-008X(73)90306-2.4738000
WHO. 2000. Air quality guidelines for Europe. 2nd ed. World Health Organization. https://apps.who.int/iris/handle/10665/107335. November 29, 2022.
WHO. 2022. Guidelines for drinking-water quality. Fourth edition incorporating the first and second addenda. World Health Organization. https://www.who.int/publications/i/item/9789240045064. June 22, 2022.
Windom HL, Schropp SJ, Calder FD, . 1989. Natural trace metal concentrations in estuarine and coastal marine sediments of the southeastern United States. Environ Sci Technol 23:314–320.
Winger PV, Schultz DP, Johnson WW. 1990. Environmental contaminant concentrations in biota from the lower Savannah River, Georgia and South Carolina. Arch Environ Contam Toxicol 19(1):101–117. 10.1007/BF01059818.2331144
Wittsiepe J, Schnell K, Hilbig A, . 2009. Dietary intake of nickel and zinc by young children--results from food duplicate portion measurements in comparison to data calculated from dietary records and available data on levels in food groups. J Trace Elem Med Biol 23(3):183–194. 10.1016/j.jtemb.2009.03.007.19486828
Wong PK. 1988. Mutagenicity of heavy metals. Bull Environ Contam Toxicol 40(4):597–603. 10.1007/bf01688386.3285919
Wood JM. 1987. Biological processes involved in the cycling of elements between soil or sediments and the aqueous environment. Hydrobiologia 149:31–42.
Wood BW, Reilly CC, Nycaepir AP. 2004. Mouse-ear of pecan: a nickel deficiency. HortScience 39(6):1238–1242.
WQP. 2024. Nickel. Water quality portal. Advisory Committee on Water Information (ACWI); Agricultural Research Service (ARS); Environmental Protection Agency (EPA); National Water Quality Monitoring Council (NWQMC); United States Geological Survey (USGS). https://www.waterqualitydata.us/portal/. April 25, 2024.
WSDOT. 2006. Phase I: Preliminary environmental investigation of heavy metals in highway runoff. Olympia, WA: Washington State Department of Transportation. https://www.epa.gov/sites/default/files/2015-11/documents/prelimenvironmentalinvestigationheavymetals.pdf. May 23, 2024.
Wu S, Bai YN, Pu HQ, . 2015. Dynamic changes in DNA damage and repair biomarkers with employment length among nickel smelting workers. Biomed Environ Sci 28(9):679–682. 10.3967/bes2015.095.26464256
Wu L, Cui F, Ma J, . 2022. Associations of multiple metals with lung function in welders by four statistical models. Chemosphere 298:134202. 10.1016/j.chemosphere.2022.134202.35257699
Wu L, Cui F, Zhang S, . 2023. Associations between multiple heavy metals exposure and neural damage biomarkers in welders: A cross-sectional study. Sci Total Environ 869:161812. 10.1016/j.scitotenv.2023.161812.36706997
Wulf HC. 1980. Sister chromatid exchanges in human lymphocytes exposed to nickel and lead. Preliminary communication. Dan Med Bull 27(1):40–42.7398378
Xu X, Rao X, Wang T-Y, . 2012. Effect of co-exposure to nickel and particulate matter on insulin resistance and mitochondrial dysfunction in a mouse model. Part Fibre Toxicol 9:40–40. 10.1186/1743-8977-9-40.23126276
Ying Z, Xu X, Chen M, . 2013. A synergistic vascular effect of airborne particulate matter and nickel in a mouse model. Toxicol Sci 135(1):72–80. 10.1093/toxsci/kft136.23788629
Yokota K, Johyama Y, Kunitani Y, . 2007. Urinary elimination of nickel and cobalt in relation to airborne nickel and cobalt exposures in a battery plant. Int Arch Occup Environ Health 80(6):527–531. 10.1007/s00420-006-0159-7.17136408
Young TC, DePinto JV, Seger ES. 1982. Transport and fate of heavy metals in Onondaga Lake, New York. Bull Environ Contam Toxicol 29:554–561.7150803
Yu CP, Hsieh TH, Oller AR, . 2001. Evaluation of the human nickel retention model with workplace data. Regul Toxicol Pharmacol 33(2):165–172. 10.1006/rtph.2000.1457.11350199
Yu S, Liu F, Wang C, . 2018. Role of oxidative stress in liver toxicity induced by nickel oxide nanoparticles in rats. Mol Med Rep 17(2):3133–3139. 10.3892/mmr.2017.8226.29257258
Zaitseva NV, Zemlyanova MA, Ignatova AM, . 2018. Morphological changes in lung tissues of mice caused by exposure to nano-sized particles of nickel oxide. Nanotechnol Russ 13(7–8):393–399. 10.1134/s199507801804016x.
Zaroogian GE, Johnson M. 1984. Nickel uptake and loss in the bivalves Crassostrea virginica and Mytilus edulis. Arch Environ Contam Toxicol 13:411–418.6465950
Zhang Q, Kusaka Y, Donaldson K. 2000. Comparative injurious and proinflammatory effects of three ultrafine metals in macrophages from young and old rats. Inhal Toxicol 12(Suppl 3):267–273. 10.1080/08958378.2000.11463222.26368625
Zhang X, Tanwar VS, Jose CC, . 2022. Transcriptional repression of E-cadherin in nickel-exposed lung epithelial cells mediated by loss of Sp1 binding at the promoter. Mol Carcinog 61(1):99–110. 10.1002/mc.23364.34727382
Zissu D, Cavelier C, De Ceaurriz J. 1987. Experimental sensitization of guinea-pigs to nickel and patch testing with metal samples. Food Chem Toxicol 25(1):83–85. 10.1016/0278-6915(87)90309-7.3817663