# ERRATUM

In Appendix A, Table A-7 the aerosol concentration was corrected to 0.00025 mg Ni/m^a^ and a new footnote (f) was added to explain how the time-weighted average (TWA) deposition fraction was calculated. In Table A-8, the human deposition fraction (DF) was corrected to 0.2273. Under the Contributors and Reviewers section, a footnote was added to the Peer Reviewers list. These corrections do not affect the calculations, and the Minimal Risk Levels (MRLs) remain unchanged.