# CONTRIBUTORS & REVIEWERS

## CHEMICAL MANAGER TEAM

- Custodio Muianga, M.P.H., Ph.D., C.H.M.M. (Lead)
  Franco Scinicariello, M.D., M.P.H.
  Gaston Casillas, Ph.D.
  Mohammad Shoeb, Ph.D.
  ATSDR, Office of Innovation and Analytics, Toxicology Section, Atlanta, GA
- Adriana Antezana, M.P.H.
  Rekha Balachandran, Ph.D.
  Hannah Derrick, B.S.
  Kerry Diskin, D.Sc.
  Andrea Chiger, M.P.H.
  Meghan Lynch, M.P.H, D.Sc.
  Abt Associates, Cambridge, MA
- Lisa Ingerman, Ph.D., D.A.B.T.
  Heather Carlson-Lynch, M.S., D.A.B.T.
  Savannah Sierco, M.S.
  SRC, Inc., North Syracuse, NY

## REVIEWERS

Interagency Minimal Risk Level Workgroup:

- Includes ATSDR; National Center for Environmental Health (NCEH); National Institute for Occupational Safety and Health (NIOSH); U.S. Environmental Protection Agency (EPA); National Toxicology Program (NTP).

Additional reviews for science and/or policy:

- ATSDR, Office of Community Health Hazard Assessment; ATSDR, Office of Capacity Development and Applied Prevention Science; ATSDR, Office of Science; Department of Defense; NCEH, Division of Laboratory Sciences; NCEH, Division of Environmental Health Science and Practice; EPA, Office of Research and Development; EPA, Office of Water.

## PEER REVIEWERS

1. David C. Dorman, DVM, Ph.D., DABT, DABVT, ATS, North Carolina State University
2. Samuel Buxton, Ph.D., DABT, ERT, NiPERA Inc., Durham, North Carolina^1^
  1 External peer-reviewer for pre-public comment version only
3. Orish Ebere Orisakwe Ph.D., ERT, ATS, FRSC, University of Port Harcourt
4. Jerome Nriagu, Ph.D., Sc.D.; Emeritus Professor, Environmental Health Sciences Research Professor, Center for Human Growth and Development; University of Michigan, School of Public Health^2^
  2 External peer-reviewer for post-public comment version only

These experts collectively have knowledge of toxicology, chemistry, and/or health effects. All reviewers were selected in conformity with Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

ATSDR scientists review peer reviewers’ comments and determine whether changes will be made to the profile based on comments. The peer reviewers’ comments and responses to these comments are part of the administrative record for this compound.

The listing of peer reviewers should not be understood to imply their approval of the profile’s final content. The responsibility for the content of this profile lies with ATSDR.