# VERSION HISTORY

Date | Description
May 2026 | Erratum added
October 2024 | Final toxicological profile released
August 2023 | Draft for public comment toxicological profile released
August 2005 | Final toxicological profile released
September 1997 | Final toxicological profile released
October 1993 | Final toxicological profile released
October 1988 | Final toxicological profile released