# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding nickel in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for nickel.

Table 7-1 Regulations and Guidelines Applicable to Nickel

Agency | Description | Information | Reference
Air
EPA | RfC
EPA | Nickel, soluble salts | Not evaluated | IRIS 1994
EPA | Nickel refinery dust | Not evaluated | IRIS 2006
EPA | Nickel subsulfide | Not evaluated | IRIS 2002
WHO | Air quality guidelines | | WHO 2000
WHO | Incremental risk for 1 μg/m^3^ nickel in air | 3.8×10^−4^ | WHO 2000
Water & Food
EPA | Drinking water standards and health advisories | | EPA 2018a
EPA | Nickel | | EPA 2018a
EPA | 1-day health advisory for a 10-kg child | 1 mg/L | EPA 2018a
EPA | 10-day health advisory for a 10-kg child | 1 mg/L | EPA 2018a
EPA | DWEL | 0.7 mg/L | EPA 2018a
EPA | Lifetime health advisory | 0.1 mg/L | EPA 2018a
EPA | National primary drinking water regulations | Not listed | EPA 2009
EPA | RfD
EPA | Nickel, soluble salts | 0.02 mg/kg/day | IRIS 1994
EPA | Nickel refinery dust | Not evaluated | IRIS 2006
EPA | Nickel subsulfide | Not evaluated | IRIS 2002
WHO | Guideline value | | WHO 2022
WHO | Nickel | 0.07 mg/L | WHO 2022
FDA | Substances added to food (formerly EAFUS)
FDA | Nickel | GRAS | FDA 2023a
FDA | Nickel | Permitted as a component of paper/paperboard in contact with dry food | FDA 2023b
FDA | Allowable level of nickel in bottled water | 0.1 mg/L | FDA 2022
Cancer
HHS | Carcinogenicity classification | | NTP 2021
HHS | Nickel compounds | Known to be human carcinogens | NTP 2021
HHS | Nickel metallic | Reasonably anticipated to be a human carcinogen | NTP 2021
EPA | Carcinogenicity classification
EPA | Nickel, soluble salts | Not evaluated | IRIS 1994
EPA | Nickel refinery dust | A^a^ | IRIS 2006
EPA | Nickel subsulfide | A^a^ | IRIS 2002
EPA | Inhalation unit risk
EPA | Nickel refinery dust | 0.00024 (µg/m^3^)^−1^ | IRIS 2006
EPA | Nickel subsulfide | 0.00048 (µg/m^3^)^−1^ | IRIS 2002
IARC | Carcinogenicity classification
IARC | Nickel compounds | Group 1^c^ | IARC 2012
IARC | Nickel, metallic | Group 2B^d^ | IARC 1990
Occupational
OSHA | PEL (8-hour TWA) for general industry, construction, and shipyards | | OSHA 2021a, 2021b, 2021c
OSHA | Nickel, metal, and insoluble compounds (as Ni) | 1 mg/m^3^ | OSHA 2021a, 2021b, 2021c
OSHA | Nickel, soluble compounds (as Ni) | 1 mg/m^3^ | OSHA 2021a, 2021b, 2021c
NIOSH | REL (up to 10-hour TWA)
NIOSH | Nickel metal and other compounds (as Ni) | 0.015 mg/m^3^ ^e^ | NIOSH 2019
Emergency Criteria
NIOSH | IDLH
NIOSH | Nickel metal and other compounds (as Ni) | 10 mg/m^3^ ^e^ | NIOSH 2019
EPA | AEGLS-air^f^ | No data | EPA 2018b
DOE | PACs-air^h^ | | DOE 2018a
DOE | Nickel | | DOE 2018a
DOE | PAC-1 | 4.5 mg/m^3^ | DOE 2018a
DOE | PAC-2 | 50 mg/m^3^ | DOE 2018a
DOE | PAC-3 | 99 mg/m^3^ | DOE 2018a
DOE | Nickel acetate tetrahydrate | | DOE 2018a
DOE | PAC-1 | 13 mg/m^3^ | DOE 2018a
DOE | PAC-2 | 140 mg/m^3^ | DOE 2018a
DOE | PAC-3 | 830 mg/m^3^ | DOE 2018a
DOE | Nickel(II) carbonate | | DOE 2018a
DOE | PAC-1 | 0.61 mg/m^3^ | DOE 2018a
DOE | PAC-2 | 6.6 mg/m^3^ | DOE 2018a
DOE | PAC-3 | 40 mg/m^3^ | DOE 2018a
DOE | Nickel chloride | | DOE 2018a
DOE | PAC-1 | 0.66 mg/m^3^ | DOE 2018a
DOE | PAC-2 | 22 mg/m^3^ | DOE 2018a
DOE | PAC-3 | 130 mg/m^3^ | DOE 2018a
DOE | Nickel cyanide | | DOE 2018a
DOE | PAC-1 | 1.1 mg/m^3^ | DOE 2018a
DOE | PAC-2 | 13 mg/m^3^ | DOE 2018a
DOE | PAC-3 | 75 mg/m^3^ | DOE 2018a
DOE | Nickel(II) nitrate | | DOE 2018a
DOE | PAC-1 | 0.93 mg/m^3^ | DOE 2018a
DOE | PAC-2 | 10 mg/m^3^ | DOE 2018a
DOE | PAC-3 | 61 mg/m^3^ | DOE 2018a
DOE | Nickel oxide | | DOE 2018a
DOE | PAC-1 | 0.76 mg/m^3^ | DOE 2018a
DOE | PAC-2 | 220 mg/m^3^ | DOE 2018a
DOE | PAC-3 | 1,300 mg/m^3^ | DOE 2018a
DOE | Nickel sulfamate | | DOE 2018a
DOE | PAC-1 | 1.3 mg/m^3^ | DOE 2018a
DOE | PAC-2 | 12 mg/m^3^ | DOE 2018a
DOE | PAC-3 | 71 mg/m^3^ | DOE 2018a
DOE | Nickel sulfate | | DOE 2018a
DOE | PAC-1 | 0.79 mg/m^3^ | DOE 2018a
DOE | PAC-2 | 8.6 mg/m^3^ | DOE 2018a
DOE | PAC-3 | 51 mg/m^3^ | DOE 2018a

a A: human carcinogen.

b B2: probable human carcinogen.

c Group 1: carcinogenic to humans.

d Group 2B: possibly carcinogenic to humans

e Potential occupational carcinogen.

f Definitions of AEGL terminology are available from EPA (2018c).

g Not recommended due to insufficient data.

h Definitions of PAC terminology are available from DOE (2018b).

AEGL = acute exposure guideline levels; HHS = Department of Health and Human Services; DOE = Department of Energy; DWEL = drinking water equivalent level; EAFUS = Everything Added to Food in the United States; EPA = U.S. Environmental Protection Agency; FDA = Food and Drug Administration; GRAS = Generally Recognized As Safe; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = Protective Action Criteria; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TWA = time-weighted average; WHO = World Health Organization