# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Nickel is a transition metal in group 10 of the periodic table following iron and cobalt (Kerfoot 2012). Its outer shell of electrons has a 3d^8^ 4s^2^ configuration (Haynes et al. 2015). Nickel occurs naturally in the Earth’s crust. While nickel can exist in oxidation states −1, 0, +2, +3, and +4, its only important oxidation state is nickel (+2) under normal environmental conditions. Information regarding the chemical identity of nickel and nickel compounds is presented in Table 4-1.

Table 4-1 Chemical Identity of Nickel and Selected Nickel Compounds

Characteristic | Nickel^a^ | Nickel acetate^b^ | Nickel ammonium sulfate^c^ | Nickel carbonate^d^
Synonym(s) and Registered trade name(s) | CI 77775; NI 0901-S; NI 270; NI 4303T; Nickel 200; Nickel 201; Nickel 205; Nickel 207; Nickel 270; Nickel sponge; NI 0901-S (Harshaw); NP-2; Raney alloy; Raney nickel; RCH 55/5 | Nickel (II) acetate; nickelous acetate; nickel diacetate; acetic acid, nickel(2+) salt; AI3-26110; nickel(2+) acetate | Nickel (II) ammonium sulfate; Diammonium nickel bis(sulphate); Ammonium disulfatonickelate(II); Sulfuric acid, ammonium nickel(2+) salt (2:2:1); diazanium; nickel(2+);disulfate; ammonium nickel sulfate (anhydrous); ammonium nickel(2+) sulfate (2/1/2) | CI 7779; Carbonic acid, nickel (2+) salt; nickel (II) carbonate; nickelous carbonate
Chemical formula | Ni | C_4_H_6_NiO_4_ | Ni (NH_4_)_2_(SO_4_)_2_^e^ | NiCO_3_
SMILES | [Ni] | CC(=O)[O-].; CC(=O)[O-].[Ni+2] | [NH4+].[NH4+].; [O-]S(=O)(=O)[O-].; [O-]S(=O)(=O); [O-].[Ni+2] | C(=O)([O-]); [O-].[Ni+2]
Chemical structure | Ni | A graphic depicting the chemical structure of Nickel acetate (C4h7Ni04a) | A graphic depicting the chemical structure of Nickel ammonium sulfate (Ni (NH4)2(SO4)2a) | A graphic depicting the chemical structure of Nickel carbonate (NiCO3a)
CAS registry number | 7440-02-0 | 373-02-4; 14998-37-9 (EU) | 15699-18-0 | 3333-67-3; 16337-84-1 (EU); 18195-55-6 (EU); 39380-74-0 (EU)

Characteristic | Nickel chloride^f^ | Nickel cyanide^g^ | Nickel oxide^h^ | Nickel nitrate^i^
Synonym(s) and Registered trade name(s) | Nickel (2+) chloride; nickel dichloride; nickel(II) chloride; nickelous chloride | Dicyanonickel; Nickel dicyanide; Nickel (II) cyanide | Bunsenite; CI 77777; Green nickel oxide; mononickel oxide; nickel (II) oxide; nickel(2+) oxide; nickel protoxide | Nickel dinitrate; nickel (II) nitrate; nickel(2+) nitrate; nickelous nitrate; nitric acid, nickel(II) salt; nitric acid, nickel(2+) salt
Chemical formula | NiCl_2_ | C_2_N_2_Ni | NiO | Ni (NO_3_)_2_
SMILES | Cl[Ni]Cl | [C-]#N.; [C-]#N.[Ni+2] | O=[Ni] | [N+](=O)([O-]); [O-].[N+](=O); ([O-])[O-].[Ni+2]
Chemical structure | Cl−Ni−Cl | CN−Ni−CN | Ni−O | A graphic showing the chemical structure of Nickel Nitrate (Ni(No3)2a)
CAS registry number | 7718-54-9; 37211-05-5 (EU and NZ) | 557-19-7 | 1313-99-1; 34492-97-2; 11099-02-8 | 13138-45-9; 13478-00-7 (hexahydrate); 14216-75-2 (EU)

Characteristic | Nickel subsulfide^j^ | Nickel sulfamate^k^ | Nickel sulfate^l^
Synonym(s) and Registered trade name(s) | Trinickel disulfide; Heazlewoodite; nickel subsulphide; nickel sulfide; alpha-nickel sulfide (3:2) crystalline; nickel sulphide; nickel tritadisulphide | Nickel bis(sulphamidate); nickel (II) sulfamate; Aeronikl 250; Aeronikl 400; Aeronikl 575; sulfamic acid, nickel(2+) salt (2:1); Nickel aminosulfonate | NCI-C60344; Nickel (II) sulfate; nickelous sulfate; nickel(2+) sulfate; nickel sulphate; sulfuric acid, nickel(2+) salt; sulphuric acid, nickel (II) salt
Chemical formula | Ni_3_S_2_ | Ni(SO_3_NH_2_)_2_ | NiSO_4_
SMILES | [S-2].[S-2].[Ni].[Ni+2].[Ni+2] | NS(=O)(=O); [O-].NS(=O)(=O)[O-].[Ni+2] | [O-]S(=O)(=O)[O-].[Ni+2]
Chemical structure | Ni-Ni-Ni=S=S | A graphic showing the chemical structure of Nickel sulfamate (Ni(SO3NH2)2k) | A graphic showing the chemical structure of Nickel Sulfate (NIS)4a)
CAS registry number | 12035-72-2 | 13770-89-3 | 7786-81-4; 15244-37-8 (EU)

a NLM 2024a unless otherwise specified.

b NLM 2024b unless otherwise specified.

c NLM 2024c unless otherwise specified.

d NLM 2024d unless otherwise specified.

e Haynes et al. 2015.

f NLM 2024e unless otherwise specified.

g NLM 2024f unless otherwise specified.

h NLM 2024g unless otherwise specified.

i NLM 2024h unless otherwise specified.

j NLM 2024i unless otherwise specified.

k NLM 2024j unless otherwise specified.

l NLM 2024k unless otherwise specified.

CAS = Chemical Abstract Service; EU = European Union; NZ = New Zealand; SMILES = simplified molecular-input line-entry system

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Nickel exists in the solid state and is a hard, lustrous, silvery white metal that takes on a high polish (Haynes et al. 2015). Nickel has typical metallic properties; it is malleable, ductile, ferromagnetic, and a good conductor of both heat and electricity (Haynes et al. 2015). Nickel forms useful alloys with many metals. It is added to metals to increase their hardness, strength, and corrosion resistance. The most familiar are nickeliferous alloys used in stainless steel and copper nickel alloys used in coinage metal.

Nickel ammonium sulfate, nickel sulfate, nickel chloride, and nickel nitrate usually exist as hexahydrates, while nickel acetate, nickel cyanide, and nickel sulfamate are in the form of a tetrahydrate (Haynes et al. 2015). Nickel compounds are also solid, and colors include a yellow-brown or a blue-green color.

Metallic nickel is insoluble in water and slightly soluble in dilute acid. Nickel and its compounds are nonvolatile and exist in the atmosphere in particulate form. Information regarding physical and chemical properties of nickel and nickel compounds is presented in Table 4-2.

Table 4-2 Physical and Chemical Properties of Nickel and Selected Nickel Compounds

Property | Nickel^a^ | Nickel acetate^b^ | Nickel ammonium sulfate^c^ | Nickel carbonate^d^
Molecular weight | 58.7 | 176.78 | 286.9 | 118.70
Color | Silvery white | Green | Blue-green | Green
Physical state | Solid^e^ | Solid^e.f^ | Solid^e^ | Solid^e^
Melting point | 1,455°C^e^ | Decomposes at 250°C^e.f^ | Decomposes at 250°C^e^ | Decomposes on heating
Boiling point | 2,913°C^e^ | 16°C^e.f^ | No data | No data
Density: | 8.9^e^ | 1.74 g/cm^3e.f^ | 1.92 g/cm^3g^ | 4.39 g/cm^3^
Odor | Odorless | Acetic acid odor^g^ | Odorless^g^ | No data
Odor threshold:
Water | No data | No data | No data | No data
Air | No data | No data | No data | No data
Taste threshold | No data | No data | No data | No data
Solubility:
Water | Insoluble in H_2_O^e^ | Very soluble in H_2_O^e.f^; 17 pounds/100 pounds water at 68 °F | Slightly soluble in H_2_O^e^; 10.4 g/100 g H_2_O^g^ at 20°C; 6.5 g/100 g H_2_O at 68 °F^e,g^ | 0.0043 g/100 g H_2_O^e^; 93 mg/L at 25°C
Organic solvent(s) | Slightly soluble in dilute acid | Soluble in ethanol^e.f^ | Insoluble in alcohol^g^ | Soluble in dilute acid^e^
Partition coefficients:
Log K_ow_ | No data | No data | No data | No data
Log K_oc_ | No data | No data | No data | No data
Vapor pressure | 0 mmHg (approximate) | No data | No data | No data
Henry’s law constant | No data | No data | No data | No data
Autoignition temperature | No data | Nonflammable | Nonflammable | No data
Flashpoint | No data | Nonflammable | Nonflammable | No data
Flammability limits | No data | Nonflammable | Nonflammable | No data
Conversion factors | No data | No data | No data | No data
Explosive limits | No data | No data | No data | No data

Property | Nickel chloride^h^ | Nickel cyanide^i^ | Nickel oxide^j^ | Nickel nitrate^k^
Molecular weight | 129.60 | 110.73 | 74.69 | 182.7
Color | Yellow^e^; green^e,g^ | Yellow-brown; green^e,g^ | Green; black | Green
Physical state | Solid | Solid | Solid | Solid
Melting point | 1,031°C^e^ | >200°C | 1,957°C^e^ | Decomposes at 56°C^e,g^
Boiling point | Sublimation point 985°C^e^ | Decomposes | No data | No data
Density | 3.51 g/cm^3^ | 2.393 g/cm^3^ | 6.72 g/cm^3e^ | 2.05 g/cm^3e,g^
Odor | Odorless | Weak almond odor | Odorless | No data
Odor threshold:
Water | No data | No data | No data | No data
Air | No data | No data | No data | No data
Taste threshold | No data | No data | No data | No data
Solubility:
Water | 67.5 g/100 g H_2_O^e^ | Insoluble in H_2_O | Insoluble in H_2_O^e^ 0.11 mg/100 mL H_2_O at 20°C | 99.2 g/100 g H_2_O^e,g^
Organic solvent(s) | Soluble in ethanol | Soluble in aqueous alkali cyanides and other bases | Soluble in acid | Soluble in ethanol
Partition coefficients:
Log K_ow_ | No data | No data | No data | No data
Log K_oc_ | No data | No data | No data | No data
Vapor pressure | No data | No data | No data | No data
Henry’s law constant | No data | No data | No data | No data
Autoignition temperature | Nonflammable | Nonflammable | No data | No data
Flashpoint | Nonflammable | Nonflammable | Flammable as dust or fume | No data
Flammability limits | Nonflammable | Nonflammable | No data | No data
Conversion factors | No data | No data | No data | No data
Explosive limits | Mixture of potassium and NiCl_2_ produces strong explosion on impact | No data | No data | May explode after prolonged exposure to fire or heat

Property | Nickel subsulfide^l^ | Nickel sulfamate^m^ | Nickel sulfate^n^
Molecular weight | 240.21 | 250.87 | 154.76
Color | Yellow^e^ | Blue-green | Greenish-yellow; blue-green^g^, green^o^
Physical state | Solid^e^ | Liquid | Solid
Melting point | 789°C^e^ | No data | Decomposes at 840°C Decomposes at 100°C^e,g^
Boiling point | No data | No data | No data
Density | 5.87 g/cm^3e^ | No data | 4.01 g/cm^3^; 2.03 g/cm^3g^; 1.98 g/cm^3o^
Odor | No data | No data | Odorless
Odor threshold:
Water | No data | No data | No data
Air | No data | No data | No data
Taste threshold | No data | No data | Sweet astringent taste
Solubility:
Water | No data | Highly soluble^f,p^ | 40.4 g/100 g H_2_O^e,g,o^
Organic solvent(s) | No data | No data | Insoluble in alcohol; slightly soluble^g^ or soluble^o^ in ethanol
Partition coefficients:
Log K_ow_ | No data | No data | No data
Log K_oc_ | No data | No data | No data
Vapor pressure | No data | No data | No data
Henry’s law constant | No data | No data | No data
Autoignition temperature | No data | No data | Nonflammable
Flashpoint | No data | No data | Nonflammable
Flammability limits | No data | No data | Nonflammable
Conversion factors | No data | No data | No data
Explosive limits | No data | No data | No data

a NLM 2024a unless otherwise specified.

b NLM 2024b unless otherwise specified.

c NLM 2024c unless otherwise specified.

d NLM 2024d unless otherwise specified.

e Haynes et al. 2015.

f Data are for the tetrahydrate.

g Data are for the hexahydrate.

h NLM 2024e unless otherwise specified.

i NLM 2024f unless otherwise specified.

j NLM 2024g unless otherwise specified.

k NLM 2024h unless otherwise specified.

l NLM 2024i unless otherwise specified.

m NLM 2024j unless otherwise specified.

n NLM 2024k unless otherwise specified.

o Data are for the heptahydrate.

p Lascelles et al. 2019.