# APPENDIX C FRAMEWORK FOR ATSDR’S SYSTEMATIC REVIEW OF HEALTH EFFECTS DATA FOR NICKEL

To increase the transparency of ATSDR’s process of identifying, evaluating, synthesizing, and interpreting the scientific evidence on the health effects associated with exposure to nickel, ATSDR utilized a slight modification of NTP’s Office of Health Assessment and Translation (OHAT) systematic review methodology (NTP 2013, 2015; Rooney et al. 2014). ATSDR’s framework is an eight-step process for systematic review with the goal of identifying the potential health hazards of exposure to nickel:

- Step 1. Problem Formulation
- Step 2. Literature Search and Screen for Health Effects Studies
- Step 3. Extract Data from Health Effects Studies
- Step 4. Identify Potential Health Effect Outcomes of Concern
- Step 5. Assess the Risk of Bias for Individual Studies
- Step 6. Rate the Confidence in the Body of Evidence for Each Relevant Outcome
- Step 7. Translate Confidence Rating into Level of Evidence of Health Effects
- Step 8. Integrate Evidence to Develop Hazard Identification Conclusions

## C.1 PROBLEM FORMULATION

The objective of the toxicological profile and this systematic review was to identify the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to nickel. The inclusion criteria used to identify relevant studies examining the health effects of nickel are presented in Table C-1.

Data from human and laboratory animal studies were considered relevant for addressing this objective. Human studies were divided into two broad categories: observational epidemiology studies and controlled exposure studies. The observational epidemiology studies were further divided: cohort studies (retrospective and prospective studies), population studies (with individual data or aggregate data), and case-control studies.

Table C-1 Inclusion Criteria for Identifying Health Effects Studies

Species; - Human; - Laboratory mammals
Route of exposure; - Inhalation; - Oral; - Dermal (or ocular); - Parenteral (these studies will be considered supporting data)
Health outcome; - Death; - Systemic effects; - Body weight effects; - Respiratory effects; - Cardiovascular effects; - Gastrointestinal effects; - Hematological effects; - Musculoskeletal effects; - Hepatic effects; - Renal effects; - Dermal effects; - Ocular effects; - Endocrine effects; - Immunological effects; - Neurological effects; - Reproductive effects; - Developmental effects; - Other noncancer effects; - Cancer

Prioritization of Human Data. Human studies of exposure to nickel include case reports/case series, controlled oral exposure studies, epidemiological studies of occupational exposures, and epidemiological studies of general population exposures to nickel as a constituent of ambient particulate matter. All controlled exposure studies were included. Case reports and case series were included in the profile if there was clear evidence of exposure primarily to nickel. Epidemiology studies included in this profile were restricted to those of populations with known exposure above background levels (e.g., occupational exposure).

## C.2 LITERATURE SEARCH AND SCREEN FOR HEALTH EFFECTS STUDIES

A literature search and screen were conducted to identify studies examining the health effects of nickel. The literature search framework for the toxicological profile is discussed in detail in Appendix B.

### C.2.1 Literature Search

As noted in Appendix B, the current literature search was intended to update the Draft Toxicological Profile for Nickel released for public comment in 2023. See Appendix B for the databases searched and the search strategy.

A total of 10,847 records relevant to all sections of the toxicological profile were identified (after duplicate removal).

### C.2.2 Literature Screening

As described in Appendix B, a two-step process was used to screen the literature search to identify relevant studies examining the health effects of nickel.

Title and Abstract Screen. In the Title and Abstract Screen step, 10,847 records were reviewed; 23 documents were considered to meet the health effects inclusion criteria in Table C-1 and were moved to the next step in the process.

Full Text Screen. In the second step in the literature screening process for the systematic review, a full text review of 189 health effect documents (documents identified in the update literature search and documents cited in older versions of the profile) was performed. From those 189 documents (231 studies), 60 documents (93 studies) were included in the qualitative review.

## C.3 EXTRACT DATA FROM HEALTH EFFECTS STUDIES

Relevant data extracted from the individual studies selected for inclusion in the systematic review were collected in customized data forms. A summary of the type of data extracted from each study is presented in Table C-2. For references that included more than one experiment or species, data extraction records were created for each experiment or species.

Table C-2 Data Extracted From Individual Studies

- Citation; - Chemical form; - Route of exposure (e.g., inhalation, oral, dermal); - Specific route (e.g., gavage in oil, drinking water); - Species; - Strain; - Exposure duration category (e.g., acute, intermediate, chronic); - Exposure duration; - Frequency of exposure (e.g., 6 hours/day, 5 days/week); - Exposure length; - Number of animals or subjects per sex per group; - Dose/exposure levels; - Parameters monitored; - Description of the study design and method; - Summary of calculations used to estimate doses (if applicable); - Summary of the study results; - Reviewer’s comments on the study; - Outcome summary (one entry for each examined outcome); - No-observed-adverse-effect level (NOAEL) value; - Lowest-observed-adverse-effect level (LOAEL) value; - Effect observed at the LOAEL value

A summary of the extracted data for each study is presented in the Supplemental Documents for Nickel and overviews of the results of the inhalation, oral and dermal exposure studies are presented in Sections 2.2–2.18 of the profile and in the Levels Significant Exposures tables in Section 2.1 of the profile (Tables 2-1, 2-2, and 2-3, respectively).

## C.4 IDENTIFY POTENTIAL HEALTH EFFECT OUTCOMES OF CONCERN

Overviews of the potential health effect outcomes for nickel identified in human and animal studies are presented in Tables C-3 and C-4, respectively.

Human studies evaluating noncancerous effects are primarily cohort studies of occupational exposure that examined mortality from respiratory effects.

Animal studies examined a wide range of endpoints following inhalation, oral, and dermal exposure and reported body weight, respiratory, cardiovascular, gastrointestinal, hematological, hepatic, renal, endocrine, reproductive, developmental, and cancer effects. Of the consistently observed effects, respiratory effects following inhalation exposure, immunological effects, reproductive, and developmental effects were considered sensitive outcomes (i.e., effects were observed at low concentrations or doses). There were 93 studies (published in 60 documents) examining these potential outcomes carried through to Steps 4–8 of the systematic review.

Table C-3 Overview of the Health Outcomes for Nickel Evaluated In Human Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological | Neurological | Reproductive | Developmental | Other Noncancer | Caner
Inhalation studies
Cohort | | 14 | 4 | | | 1 | 1 | 4 | | | 1 | 3 | 1 | 2 | 4 | | 28
Cohort | | 3 | 0 | | | 0 | 1 | 2 | | | 1 | 3 | 0 | 1 | 0 | | 11
Case control | | | | | | | | | | | | | | | | | 8
Case control | | | | | | | | | | | | | | | | | 1
Cross-sectional | | 4 | | | | | | | | | | | 1
Cross-sectional | | 3 | | | | | | | | | | | 1
Case series | | 7 | 1 | 1 | 1 | 1 | 1 | 2 | | 1 | | 1 | 3 | | | | 1
Case series | | 7 | 1 | 1 | 1 | 1 | 1 | 2 | | 1 | | 1 | 3 | | | | 1
Controlled
Controlled
Oral studies
Cohort
Cohort
Case control
Case control
Population
Population
Case series
Case series
Controlled | | | | | | | | | | | | 16
Controlled | | | | | | | | | | | | 16
Dermal studies
Cohort
Cohort
Case control
Case control
Population
Population
Case series
Case series
Controlled | | | | | | | | | | | | 33
Controlled | | | | | | | | | | | | 33
Number of studies examining endpoint | | | | 0 | 1 | 2 | 3 | 4 | 5-9 | ≥10
Number of studies reporting outcome | | | | 0 | 1 | 2 | 3 | 4 | 5-9 | ≥10

Table C-4 Overview of the Health Outcomes for Nickel Evaluated in Experimental Animal Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological^a^ | Neurological^a^ | Reproductive^a^ | Developmental | Other Noncancer | Caner
Inhalation studies
Acute-duration | 8 | 10 | 6 | 6 | | 3 | 6 | 6 | 6 | | 6 | 11 | 6 | 6
Acute-duration | 3 | 10 | 0 | 0 | | 0 | 0 | 0 | 0 | | 0 | 6 | 0 | 0
Intermediate-duration | 17 | 23 | 6 | 6 | 5 | 6 | 6 | 7 | 6 | | 7 | 14 | 6 | 6 | 1
Intermediate-duration | 2 | 23 | 0 | 0 | 2 | 0 | 0 | 0 | 0 | | 0 | 14 | 0 | 1 | 1
Chronic-duration | 10 | 10 | 7 | 7 | 7 | 6 | 8 | 8 | 6 | | 8 | 8 | 7 | 6 | | | 8
Chronic-duration | 4 | 10 | 0 | 0 | 3 | 0 | 0 | 0 | 0 | | 4 | 7 | 0 | 0 | | | 4
Acute-duration | 3 | | | 1 | | | | | | | | | 1 | 1 | 7
Acute-duration | 3 | | | 1 | | | | | | | | | 1 | 1 | 7
Intermediate-duration | 15 | 4 | 3 | 3 | 4 | | 8 | 10 | 1 | 1 | 3 | 3 | 4 | 12 | 9
Intermediate-duration | 8 | 3 | 0 | 1 | 2 | | 2 | 5 | 0 | 0 | 1 | 3 | 2 | 2 | 8
Chronic-duration | 2 | 1 | 1 | 1 | 2 | 1 | 1 | 1 | 1 | | 1 | 1 | 1
Chronic-duration | 2 | 1 | 0 | 0 | 1 | 0 | 0 | 1 | 0 | | 0 | 0 | 0
Acute-duration | | | | | | | | | | | | 1
Acute-duration | | | | | | | | | | | | 1
Intermediate-duration | | | | | 1 | | 1 | 2 | 1 | | | | | 1 | | 1
Intermediate-duration | | | | | 0 | | 1 | 1 | 1 | | | | | 1 | | 1
Chronic-duration
Chronic-duration
Number of studies examining endpoint | | | | 0 | 1 | 2 | 3 | 4 | 5-9 | ≥10
Number of studies reporting outcome | | | | 0 | 1 | 2 | 3 | 4 | 5-9 | ≥10

a Number of studies examining endpoint includes study evaluating histopathology, but not evaluating function.

## C.5 ASSESS THE RISK OF BIAS FOR INDIVIDUAL STUDIES

### C.5.1 Risk of Bias Assessment

The risk of bias of individual studies was assessed using OHAT’s Risk of Bias Tool (NTP 2015). The risk of bias questions for observational epidemiology studies, human-controlled exposure studies, and animal experimental studies are presented in Tables C-5, C-6, and C-7, respectively. Each risk of bias question was answered on a four-point scale:

- Definitely low risk of bias (++)
- Probably low risk of bias (+)
- Probably high risk of bias (−)
- Definitely high risk of bias (− −)

In general, “definitely low risk of bias” or “definitely high risk of bias” were used if the question could be answered with information explicitly stated in the study report. If the response to the question could be inferred, then “probably low risk of bias” or “probably high risk of bias” responses were typically used.

Table C-5 Risk of Bias Questionnaire for Observational Epidemiology Studies

Selection bias; - Were the comparison groups appropriate?
Confounding bias; - Did the study design or analysis account for important confounding and modifying variables?
Attrition/exclusion bias; - Were outcome data complete without attrition or exclusion from analysis?
Detection bias; - Is there confidence in the exposure characterization?; - Is there confidence in outcome assessment?
Selective reporting bias; - Were all measured outcomes reported?

Table C-6 Risk of Bias Questionnaire for Human-Controlled Exposure Studies

Selection bias; - Was administered dose or exposure level adequately randomized?; - Was the allocation to study groups adequately concealed?
Performance bias; - Were the research personnel and human subjects blinded to the study group during the study?
Attrition/exclusion bias; - Were outcome data complete without attrition or exclusion from analysis?
Detection bias; - Is there confidence in the exposure characterization?; - Is there confidence in outcome assessment?
Selective reporting bias; - Were all measured outcomes reported?

Table C-7 Risk of Bias Questionnaire for Experimental Animal Studies

Selection bias; - Was administered dose or exposure level adequately randomized?; - Was the allocation to study groups adequately concealed?
Performance bias; - Were experimental conditions identical across study groups?; - Were the research personnel blinded to the study group during the study?
Attrition/exclusion bias; - Were outcome data complete without attrition or exclusion from analysis?
Detection bias; - Is there confidence in the exposure characterization?; - Is there confidence in outcome assessment?
Selective reporting bias; - Were all measured outcomes reported?

After the risk of bias questionnaires were completed for the health effects studies, the studies were assigned to one of three risk of bias tiers based on the responses to the key questions listed below and the responses to the remaining questions.

- Is there confidence in the exposure characterization? (only relevant for observational studies)
- Is there confidence in the outcome assessment?
- Does the study design or analysis account for important confounding and modifying variables? (only relevant for observational studies)

First Tier. Studies placed in the first tier received ratings of “definitely low” or “probably low” risk of bias on the key questions AND received a rating of “definitely low” or “probably low” risk of bias on the responses to at least 50% of the other applicable questions.

Second Tier. A study was placed in the second tier if it did not meet the criteria for the first or third tiers.

Third Tier. Studies placed in the third tier received ratings of “definitely high” or “probably high” risk of bias for the key questions AND received a rating of “definitely high” or “probably high” risk of bias on the response to at least 50% of the other applicable questions.

The results of the risk of bias assessment for the different types of nickel health effects studies (observational epidemiology and animal experimental studies) are presented in Tables C-8 and C-9, respectively.

Table C-8 Summary of Risk of Bias Assessment for Nickel––Observational Epidemiology Studies

Reference | Risk of bias criteria and ratings | | | | | | Risk of bias tier
Reference | Selection bias | Confounding bias | Attrition / exclusion bias | Detection bias | | Selective reporting bias | Risk of bias tier
Reference | Were the comparison groups appropriate? | Did the study design or analysis account for important confounding and modifying variables?^*^ | Were outcome data complete without attrition or exclusion from analysis? | Is there confidence in the exposure characterization?^*^ | Is there confidence in the outcome assessment?^*^ | Were all measured outcomes reported? | Risk of bias tier
Outcome: Respiratory
Cohort studies inhalation
Berge and Skyberg 2003 | + | + | − | − | − | ++ | Second
Syurin and Vinnikov 2022 | − | + | + | − | − − | ++ | Second
Cross-sectional
Fishwick et al. 2004 | ++ | + | + | − | − | ++ | Second
Kilburn et al. 1990 | + | − | + | − | + | ++ | Second
Muir et al. 1993 | + | + | − | − | + | + | Second
Wu et al. 2022 | + | ++ | + | + | + | ++ | First
Outcome: Immunological
Cohort studies inhalation
Bencko et al. 1983 | − − | − | + | − | − | ++ | Third
Bencko et al. 1986 | ++ | + | + | − | + | ++ | Second
Outcome: Reproductive
Cohort studies inhalation
Chashschin et al. 1994 | − | − | − | − | − | ++ | Third
Case-Control studies
Chashschin et al. 1994 | − | − | − | − | − | ++ | Third
Vaktskjold et al. 2008b | + | + | + | + | + | ++ | First
Outcome: Developmental
Cohort studies inhalation
Chashschin et al. 1994 | − | − | − | − | − | ++ | Third
Vaktskjold et al. 2006 | + | + | + | + | + | ++ | First
Vaktskjold et al. 2007 | + | + | + | + | + | ++ | First
Vaktskjold et al. 2008a | + | + | + | + | + | ++ | First

++ = definitely low risk of bias; + = probably low risk of bias; − = probably high risk of bias; − − = definitely high risk of bias;

* Key question used to assign risk of bias tier

Table C-9 Summary of Risk Bias Assessment for Nickel – Experimental Animal Studies

Reference | Risk of bias criteria and ratings | | | | | | | | Risk of bias tier
Reference | Selection bias | | Performance bias | | Attrition/exclusion bias | Detection bias | | Selective reporting bias | Risk of bias tier
Reference | Was administered dose or exposure level adequately randomized? | Was the allocation to study groups adequately concealed? | Were experimental conditions identical across study groups? | Were the research personnel blinded to the study group during the study? | Were outcome data complete without attrition or exclusion from analysis? | Is there confidence in the exposure characterization? | Is there confidence in the outcome assessment?^*^ | Were all measured outcomes reported? | Risk of bias tier
Outcome: Respiratory
Inhalation acute exposure
Benson et al. 1995b (rat) | + | + | + | + | + | ++ | + | + | First
Efremenko et al. 2014 (rat) | ++ | + | + | + | + | + | ++ | + | First
Efremenko et al. 2017a, 2017b (rat) | ++ | + | + | + | + | ++ | ++ | + | First
NTP 1996a (rat) | + | + | + | + | ++ | ++ | ++ | ++ | First
NTP 1996a (mouse) | + | + | + | + | ++ | ++ | ++ | ++ | First
NTP 1996b (rat) | + | + | + | + | ++ | ++ | ++ | ++ | First
NTP 1996b (mouse) | + | + | + | + | ++ | ++ | ++ | ++ | First
NTP 1996c (rat) | + | + | + | + | ++ | ++ | ++ | ++ | First
NTP 1996c (mouse) | + | + | + | + | ++ | ++ | ++ | ++ | First
Inhalation intermediate exposure
Benson et al. 1995a (rat, nickel sulfate) | + | + | + | + | + | ++ | + | + | First
Benson et al. 1995a (rat, nickel oxide) | + | + | + | + | + | ++ | + | + | First
Benson et al. 1995a (mouse, nickel sulfate) | + | + | + | + | + | ++ | + | + | First
Benson et al. 1995a (mouse, nickel oxide) | + | + | + | + | + | ++ | + | + | First
Benson et al. 1995b (rat) | + | + | + | + | + | ++ | + | + | First
Efremenko et al. 2014 (rat) | ++ | − | + | − | + | + | ++ | + | First
Efremenko et al. 2017a, 2017b (rat) | ++ | + | + | + | + | ++ | ++ | + | First
Evans et al. 1995 (rat) | − | − | ++ | − | + | + | ++ | ++ | First
Horie et al. 1985 (rat) | − | − | + | − | + | − | − | + | Second
NTP 1996a (rat) | + | + | + | + | ++ | ++ | ++ | ++ | First
NTP 1996a (mouse) | + | + | + | + | ++ | ++ | ++ | ++ | First
NTP 1996b (rat) | + | + | + | + | ++ | ++ | ++ | ++ | First
NTP 1996b (mouse) | + | + | + | + | ++ | ++ | ++ | ++ | First
NTP 1996c (rat) | + | + | + | + | ++ | ++ | ++ | ++ | First
NTP 1996c (mouse) | + | + | + | + | ++ | ++ | ++ | ++ | First
Oller et al. 2023 (rat, nickel subsulfide) | ++ | + | + | + | ++ | ++ | + | + | First
Oller et al. 2023 (rat, nickel sulfate) | ++ | + | + | + | ++ | ++ | + | + | First
Weischer et al. 1980 (rat) | − | − | + | − | + | − | + | + | Second
Inhalation chronic exposure
NTP 1996a (rat) | + | + | + | + | ++ | ++ | ++ | ++ | First
NTP 1996a (mouse) | + | + | + | + | ++ | ++ | ++ | ++ | First
NTP 1996b (rat) | + | + | + | + | ++ | ++ | ++ | ++ | First
NTP 1996b (mouse) | + | + | + | + | ++ | ++ | ++ | ++ | First
NTP 1996c (rat) | + | + | + | + | ++ | ++ | ++ | ++ | First
NTP 1996c (mouse) | + | + | + | + | ++ | ++ | ++ | ++ | First
Oller et al. 2008 (rat) | ++ | − | + | − | + | ++ | ++ | ++ | First
Ottolenghi et al. 1975 (rat) | − | − | + | − | + | − | + | + | Second
Takenaka et al. 1985 (rat) | − | − | ++ | − | + | − | + | + | Second
Tanaka et al. 1988 (rat) | − | + | + | + | + | + | + | + | First
Oral intermediate exposure
American Biogenics Corporation 1988 (rat) | ++ | − | + | − | + | ++ | + | + | First
Obone et al. 1999 (rat) | − | − | + | − | ++ | + | ++ | ++ | First
EPA 1988a, 1988b (rat) | + | − | + | − | + | − | + | + | First
Springborn Laboratories 2002 (rat) | ++ | − | + | − | ++ | ++ | ++ | ++ | First
Oral intermediate exposure
Ambrose et al. 1976 (dog) | − | − | + | − | + | − | + | + | Second
Outcome: Immunological
Inhalation acute exposure
Adkins et al. 1979 (mouse, bacteria clearance) | − | − | + | − | + | − | + | + | Second
Adkins et al. 1979 (mouse, nickel chloride) | − | − | + | − | + | − | + | + | Second
Adkins et al. 1979 (mouse, nickel sulfate) | − | − | + | − | + | − | + | + | Second
Buxton et al. 2021 (mouse) | ++ | − | ++ | − | + | + | + | ++ | First
Graham et al. 1978 (mouse) | − | − | + | − | + | − | + | + | Second
NTP 1996a (rat) | + | + | + | + | ++ | ++ | ++ | ++ | First
NTP 1996a (mouse) | + | + | + | + | ++ | ++ | ++ | ++ | First
NTP 1996b (rat) | + | + | + | + | ++ | ++ | ++ | ++ | First
NTP 1996b (mouse) | + | + | + | + | ++ | ++ | ++ | ++ | First
NTP 1996c (rat) | + | + | + | + | ++ | ++ | ++ | ++ | First
NTP 1996c (mouse) | + | + | + | + | ++ | ++ | ++ | ++ | First
Inhalation intermediate exposure
Haley et al. 1990 (mouse, nickel oxide) | + | − | + | − | + | ++ | ++ | ++ | First
Haley et al. 1990 (mouse, nickel subsulfide) | + | − | + | − | + | ++ | ++ | ++ | First
Haley et al. 1990 (mouse, nickel sulfate) | + | − | + | − | + | ++ | ++ | ++ | First
Johansson et al. 1987 (rabbit) | − | − | + | − | + | − | + | + | Second
Johansson et al. 1988a, 1989 (rabbit) | − | − | + | − | + | − | + | + | Second
Morimoto et al. 1995 (rat) | − | − | + | − | + | + | + | + | First
NTP 1996a (rat) | + | + | + | + | ++ | ++ | ++ | ++ | First
NTP 1996a (mouse) | + | + | + | + | ++ | ++ | ++ | ++ | First
NTP 1996b (rat) | + | + | + | + | ++ | ++ | ++ | ++ | First
NTP 1996b (mouse) | + | + | + | + | ++ | ++ | ++ | ++ | First
NTP 1996c (rat) | + | + | + | + | ++ | ++ | ++ | ++ | First
NTP 1996c (mouse) | + | + | + | + | ++ | ++ | ++ | ++ | First
Spiegelberg et al. 1984 (rat) | − | − | + | − | + | − | + | + | Second
Inhalation chronic exposure
NTP 1996a (rat) | − | − | + | − | ++ | ++ | ++ | ++ | First
NTP 1996a (mouse) | − | − | + | − | ++ | ++ | ++ | ++ | First
NTP 1996b (rat) | − | − | + | − | ++ | ++ | ++ | ++ | First
NTP 1996b (mouse) | − | − | + | − | ++ | ++ | ++ | ++ | First
NTP 1996c (rat) | − | − | + | − | ++ | ++ | ++ | ++ | First
NTP 1996c (mouse) | − | − | + | − | ++ | ++ | ++ | ++ | First
Oller et al. 2008 (rat) | ++ | − | + | − | + | ++ | ++ | ++ | First
Ottolenghi et al. 1975 (rat) | − | − | + | − | + | − | + | + | Second
Oral intermediate exposure
Dieter et al. 1988 (mouse) | − | − | + | − | + | − | + | + | Second
Ilbäck et al. 1994 (mouse) | + | − | + | − | + | − | + | + | First
Obone et al. 1999 (rat) | − | − | + | − | ++ | + | ++ | ++ | First
Oral chronic exposure
Ambrose et al. 1976 (dog) | − | − | + | − | + | − | + | + | Second
Dermal acute exposure
Siller and Seymour 1994 (mouse) | − | − | + | − | + | − | + | + | Second
Outcome: Reproductive
Inhalation acute exposure
NTP 1996a (rat) | + | + | + | + | + | ++ | ++ | + | First
NTP 1996a (mouse) | + | + | + | + | + | ++ | ++ | + | First
NTP 1996b (rat) | + | + | + | + | + | ++ | ++ | + | First
NTP 1996b (mouse) | + | + | + | + | + | ++ | ++ | + | First
NTP 1996c (rat) | + | + | + | + | + | ++ | ++ | + | First
NTP 1996c (mouse) | + | + | + | + | + | ++ | ++ | + | First
Inhalation intermediate exposure
NTP 1996a (rat) | + | + | + | + | ++ | ++ | ++ | ++ | First
NTP 1996b (rat) | + | + | + | + | ++ | ++ | ++ | ++ | First
NTP 1996a (mouse) | + | + | + | + | ++ | ++ | ++ | ++ | First
NTP 1996b (mouse) | + | + | + | + | ++ | ++ | ++ | ++ | First
NTP 1996c (rat) | + | + | + | + | ++ | ++ | ++ | ++ | First
NTP 1996c (mouse) | + | + | + | + | ++ | ++ | ++ | ++ | First
Inhalation chronic exposure
NTP 1996a (rat) | + | + | + | + | ++ | ++ | ++ | ++ | First
NTP 1996a (mouse) | + | + | + | + | ++ | ++ | ++ | ++ | First
NTP 1996b (rat) | + | + | + | + | ++ | ++ | ++ | ++ | First
NTP 1996b (mouse) | + | + | + | + | ++ | ++ | ++ | ++ | First
NTP 1996c (rat) | + | + | + | + | ++ | ++ | ++ | ++ | First
NTP 1996c (mouse) | + | + | + | + | ++ | ++ | ++ | ++ | First
Oral acute exposure
Saini et al. 2013 (mouse) | − | + | + | + | + | − | ++ | + | First
Saini et al. 2014a (mouse) | − | + | + | + | + | − | ++ | + | First
Saini et al. 2014b (mouse, GDs 0–5) | − | + | + | + | + | + | ++ | + | First
Saini et al. 2014b (mouse, GDs 6–13) | − | + | + | + | + | + | ++ | + | First
Saini et al. 2014b (mouse, GDs 14–18) | − | + | + | + | + | + | ++ | + | First
Seidenberg et al. 1986 (mouse) | − | + | + | + | + | − | + | + | First
Sobti and Gill 1989 (mouse, nickel sulfate) | − | + | + | + | − | − | − | + | Second
Sobti and Gill 1989 (mouse, nickel nitrate) | − | + | + | + | − | − | − | + | Second
Sobti and Gill 1989 (mouse, nickel chloride) | − | + | + | + | − | − | − | + | Second
Oral intermediate exposure
Ambrose et al. 1976 (rat) | − | + | + | + | + | − | + | + | First
Käkelä et al. 1999 (rat, 28 or 42 days prior to mating) | − | + | + | + | + | − | + | + | First
Käkelä et al. 1999 (rat, 14 or 100 days prior to mating) | − | + | + | + | ++ | − | + | + | First
Käkelä et al. 1999 (rat, 28–76 days) | − | + | + | + | + | − | + | + | First
Obone et al. 1999 (rat) | − | + | + | + | ++ | + | ++ | ++ | First
Pandey and Srivastava 2000 (mouse, nickel chloride) | − | + | + | + | ++ | − | + | + | First
Pandey and Srivastava 2000 (mouse, nickel sulfate) | − | + | + | + | ++ | − | + | + | First
Pandey et al. 1999 (mouse, one dose group) | − | + | + | + | ++ | + | + | + | First
Pandey et al. 1999 (mouse, two dose groups) | − | + | + | + | + | + | + | + | First
EPA 1988a, 1988b (rat) | + | + | + | + | + | − | + | + | First
Smith et al. 1993 (rat) | + | + | + | + | + | − | + | + | First
Springborn Laboratories 2000a (rat) | ++ | + | + | + | ++ | ++ | + | ++ | First
Springborn Laboratories 2000b (rat) | ++ | + | + | + | ++ | ++ | + | ++ | First
Toman et al. 2012 (mouse) | − | + | + | + | ++ | − | + | + | First
Oral chronic exposure
Ambrose et al. 1976 (dog) | − | + | + | + | ++ | − | + | + | First
Outcome: Developmental
Oral acute exposure
Saini et al. 2013 (mouse) | − | + | + | + | + | − | ++ | + | First
Saini et al. 2014a (mouse) | − | + | + | + | + | − | ++ | + | First
Saini et al. 2014b (mouse, GDs 0–5) | − | + | + | + | + | + | ++ | + | First
Saini et al. 2014b (mouse, GDs 6–13 | − | + | + | + | + | + | ++ | + | First
Saini et al. 2014b (Mouse, GDs 14–18) | − | + | + | + | + | + | ++ | + | First
Seidenberg et al. 1986 (mouse) | − | + | + | + | + | − | + | + | First
Oral intermediate exposure
Ambrose et al. 1976 (rat) | − | + | + | + | + | − | + | + | First
EPA 1983 (mouse) | + | + | − | + | − | − | + | + | First
Käkelä et al. 1999 (rat, 28 or 42 days prior to mating) | − | + | + | + | + | − | + | + | First
Käkelä et al. 1999 (rat, 14 or 100 days prior to mating) | − | + | + | + | ++ | − | + | + | First
Käkelä et al. 1999 (rat, 28–76 days) | − | + | + | + | + | − | + | + | First
EPA 1988a, 1988b (rat) | + | + | + | + | + | − | + | + | First
Smith et al. 1993 (rat) | + | + | + | + | + | − | + | + | First
Springborn Laboratories 2000a (rat) | ++ | + | + | + | ++ | ++ | + | ++ | First
Springborn Laboratories 2000b (rat) | ++ | + | + | + | ++ | ++ | + | ++ | First

++ = definitely low risk of bias; + = probably low risk of bias; − = probably high risk of bias; − − = definitely high risk of bias;

* Key question used to assign risk of bias tier

## C.6 RATE THE CONFIDENCE IN THE BODY OF EVIDENCE FOR EACH RELEVANT OUTCOME

Confidences in the bodies of human and animal evidence were evaluated independently for each potential outcome. ATSDR did not evaluate the confidence in the body of evidence for carcinogenicity; rather, the Agency defaulted to the cancer weight-of-evidence assessment of other agencies including HHS, EPA, and IARC. The confidence in the body of evidence for an association or no association between exposure to nickel and a particular outcome was based on the strengths and weaknesses of individual studies. Four descriptors were used to describe the confidence in the body of evidence for effects or when no effect was found:

- High confidence: the true effect is highly likely to be reflected in the apparent relationship
- Moderate confidence: the true effect may be reflected in the apparent relationship
- Low confidence: the true effect may be different from the apparent relationship
- Very low confidence: the true effect is highly likely to be different from the apparent relationship

Confidence in the body of evidence for a particular outcome was rated for each type of study: case-control, case series, cohort, population, human-controlled exposure, and experimental animal. In the absence of data to the contrary, data for a particular outcome were collapsed across animal species, routes of exposure, and exposure durations. If species (or strain), route, or exposure duration differences were noted, then the data were treated as separate outcomes.

### C.6.1 Initial Confidence Rating

In ATSDR’s modification to the OHAT approach, the body of evidence for an association (or no association) between exposure to nickel and a particular outcome was given an initial confidence rating based on the key features of the individual studies examining that outcome. The presence of these key features of study design was determined for individual studies using four “yes or no” questions, which were customized for epidemiology, human controlled exposure, or experimental animal study designs. Separate questionnaires were completed for each outcome assessed in a study. The key features for observational epidemiology (cohort, population, and case-control) studies, human controlled exposure, and experimental animal studies are presented in Tables C-10, C-11, and C-12, respectively. The initial confidence in the study was determined based on the number of key features present in the study design:

- High Initial Confidence: Studies in which the responses to the four questions were “yes”.
- Moderate Initial Confidence: Studies in which the responses to only three of the questions were “yes”.
- Low Initial Confidence: Studies in which the responses to only two of the questions were “yes”.
- Very Low Initial Confidence: Studies in which the response to one or none of the questions was “yes”.

Table C-10 Key Features of Study Design for Observational Epidemiology Studies

Exposure was experimentally controlled
Exposure occurred prior to the outcome
Outcome was assessed on individual level rather than at the population level
A comparison group was used

Table C-11 Key Features of Study Design for Human-Controlled Exposure Studies

A comparison group was used or the subjects served as their own control
A sufficient number of subjects were tested
Appropriate methods were used to measure outcomes (i.e., clinically-confirmed outcome versus self-reported)
Appropriate statistical analyses were performed and reported or the data were reported in such a way to allow independent statistical analysis

Table C-12 Key Features of Study Design for Experimental Animal Studies

A concurrent control group was used
A sufficient number of animals per group were tested
Appropriate parameters were used to assess a potential adverse effect
Appropriate statistical analyses were performed and reported or the data were reported in such a way to allow independent statistical analysis

The presence or absence of the key features and the initial confidence levels for studies examining respiratory and immunological effects observed in the observational epidemiology and animal experimental studies are presented in Tables C-13 and C-14, respectively.

Table C-13 Presence of Key Features of Study Design for Nickel—Observational Epidemiology Studies

Reference | Key features | | | | Initial study confidence
Reference | Controlled exposure | Exposure prior to outcome | Outcome assessed on individual level | Comparison group | Initial study confidence
Outcome: Respiratory effects
Cohort inhalation studies
Berge and Skyberg 2003 | No | No | Yes | Yes | Low
Syurin and Vinnikov 2022 | No | Yes | Yes | Yes | Moderate
Cross-sectional studies
Fishwick et al. 2004 | No | Yes | Yes | Yes | Moderate
Kilburn et al. 1990 | No | Yes | Yes | Yes | Moderate
Muir et al. 1993 | No | Yes | Yes | Yes | Moderate
Wu et al. 2022 | No | Yes | Yes | Yes | Moderate
Outcome: Immunological effects
Cohort inhalation studies
Bencko et al. 1983 | No | Yes | Yes | Yes | Moderate
Bencko et al. 1986 | No | Yes | Yes | Yes | Moderate
Outcome: Reproductive effects
Cohort inhalation studies
Chashschin et al. 1994 | No | Yes | Yes | Yes | Moderate
Case-Control studies
Vaktskjold et al. 2008b | No | Yes | Yes | Yes | Moderate
Outcome: Developmental effects
Cohort inhalation studies
Chashschin et al. 1994 | No | Yes | Yes | Yes | Moderate
Vaktskjold et al. 2006 | No | Yes | Yes | Yes | Moderate
Vaktskjold et al. 2007 | No | Yes | Yes | Yes | Moderate
Vaktskjold et al. 2008a | No | Yes | Yes | Yes | Moderate

Table C-14 Presence of Key Features of Study Design for Nickel – Experimental Animal Studies

Reference | Key features | | | | Initial study confidence
Reference | Concurrent Control Group | Sufficient number of animals per group | Appropriate parameters to assess potential effect | Adequate data for statistical analysis | Initial study confidence
Outcome: Respiratory effects
Inhalation acute exposure
Benson et al. 1995b (rat) | Yes | Yes | Yes | Yes | High
Efremenko et al. 2014 (rat) | Yes | Yes | Yes | Yes | High
Efremenko et al. 2017a, 2017b (rat) | Yes | Yes | Yes | Yes | High
NTP 1996a (rat) | Yes | Yes | Yes | Yes | High
NTP 1996a (mouse) | Yes | Yes | Yes | Yes | High
NTP 1996b (rat) | Yes | Yes | Yes | Yes | High
NTP 1996b (mouse) | Yes | Yes | Yes | Yes | High
NTP 1996c (rat) | Yes | Yes | Yes | Yes | High
NTP 1996c (mouse) | Yes | Yes | Yes | Yes | High
Inhalation intermediate exposure
Benson et al. 1995a (rat, nickel sulfate) | Yes | Yes | Yes | Yes | High
Benson et al. 1995a (rat, nickel oxide) | Yes | Yes | Yes | Yes | High
Benson et al. 1995a (mouse, nickel sulfate) | Yes | Yes | Yes | Yes | High
Benson et al. 1995a (mouse, nickel oxide) | Yes | Yes | Yes | Yes | High
Benson et al. 1995b (rat) | Yes | Yes | Yes | Yes | High
Efremenko et al. 2014 (rat) | Yes | Yes | Yes | Yes | High
Efremenko et al. 2017a, 2017b (rat) | Yes | Yes | Yes | Yes | High
Evans et al. 1995 (rat) | Yes | Yes | Yes | Yes | High
Horie et al. 1985 (rat) | Yes | No | Yes | No | Low
NTP 1996a (rat) | Yes | Yes | Yes | Yes | High
NTP 1996a (mouse) | Yes | Yes | Yes | Yes | High
NTP 1996b (rat) | Yes | Yes | Yes | Yes | High
NTP 1996b (mouse) | Yes | Yes | Yes | Yes | High
NTP 1996c (rat) | Yes | Yes | Yes | Yes | High
NTP 1996c (mouse) | Yes | Yes | Yes | Yes | High
Oller et al. 2023 (rat) | Yes | Yes | Yes | Yes | High
Oller et al. 2023 (rat) | Yes | Yes | Yes | Yes | High
Weischer et al. 1980 (rat) | Yes | Yes | Yes | Yes | High
Inhalation chronic exposure
NTP 1996a (rat) | Yes | Yes | Yes | Yes | High
NTP 1996a (mouse) | Yes | Yes | Yes | Yes | High
NTP 1996b (rat) | Yes | Yes | Yes | Yes | High
NTP 1996b (mouse) | Yes | Yes | Yes | Yes | High
NTP 1996c (rat) | Yes | Yes | Yes | Yes | High
NTP 1996c (mouse) | Yes | Yes | Yes | Yes | High
Oller et al. 2008 (rat) | Yes | Yes | Yes | Yes | High
Ottolenghi et al. 1975 (rat) | Yes | Yes | Yes | Yes | High
Takenaka et al. 1985 (rat) | Yes | No | Yes | No | Low
Tanaka et al. 1988 (rat) | Yes | No | Yes | No | Low
Oral intermediate exposure
American Biogenics Corporation 1988 (rat) | Yes | Yes | Yes | Yes | High
Obone et al. 1999 (rat) | Yes | No | Yes | Yes | Moderate
EPA 1988a, 1988b (rat) | Yes | Yes | Yes | Yes | High
Springborn Laboratories 2002 (rat) | Yes | Yes | Yes | Yes | High
Oral chronic exposure
Ambrose et al. 1976 (dog) | Yes | No | Yes | No | Low
Outcome: Immunological effects
Inhalation acute exposure
Adkins et al. 1979 (mouse, bacteria clearance) | Yes | Yes | Yes | Yes | High
Adkins et al. 1979 (mouse, nickel chloride) | Yes | Yes | Yes | Yes | High
Adkins et al. 1979 (mouse, nickel sulfate) | Yes | Yes | Yes | Yes | High
Buxton et al. 2021 (mouse) | Yes | Yes | Yes | Yes | High
Graham et al. 1978 (mouse) | Yes | Yes | Yes | Yes | High
NTP 1996a (rat) | Yes | Yes | Yes | Yes | High
NTP 1996a (mouse) | Yes | Yes | Yes | Yes | High
NTP 1996b (rat) | Yes | Yes | Yes | Yes | High
NTP 1996b (mouse) | Yes | Yes | Yes | Yes | High
NTP 1996c (rat) | Yes | Yes | Yes | Yes | High
NTP 1996c (mouse) | Yes | Yes | Yes | Yes | High
Inhalation intermediate exposure
Haley et al. 1990 (mouse, nickel oxide) | Yes | Yes | Yes | Yes | High
Haley et al. 1990 (mouse, nickel subsulfide) | Yes | Yes | Yes | Yes | High
Haley et al. 1990 (mouse, nickel sulfate) | Yes | Yes | Yes | Yes | High
Johansson et al. 1987 (rabbit) | Yes | No | Yes | Yes | Moderate
Johansson et al. 1988a, 1989 (rabbit) | Yes | No | Yes | Yes | Moderate
Morimoto et al. 1995 (rat) | Yes | No | Yes | Yes | Moderate
NTP 1996a (rat) | Yes | Yes | Yes | Yes | High
NTP 1996a (mouse) | Yes | Yes | Yes | Yes | High
NTP 1996b (rat) | Yes | Yes | Yes | Yes | High
NTP 1996b (mouse) | Yes | Yes | Yes | Yes | High
NTP 1996c (rat) | Yes | Yes | Yes | Yes | High
NTP 1996c (mouse) | Yes | Yes | Yes | Yes | High
Spiegelberg et al. 1984 (rat) | Yes | Yes | Yes | Yes | High
Inhalation chronic exposure
NTP 1996a (rat) | Yes | Yes | Yes | Yes | High
NTP 1996a (mouse) | Yes | Yes | Yes | Yes | High
NTP 1996b (rat) | Yes | Yes | Yes | Yes | High
NTP 1996b (mouse) | Yes | Yes | Yes | Yes | High
NTP 1996c (rat) | Yes | Yes | Yes | Yes | High
NTP 1996c (mouse) | Yes | Yes | Yes | Yes | High
Oller et al. 2008 (rat) | Yes | Yes | Yes | Yes | High
Ottolenghi et al. 1975 (rat) | Yes | Yes | Yes | Yes | High
Oral intermediate exposure
Dieter et al. 1988 (mouse) | Yes | Yes | Yes | Yes | High
Ilbäck et al. 1994 (mouse) | Yes | No | Yes | Yes | Moderate
Obone et al. 1999 (rat) | Yes | No | Yes | Yes | Moderate
Oral chronic exposure
Ambrose et al. 1976 (dog) | Yes | No | Yes | No | Low
Dermal acute exposure
Siller and Seymour 1994 (mouse) | Yes | No | Yes | Yes | Moderate
Outcome: Reproductive effects
Inhalation acute exposure
NTP 1996a (rat) | Yes | Yes | Yes | No | Moderate
NTP 1996a (mouse) | Yes | Yes | Yes | No | Moderate
NTP 1996b (rat) | Yes | Yes | Yes | No | Moderate
NTP 1996b (mouse) | Yes | Yes | Yes | No | Moderate
NTP 1996c (rat) | Yes | Yes | Yes | No | Moderate
NTP 1996c (mouse) | Yes | Yes | Yes | No | Moderate
Inhalation intermediate exposure
NTP 1996a (rat) | Yes | Yes | Yes | Yes | High
NTP 1996b (rat) | Yes | Yes | Yes | Yes | High
NTP 1996a (mouse) | Yes | Yes | Yes | Yes | High
NTP 1996b (mouse) | Yes | Yes | Yes | Yes | High
NTP 1996c (rat) | Yes | Yes | Yes | Yes | High
NTP 1996c (mouse) | Yes | Yes | Yes | Yes | High
Inhalation chronic exposure
NTP 1996a (rat) | Yes | Yes | Yes | Yes | High
NTP 1996a (mouse) | Yes | Yes | Yes | Yes | High
NTP 1996b (rat) | Yes | Yes | Yes | Yes | High
NTP 1996b (mouse) | Yes | Yes | Yes | Yes | High
NTP 1996c (rat) | Yes | Yes | Yes | Yes | High
NTP 1996c (mouse) | Yes | Yes | Yes | Yes | High
Oral acute exposure
Saini et al. 2013 (mouse) | Yes | Yes | Yes | Yes | High
Saini et al. 2014a (mouse) | Yes | Yes | Yes | Yes | High
Saini et al. 2014b (mouse, GDs 0–5) | Yes | Yes | Yes | Yes | High
Saini et al. 2014b (mouse, GDs 6–13) | Yes | Yes | Yes | Yes | High
Saini et al. 2014b (mouse, GDs 14–18) | Yes | Yes | Yes | Yes | High
Seidenberg et al. 1986 (mouse) | Yes | Yes | Yes | Yes | High
Sobti and Gill 1989 (mouse, nickel sulfate) | Yes | No | No | Yes | Low
Sobti and Gill 1989 (mouse, nickel nitrate) | Yes | No | No | Yes | Low
Sobti and Gill 1989 (mouse, nickel chloride) | Yes | No | No | Yes | Low
Oral intermediate exposure
Ambrose et al. 1976 (rat) | Yes | Yes | Yes | Yes | High
Käkelä et al. 1999 (rat; male 28 or 42 days prior to mating) | Yes | No | Yes | Yes | Moderate
Käkelä et al. 1999 (rat, female; 14 or 100 days prior to mating) | Yes | No | Yes | Yes | Moderate
Käkelä et al. 1999 (rat, Male and female; 28–76 days) | Yes | No | Yes | Yes | Moderate
Obone et al. 1999 (rat) | Yes | Yes | Yes | No | Moderate
Pandey and Srivastava 2000 (mouse, nickel chloride) | Yes | Yes | Yes | Yes | High
Pandey and Srivastava 2000 (mouse, nickel sulfate) | Yes | Yes | Yes | Yes | High
Pandey et al. 1999 (mouse, one dose group) | Yes | Yes | Yes | Yes | High
Pandey et al. 1999 (mouse, two dose groups) | Yes | Yes | Yes | Yes | High
EPA 1988a, 1988b (rat) | Yes | Yes | Yes | Yes | High
Smith et al. 1993 (rat) | Yes | Yes | Yes | Yes | High
Springborn Laboratories 2000a (rat) | Yes | Yes | Yes | Yes | High
Springborn Laboratories 2000b (rat) | Yes | Yes | Yes | Yes | High
Toman et al. 2012 (mouse) | Yes | Yes | Yes | Yes | High
Oral chronic exposure
Ambrose et al. 1976 (dog) | Yes | Yes | Yes | No | Moderate
Outcome: Developmental effects
Oral acute exposure
Saini et al. 2013 (mouse) | Yes | Yes | Yes | Yes | High
Saini et al. 2014a (mouse) | Yes | Yes | Yes | Yes | High
Saini et al. 2014b (mouse, GDs 0–5) | Yes | Yes | Yes | Yes | High
Saini et al. 2014b (mouse, GDs 6–13 | Yes | Yes | Yes | Yes | High
Saini et al. 2014b (Mouse, GDs 14–18) | Yes | Yes | Yes | Yes | High
Seidenberg et al. 1986 (mouse) | Yes | Yes | Yes | Yes | High
Oral intermediate exposure
Ambrose et al. 1976 (rat) | Yes | Yes | Yes | Yes | High
EPA 1983 (mouse) | Yes | Yes | Yes | Yes | High
Käkelä et al. 1999 (rat, 28 or 42 days prior to mating) | Yes | Yes | Yes | Yes | High
Käkelä et al. 1999 (rat, 14 or 100 days prior to mating) | Yes | Yes | Yes | Yes | High
Käkelä et al. 1999 (rat, 28–76 days) | Yes | Yes | Yes | Yes | High
EPA 1988a, 1988b (rat) | Yes | Yes | Yes | Yes | High
Smith et al. 1993 (rat) | Yes | Yes | Yes | Yes | High
Springborn Laboratories 2000a (rat) | Yes | Yes | Yes | Yes | High
Springborn Laboratories 2000b (rat) | Yes | Yes | Yes | Yes | High

A summary of the initial confidence ratings for each outcome is presented in Table C-15. If individual studies for a particular outcome and study type had different study quality ratings, then the highest confidence rating for the group of studies was used to determine the initial confidence rating for the body of evidence; any exceptions were noted in Table C-15.

Table C-15 Initial Confidence Rating for Nickel Health Effects Studies

| Initial study confidence | Initial confidence rating
Outcome: Respiratory effects
Inhalation exposure
Human cohort studies
Berge and Skyberg 2003 | Low | Moderate
Human cross-sectional studies
Fishwick et al. 2004 | Moderate | Moderate
Kilburn et al. 1990 | Moderate | Moderate
Muir et al. 1993 | Moderate | Moderate
Wu et al. 2022 | Moderate | Moderate
Animal acute exposure
Benson et al. 1995b (rat) | High | High
Efremenko et al. 2014 (rat) | High | High
Efremenko et al. 2017a, 2017b (rat) | High | High
NTP 1996a (rat) | High | High
NTP 1996a (mouse) | High | High
NTP 1996b (rat) | High | High
NTP 1996b (mouse) | High | High
NTP 1996c (rat) | High | High
NTP 1996c (mouse) | High | High
Animal intermediate exposure
Benson et al. 1995a (rat, nickel sulfate) | High | High
Benson et al. 1995a (rat, nickel oxide) | High | High
Benson et al. 1995a (mouse, nickel sulfate) | High | High
Benson et al. 1995a (mouse, nickel oxide) | High | High
Benson et al. 1995b (rat) | High | High
Bingham et al. 1972 (rat) | Moderate | High
Efremenko et al. 2014 (rat) | High | High
Efremenko et al. 2017a, 2017b (rat) | High | High
Evans et al. 1995 (rat) | High | High
Horie et al. 1985 (rat) | Low | High
NTP 1996a (rat) | High | High
NTP 1996a (mouse) | High | High
NTP 1996b (rat) | High | High
NTP 1996b (mouse) | High | High
NTP 1996c (rat) | High | High
NTP 1996c (mouse) | High | High
Oller et al. 2023 (rat, nickel sulfate) | High | High
Oller et al. 2023 (rat, nickel subsulfide) | High | High
Weischer et al. 1980 (rat) | High | High
Animal chronic exposure
NTP 1996a (rat) | High | High
NTP 1996a (mouse) | High | High
NTP 1996b (rat) | High | High
NTP 1996b (mouse) | High | High
NTP 1996c (rat) | High | High
NTP 1996c (mouse) | High | High
Oller et al. 2008 (rat) | High | High
Ottolenghi et al. 1975 (rat) | High | High
Takenaka et al. 1985 (rat) | Low | High
Tanaka et al. 1988 (rat) | Low | High
Oral exposure
Animal intermediate exposure
American Biogenics Corporation 1988 (rat) | High | High
Obone et al. 1999 (rat) | Moderate | High
EPA 1988a, 1988b (rat) | High | High
Springborn Laboratories 2002 (rat) | High | High
Animal chronic exposure
Ambrose et al. 1976 (dog) | Low
Outcome: Immunological effects
Inhalation exposure
Human cohort studies
Bencko et al. 1983 | Moderate | Moderate
Bencko et al. 1986 | Moderate | Moderate
Animal acute exposure
Adkins et al. 1979 (mouse, bacteria clearance) | High | High
Adkins et al. 1979 (mouse, nickel chloride) | High | High
Adkins et al. 1979 (mouse, nickel sulfate) | High | High
Buxton et al. 2021 (mouse) | High | High
Graham et al. 1978 (mouse) | High | High
NTP 1996a (rat) | High | High
NTP 1996a (mouse) | High | High
NTP 1996b (rat) | High | High
NTP 1996b (mouse) | High | High
NTP 1996c (rat) | High | High
NTP 1996c (mouse) | High | High
Animal intermediate exposure
Haley et al. 1990 (mouse, nickel oxide) | High | High
Haley et al. 1990 (mouse, nickel subsulfide) | High | High
Haley et al. 1990 (mouse, nickel sulfate) | High | High
Johansson et al. 1987 (rabbit) | Moderate | High
Johansson et al. 1988a, 1989 (rabbit) | Moderate | High
Morimoto et al. 1995 (rat) | Moderate | High
NTP 1996a (rat) | High | High
NTP 1996a (mouse) | High | High
NTP 1996b (rat) | High | High
NTP 1996b (mouse) | High | High
NTP 1996c (rat) | High | High
NTP 1996c (mouse) | High | High
Spiegelberg et al. 1984 (rat) | High | High
Animal chronic exposure
NTP 1996a (rat) | High | High
NTP 1996a (mouse) | High | High
NTP 1996b (rat) | High | High
NTP 1996b (mouse) | High | High
NTP 1996c (rat) | High | High
NTP 1996c (mouse) | High | High
Oller et al. 2008 (rat) | High | High
Ottolenghi et al. 1975 (rat) | High | High
Oral exposure
Animal intermediate exposure
Dieter et al. 1988 (mouse) | High | Moderate
Ilbäck et al. 1994 (mouse) | Moderate | Moderate
Obone et al. 1999 (rat) | Moderate | Moderate
Animal chronic exposure
Ambrose et al. 1976 (dog) | Low
Dermal exposure
Animal acute exposure
Siller and Seymour 1994 (mouse) | Moderate | Moderate
Outcome: Reproductive Effects
Human cohort studies
Chashschin et al. 1994 | Moderate | Moderate
Human case-control studies
Vaktskjold et al. 2008b | Moderate | Moderate
Inhalation exposure
Animal acute exposure
NTP 1996a (rat) | Moderate | Moderate
NTP 1996a (mouse) | Moderate | Moderate
NTP 1996b (rat) | Moderate | Moderate
NTP 1996b (mouse) | Moderate | Moderate
NTP 1996c (rat) | Moderate | Moderate
NTP 1996c (mouse) | Moderate | Moderate
Animal intermediate exposure
NTP 1996a (rat) | High | High
NTP 1996b (rat) | High | High
NTP 1996a (mouse) | High | High
NTP 1996b (mouse) | High | High
NTP 1996c (rat) | High | High
NTP 1996c (mouse) | High | High
Animal chronic exposure
NTP 1996a (rat) | High | High
NTP 1996a (mouse) | High | High
NTP 1996b (rat) | High | High
NTP 1996b (mouse) | High | High
NTP 1996c (rat) | High | High
NTP 1996c (mouse) | High | High
Oral exposure
Animal acute exposure
Saini et al. 2013 (mouse) | High | High
Saini et al. 2014a (mouse) | High | High
Saini et al. 2014b (mouse, GDs 0–5) | High | High
Saini et al. 2014b (mouse, GDs 6–13) | High | High
Saini et al. 2014b (mouse, GDs 14–18) | High | High
Seidenberg et al. 1986 (mouse) | High | High
Sobti and Gill 1989 (mouse, nickel sulfate) | Low | High
Sobti and Gill 1989 (mouse, nickel nitrate) | Low | High
Sobti and Gill 1989 (mouse, nickel chloride) | Low | High
Animal intermediate exposure
Ambrose et al. 1976 (rat) | High | High
Käkelä et al. 1999 (rat; male 28 or 42 days prior to mating) | Moderate | High
Käkelä et al. 1999 (rat, female; 14 or 100 days prior to mating) | Moderate | High
Käkelä et al. 1999 (rat, Male and female; 28–76 days) | Moderate | High
Obone et al. 1999 (rat) | Moderate | High
Pandey and Srivastava 2000 (mouse, nickel chloride) | High | High
Pandey and Srivastava 2000 (mouse, nickel sulfate) | High | High
Pandey et al. 1999 (mouse, one dose group) | High | High
Pandey et al. 1999 (mouse, two dose groups) | High | High
EPA 1988a, 1988b (rat) | High | High
Smith et al. 1993 (rat) | High | High
Springborn Laboratories 2000a (rat) | High | High
Springborn Laboratories 2000b (rat) | High | High
Toman et al. 2012 (mouse) | High | High
Animal chronic exposure
Ambrose et al. 1976 (dog) | Moderate | Moderate
Outcome: Developmental Effects
Human cohort studies
Chashschin et al. 1994 | Moderate | Moderate
Vaktskjold et al. 2006 | Moderate | Moderate
Vaktskjold et al. 2007 | Moderate | Moderate
Vaktskjold et al. 2008a | Moderate | Moderate
Oral exposure
Animal acute exposure
Saini et al. 2013 (mouse) | High | High
Saini et al. 2014a (mouse) | High | High
Saini et al. 2014b (mouse, GDs 0–5) | High | High
Saini et al. 2014b (mouse, GDs 6–13 | High | High
Saini et al. 2014b (Mouse, GDs 14–18) | High | High
Seidenberg et al. 1986 (mouse) | High | High
Animal intermediate exposure
Ambrose et al. 1976 (rat) | High | High
EPA 1983 (mouse) | High | High
Käkelä et al. 1999 (rat, 28 or 42 days prior to mating) | High | High
Käkelä et al. 1999 (rat, 14 or 100 days prior to mating) | High | High
Käkelä et al. 1999 (rat, 28–76 days) | High | High
EPA 1988a, 1988b (rat) | High | High
Smith et al. 1993 (rat) | High | High
Springborn Laboratories 2000a (rat) | High | High
Springborn Laboratories 2000b (rat) | High | High

### C.6.2 Adjustment of the Confidence Rating

The initial confidence rating was then downgraded or upgraded depending on whether there were substantial issues that would decrease or increase confidence in the body of evidence. The nine properties of the body of evidence that were considered are listed below. The summaries of the assessment of the confidence in the body of evidence for neurological effects are presented in Table C-16. If the confidence ratings for a particular outcome were based on more than one type of human study, then the highest confidence rating was used for subsequent analyses. An overview of the confidence in the body of evidence for all health effects associated with nickel exposure is presented in Table C-17.

Table C-16 Adjustments to the Initial Confidence in the Body of Evidence

| Initial confidence | Adjustments to the initial confidence rating | Final confidence
Outcome: Respiratory effects
Human studies | Moderate | −1 Risk of bias | Low
Animal studies | High | +1 Consistency | High
Outcome: Immunological effects
Human studies | Moderate | −1 Risk of bias | Low
Animal studies | High | | High
Outcome: Reproductive effects
Human studies | Moderate | −1 Inconsistency | Low
Animal studies | High | −2 Inconsistency | Low
Outcome: Developmental effects
Human studies | Moderate | −1 Inconsistency | Low
Animal studies | High | | High

Table C-17 Confidence in the Body of Evidence for Nickel

Outcome | Confidence in body of evidence
Outcome | Human studies | Animal studies
Respiratory effects | Moderate | High
Immunological effects | Low | High
Reproductive effects | Low | Low
Developmental effects | Low | High

Five properties of the body of evidence were considered to determine whether the confidence rating should be downgraded:

- Risk of bias. Evaluation of whether there is substantial risk of bias across most of the studies examining the outcome. This evaluation used the risk of bias tier groupings for individual studies examining a particular outcome (Tables C-8 and C-9). Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for risk of bias:
  ○ No downgrade if most studies are in the risk of bias first tier
  ○ Downgrade one confidence level if most studies are in the risk of bias second tier
  ○ Downgrade two confidence levels if most studies are in the risk of bias third tier
- Unexplained inconsistency. Evaluation of whether there is inconsistency or large variability in the magnitude or direction of estimates of effect across studies that cannot be explained. Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for unexplained inconsistency:
  ○ No downgrade if there is little inconsistency across studies or if only one study evaluated the outcome
  ○ Downgrade one confidence level if there is variability across studies in the magnitude or direction of the effect
  ○ Downgrade two confidence levels if there is substantial variability across studies in the magnitude or direct of the effect
- Indirectness. Evaluation of four factors that can affect the applicability, generalizability, and relevance of the studies:
  ○ Relevance of the animal model to human health—unless otherwise indicated, studies in rats, mice, and other mammalian species are considered relevant to humans
  ○ Directness of the endpoints to the primary health outcome—examples of secondary outcomes or nonspecific outcomes include organ weight in the absence of histopathology or clinical chemistry findings in the absence of target tissue effects
  ○ Nature of the exposure in human studies and route of administration in animal studies—inhalation, oral, and dermal exposure routes are considered relevant unless there are compelling data to the contrary
  ○ Duration of treatment in animal studies and length of time between exposure and outcome assessment in animal and prospective human studies—this should be considered on an outcome-specific basis
  Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for indirectness:
  ○ No downgrade if none of the factors are considered indirect
  ○ Downgrade one confidence level if one of the factors is considered indirect
  ○ Downgrade two confidence levels if two or more of the factors are considered indirect
- Imprecision. Evaluation of the narrowness of the effect size estimates and whether the studies have adequate statistical power. Data are considered imprecise when the ratio of the upper to lower 95% CIs for most studies is ≥10 for tests of ratio measures (e.g., odds ratios) and ≥100 for absolute measures (e.g., percent control response). Adequate statistical power is determined if the study can detect a potentially biologically meaningful difference between groups (20% change from control response for categorical data or risk ratio of 1.5 for continuous data). Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for imprecision:
  ○ No downgrade if there are no serious imprecisions
  ○ Downgrade one confidence level for serious imprecisions
  ○ Downgrade two confidence levels for very serious imprecisions
- Publication bias. Evaluation of the concern that studies with statistically significant results are more likely to be published than studies without statistically significant results.
  ○ Downgrade one level of confidence for cases where there is serious concern with publication bias

Four properties of the body of evidence were considered to determine whether the confidence rating should be upgraded:

- Large magnitude of effect. Evaluation of whether the magnitude of effect is sufficiently large so that it is unlikely to have occurred as a result of bias from potential confounding factors.
  ○ Upgrade one confidence level if there is evidence of a large magnitude of effect in a few studies, provided that the studies have an overall low risk of bias and there is no serious unexplained inconsistency among the studies of similar dose or exposure levels; confidence can also be upgraded if there is one study examining the outcome, provided that the study has an overall low risk of bias
- Dose response. Evaluation of the dose-response relationships measured within a study and across studies. Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level for evidence of a monotonic dose-response gradient
  ○ Upgrade one confidence level for evidence of a non-monotonic dose-response gradient where there is prior knowledge that supports a non-monotonic dose-response and a non-monotonic dose-response gradient is observed across studies
- Plausible confounding or other residual biases. This factor primarily applies to human studies and is an evaluation of unmeasured determinants of an outcome such as residual bias towards the null (e.g., “healthy worker” effect) or residual bias suggesting a spurious effect (e.g., recall bias). Below is the criterion used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level for evidence that residual confounding or bias would underestimate an apparent association or treatment effect (i.e., bias toward the null) or suggest a spurious effect when results suggest no effect
- Consistency in the body of evidence. Evaluation of consistency across animal models and species, consistency across independent studies of different human populations and exposure scenarios, and consistency across human study types. Below is the criterion used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level if there is a high degree of consistency in the database

## C.7 TRANSLATE CONFIDENCE RATING INTO LEVEL OF EVIDENCE OF HEALTH EFFECTS

In the seventh step of the systematic review of the health effects data for nickel, the confidence in the body of evidence for specific outcomes was translated to a level of evidence rating. The level of evidence rating reflected the confidence in the body of evidence and the direction of the effect (i.e., toxicity or no toxicity); route-specific differences were noted. The level of evidence for health effects was rated on a five-point scale:

- High level of evidence: High confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Moderate level of evidence: Moderate confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Low level of evidence: Low confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Evidence of no health effect: High confidence in the body of evidence that exposure to the substance is not associated with the health outcome
- Inadequate evidence: Low or moderate confidence in the body of evidence that exposure to the substance is not associated with the health outcome OR very low confidence in the body of evidence for an association between exposure to the substance and the health outcome

A summary of the level of evidence of health effects for nickel is presented in Table C-18.

Table C-18 Level of Evidence of Health Effects for Nickel

Outcome | Confidence in body of evidence | Direction of health effect | Level of evidence for health effect
Human studies
Respiratory effects | Moderate | Health effect | Moderate
Immunological effects | Low | Health effect | Low
Reproductive effects | Low | Uncertain | Low
Developmental effects | Low | Health effect | Low
Animal studies
Respiratory effects | High | Health effect | High
Immunological effects | High | Health effect | High
Reproductive effects | Low | Uncertain | High
Developmental effects | High | Health effect | High

## C.8 INTEGRATE EVIDENCE TO DEVELOP HAZARD IDENTIFICATION CONCLUSIONS

The final step involved the integration of the evidence streams for the human studies and animal studies to allow for a determination of hazard identification conclusions. For health effects, there were four hazard identification conclusion categories:

- Known to be a hazard to humans
- Presumed to be a hazard to humans
- Suspected to be a hazard to humans
- Not classifiable as to the hazard to humans

The initial hazard identification was based on the highest level of evidence in the human studies and the level of evidence in the animal studies; if there were no data for one evidence stream (human or animal), then the hazard identification was based on the one data stream (equivalent to treating the missing evidence stream as having low level of evidence). The hazard identification scheme is presented in Figure C-1 and described below:

- Known: A health effect in this category would have:
  ○ High level of evidence for health effects in human studies AND a high, moderate, or low level of evidence in animal studies.
- Presumed: A health effect in this category would have:
  ○ Moderate level of evidence in human studies AND high or moderate level of evidence in animal studies OR
  ○ Low level of evidence in human studies AND high level of evidence in animal studies
- Suspected: A health effect in this category would have:
  ○ Moderate level of evidence in human studies AND low level of evidence in animal studies OR
  ○ Low level of evidence in human studies AND moderate level of evidence in animal studies
- Not classifiable: A health effect in this category would have:
  ○ Low level of evidence in human studies AND low level of evidence in animal studies

Other relevant data such as mechanistic or mode-of-action data were considered to raise or lower the level of the hazard identification conclusion by providing information that supported or opposed biological plausibility.

Figure C-1 Hazard Identification Scheme

Two hazard identification conclusion categories were used when the data indicated that there may be no health effect in humans:

- Not identified to be a hazard in humans
- Inadequate to determine hazard to humans

If the human level of evidence conclusion of no health effect was supported by the animal evidence of no health effect, then the hazard identification conclusion category of “not identified” was used. If the human or animal level of evidence was considered inadequate, then a hazard identification conclusion category of “inadequate” was used. As with the hazard identification for health effects, the impact of other relevant data was also considered for no health effect data.

The hazard identification conclusions for nickel are listed below and summarized in Table C-19.

Presumed Health Effects

- Respiratory effects
  ○ Low level of evidence from human studies of occupational cohorts exposed via inhalation (Berge and Skyberg 2003; Fishwick et al. 2004; Kilburn et al. 1990; Syurin and Vinnikov 2022; Wu et al. 2022).
  ○ High level of evidence in rats and mice from acute-duration exposure to nickel (Benson et al. 1995b; Efremenko et al. 2014, 2017a, 2017b; NTP 1996a, 1996b, 1996c), intermediate-duration exposure to nickel (Benson et al. 1995a, 1995b; Efremenko et al. 2014, 2017a, 2017b; Evans et al. 1995; Horie et al. 1985; NTP 1996a, 1996b, 1996c; Oller et al. 2023 Weischer et al. 1980), and chronic-duration exposure to nickel (NTP 1996a, 1996b, 1996c; Oller et al. 2008; Ottolenghi et al. 1975; Takenaka et al. 1985; Tanaka et al. 1988).
  ○ High level of evidence in rats following acute-, intermediate-, and chronic-duration oral exposure (Ambrose et al. 1976; American Biogenics Corporation 1988; EPA 1988a, 1988b; Obone et al. 1999; Springborn Laboratories 2002).
- Immunological effects
  ○ Low evidence from human inhalation studies due to the lack of controls and lack of confidence in the exposures (Bencko et al. 1983, 1986).
  ○ High level of evidence in rats, mice, and rabbits from inhalation exposure to nickel (Adkins et al. 1979; Graham et al. 1978; Haley et al. 1990; Johansson et al. 1987, 1988a, 1989; Morimoto et al. 1995; Oller et al. 2008).
  ○ High level of evidence in mice and rats from oral exposure to nickel (Dieter et al. 1988; Ilbäck et al. 1994; Obone et al. 1999), and in dogs (Ambrose et al. 1976).
- Developmental effects
  ○ Low evidence from human studies due to the small number of studies and inconsistencies of the findings (Chashschin et al. 1994; Vaktskjold et al. 2006, 2007, 2008a).
  ○ High level of evidence from animal inhalation (Weischer et al. 1980) studies and oral studies (Ambrose et al. 1976; El-Sekily et al. 2020; EPA 1983, 1988a, 1988b; Käkelä et al. 1999; Saini et al. 2013, 2014a, 2014b; Seidenberg et al. 1986; Smith et al. 1993; Springborn Laboratories 2000b).

Not Classifiable

- Reproductive effects
  ○ Low evidence from human studies due to the inconsistency of the findings (Chashschin et al. 1994; Vaktskjold et al. 2008b).
  ○ Low level of evidence from animal studies. Male reproductive effects were observed in rats exposed via inhalation to nickel oxide (NTP 1996a) but not after exposure to nickel subsulfide or nickel sulfate (NTP 1996b, 1996c). There was a high degree of inconsistency among the oral exposure studies examining male reproductive effects, with some studies finding effects (Käkelä et al. 1999; Pandey and Srivastava 2000; Pandey et al. 1999; Sobti and Gill 1989) and other studies finding no effects (Ambrose et al. 1976; American Biogenics Corporation 1988; Obone et al. 1999; Smith et al. 1993; Springborn Laboratories 2000b; Toman et al. 2012).

Table C-19 Hazard Identification Conclusions for Nickel

Outcome | Hazard identification
Respiratory effects | Presumed health effect
Immunological effects | Presumed health effect
Reproductive effects | Not classifiable
Developmental effects | Presumed health effect