# APPENDIX B LITERATURE SEARCH FRAMEWORK FOR NICKEL

The objective of the toxicological profile is to evaluate the potential for human exposure and the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to nickel.

## B.1 LITERATURE SEARCH AND SCREEN

A literature search and screen were conducted to identify studies examining health effects, toxicokinetics, mechanisms of action, susceptible populations, biomarkers, chemical interactions, physical and chemical properties, production, use, environmental fate, environmental releases, and environmental and biological monitoring data for nickel. ATSDR primarily focused on peer-reviewed articles without publication date or language restrictions. Foreign language studies are reviewed based on available English-language abstracts and/or tables (or summaries in regulatory assessments, such as International Agency for Research on Cancer [IARC] documents). If the study appears critical for hazard identification or MRL derivation, translation into English is requested. Non-peer-reviewed studies that were considered relevant to the assessment of the health effects of nickel have undergone peer review by at least three ATSDR-selected experts who have been screened for conflict of interest. The inclusion criteria used to identify relevant studies examining the health effects of nickel are presented in Table B-1.

Table B-1 Inclusion Criteria for the Literature Search and Screen

- Health Effects; - Species; - Human; - Laboratory mammals; - Route of exposure; - Inhalation; - Oral; - Dermal (or ocular); - Parenteral (these studies will be considered supporting data); - Health outcome; - Death; - Systemic effects; - Body weight effects; - Respiratory effects; - Cardiovascular effects; - Gastrointestinal effects; - Hematological effects; - Musculoskeletal effects; - Hepatic effects; - Renal effects; - Dermal effects; - Ocular effects; - Endocrine effects; - Immunological effects; - Neurological effects; - Reproductive effects; - Developmental effects; - Other noncancer effects; - Cancer; - Toxicokinetics; - Absorption; - Distribution; - Metabolism; - Excretion; - PBPK models; - Biomarkers; - Biomarkers of exposure; - Biomarkers of effect; - Interactions with other chemicals; - Potential for human exposure; - Releases to the environment; - Air; - Water; - Soil; - Environmental fate; - Transport and partitioning; - Transformation and degradation; - Environmental monitoring; - Air; - Water; - Sediment and soil; - Other media; - Biomonitoring; - General populations; - Occupation populations

### B.1.1 Literature Search

The current literature search was intended to update the Draft Toxicological Profile for Nickel released for public comment in 2023; thus, the literature search was restricted to studies published between January 2020 and October 2023. The following main databases were searched in October 2023:

- PubMed
- National Technical Reports Library (NTRL)
- Scientific and Technical Information Network’s TOXCENTER

The search strategy used the chemical names, Chemical Abstracts Service (CAS) numbers, synonyms, Medical Subject Headings (MeSH) headings, and keywords for nickel. The query strings used for the literature search are presented in Table B-2.

The search was augmented by searching the Toxic Substances Control Act Test Submissions (TSCATS), NTP website, and National Institute of Health Research Portfolio Online Reporting Tools Expenditures and Results (NIH RePORTER) databases using the queries presented in Table B-3. Additional databases were searched in the creation of various tables and figures, such as the TRI Explorer, the Substance Priority List (SPL) resource page, and other items as needed. Regulations applicable to nickel were identified by searching international and U.S. agency websites and documents.

Review articles were identified and used for the purpose of providing background information and identifying additional references. ATSDR also identified reports from the grey literature, which included unpublished research reports, technical reports from government agencies, conference proceedings and abstracts, and theses and dissertations.

Table B-2 Database Query Strings

Database search date | Query string
PubMed
10/2023 | (((7440-02-0[rn] OR 373-02-4[rn] OR 7718-54-9[rn] OR 1313-99-1[rn] OR 7786-81-4[rn] OR 13138-45-9[rn] OR 15699-18-0[rn] OR 3333-67-3[rn] OR (“Dicyanonickel”[tw] OR “Nickel cyanide”[tw]) OR 13770-89-3[rn]) AND (((“NICKEL/toxicity”[mh] OR “NICKEL/adverse effects”[mh] OR “NICKEL/poisoning”[mh] OR “NICKEL/pharmacokinetics”[mh] OR “environmental exposure”[mh] OR ci[sh] OR toxicokinetics[mh:noexp] OR “NICKEL/blood”[mh] OR “NICKEL/cerebrospinal fluid”[mh] OR “NICKEL/urine”[mh] OR “endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh] OR (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic ”[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh]) OR “NICKEL/antagonists and inhibitors”[mh] OR (“NICKEL/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR “NICKEL/pharmacology”[majr] OR (“Neoplasms”[mh] OR “Carcinogens”[mh] OR “Lymphoproliferative disorders”[mh] OR “Myeloproliferative disorders”[mh] OR “Toxicity Tests”[mh] OR ((cancer*[tiab] OR carcinogen*[tiab]) AND (risk*[tiab] OR health[tiab]) AND assessment*[tiab]) OR “Mutagens”[mh] OR “Mutagenicity Tests”[mh] OR “Chromosome Aberrations”[mh] OR “DNA Damage”[mh] OR “DNA Repair”[mh] OR “DNA Replication/drug effects”[mh] OR “DNA/drug effects”[mh] OR “DNA/metabolism”[mh] OR “Genomic Instability”[mh] OR “Salmonella typhimurium/drug effects”[mh] OR “Salmonella typhimurium/genetics”[mh] OR “Sister Chromatid Exchange”[mh] OR strand-break*[tiab]) OR (Nickel[mh] AND (indexingmethod_automated OR indexingmethod_curated) AND (“RNA”[mh] OR “DNA”[mh] OR “DNA Replication”[mh] OR “Salmonella typhimurium”[mh] OR antagonist*[tw] OR inhibitor*[tw] OR “blood”[tw] OR “serum”[tw] OR “plasma”[tw] OR pharmacokinetic*[tw] OR toxicokinetic*[tw] OR “pbpk”[tw] OR “poisoned”[tw] OR “poisoning”[tw] OR “urine”[tw] OR “urinary”[tw] OR “toxicity”[sh] OR “occupational diseases”[mh] OR “hazardous substances”[mh] OR “epidemiology”[sh] OR “epidemiologic studies”[mh])))) OR “Sulfonic Acids”[mh] OR “Organometallic Compounds”[mh]) AND (2020:3000[mhda]))) OR (((((“(Oxido)nickel”[tw] OR “Ammonium disulfatonickelate(II)”[tw] OR “Bunsenite”[tw] OR “Dicyanonickel”[tw] OR “Mononickel oxide”[tw] OR “Ni 210”[tw] OR “Nickel”[tw] OR “Nickelacetat”[tw] OR “Nickelcarbonat”[tw] OR “Nickelchlorid”[tw] OR “Nickeldi(acetat)”[tw] OR “Nickeldichlorid”[tw] OR “Nickelmonoxid”[tw] OR “Nickelous acetate”[tw] OR “Nickelous carbonate”[tw] OR “Nickelous chloride”[tw] OR “Nickelous nitrate”[tw] OR “Nickelous oxide”[tw] OR “Nickelous sulfate”[tw] OR “Nickelous sulphate”[tw] OR “Nickelsulfat”[tw] OR “Raney Ni”[tw] OR “Carbonyl 255”[tw] OR “Carbonyl Ni 123”[tw] OR “Carbonyl Ni 283”[tw] OR “Celmet”[tw] OR “Cerac N 2003”[tw] OR “Fine Emerald”[tw] OR “Inco 210”[tw] OR “Incofoam”[tw] OR “Melbright EF 2201”[tw] OR “MG-Ni 50”[tw] OR “MG-Ni 600”[tw] OR “Ni 006021”[tw] OR “Ni 0901-S”[tw] OR “NI 0901-S (harshaw)”[tw] OR “NI 110104”[tw] OR “NI 123”[tw] OR “Ni 123J”[tw] OR “Ni 123T”[tw] OR “Ni 255”[tw] OR “NI 255AC”[tw] OR “NI 255T”[tw] OR “NI 255T280”[tw] OR “Ni 270”[tw] OR “NI 287”[tw] OR “NI 313324”[tw] OR “NI 313463”[tw] OR “NI 313551”[tw] OR “Ni 4303T”[tw] OR “NI 525”[tw] OR “Ni Celmet”[tw] OR “Ni Powder CuLox 5100A”[tw] OR “Niccolum metallicum”[tw] OR “Nichel(II) chloride”[tw] OR “Nicobraz LM BNI2”[tw] OR “Nicrobraz LM:BNi 2”[tw] OR “NiFL 5”[tw] OR “NiFLA 10”[tw] OR “Ni-Flake 95”[tw] OR “Ni-J 20”[tw] OR “Nikko 255”[tw] OR “Nikko Rica 123”[tw] OR “NiO-D”[tw] OR “NiO-FP”[tw] OR “NiO-G 39”[tw] OR “NiS 10”[tw] OR “Novamet 123”[tw] OR “Novamet 4SP”[tw] OR “Novamet 4SP10”[tw] OR “Novamet 525”[tw] OR “Novamet CNS 400”[tw] OR “Novamet HCA 1”[tw] OR “Novamet NI 255”[tw] OR “Raney 2400”[tw] OR “Raney 2486”[tw] OR “Raney 2800”[tw] OR “Raney 3110”[tw] OR “Raney 3202”[tw] OR “Raney 4200”[tw] OR “Raney 5831”[tw] OR “Raney 5886”[tw] OR “Raney alloy”[tw] OR “SF-Ni”[tw] OR “SFR-Ni”[tw] OR “Sun Ti-Ni”[tw] OR “Top Seal DX 300”[tw] OR “Top Seal H 298”[tw]) NOT medline[sb])) AND 2020:3000[dp] AND (toxicity[ti] OR death OR lethal OR fatal OR fatality OR necrosis OR LC50* OR LD50* OR “body weight” OR “weight loss” OR “weight gain” OR weight-change* OR overweight OR obesity OR inhal* OR respiratory OR “pulmonary edema” OR “pulmonary effect” OR “pulmonary system” OR “pulmonary function” OR “pulmonary organ” OR “pulmonary toxicity” OR airway OR trachea OR tracheobronchial OR lung OR lungs OR nose OR nasal OR nasopharyngeal OR larynx OR laryngeal OR pharynx OR bronchial OR bronchi OR bronchioles OR bronchitis OR hemothorax OR alveolar OR alveoli OR irritation OR irritant OR sensitization OR sensitizer OR cilia OR mucocilliary OR cvd OR cardio OR vascular OR cardiovascular OR “circulatory system” OR “circulatory function” OR “circulatory effect” OR “circulatory organ” OR “circulatory toxicity” OR “cardiac arrest” OR “cardiac palpitation” OR “cardiac arrhythmia” OR “cardiac edema” OR “heart rate” OR “heart failure” OR “heart attack” OR “heart muscle” OR “heart beat” OR “myocardial-infarction” OR “chest pain” OR artery OR arteries OR veins OR venules OR cardiotox* OR “gastro-intestinal” OR gastrointestinal OR “digestive system” OR “digestive function” OR “digestive effect” OR “digestive organ” OR “Intestinal system” OR “intestinal function” OR “intestinal microbiota” OR “intestinal effect” OR “intestinal organ” OR “gi tract” OR “gi disorder” OR abdominal OR esophagus OR stomach OR intestine OR pancreas OR pancreatic OR diarrhea OR nausea OR vomit OR ulcer OR constipation OR emesis OR “gut microbes” OR “gut flora” OR “gut microflora” OR anorexia OR hematological OR hematology OR hemato OR haemato OR blood OR anemia OR cyanosis OR erythrocytopenia OR leukopenia OR thrombocytopenia OR hemoglobin OR erythrocyte OR hematocrit OR “bone marrow” OR reticulocyte OR methemoglobin OR red-blood-cell OR musculoskeletal OR skeletal OR muscle OR muscular OR arthritis OR “altered bone” OR “joint pain” OR “joint-ache” OR “limb pain” OR “limb ache” OR hepatic OR “liver system” OR “liver function” OR “liver effect” OR “liver organ” OR “Liver enzyme” OR “liver weight” OR “liver congestion” OR “liver changes” OR “liver biochemical changes” OR “liver toxicity” OR hepatocytes OR gallbladder OR cirrhosis OR jaundice OR “hepatocellular degeneration” OR “hepatocellular hypertrophy” OR hepatomegaly OR hepatotox* OR renal OR “kidney system” OR “kidney function” OR “Kidney effect” OR “kidney toxicity” OR “urinary system” OR “urinary function” OR “urinary effect” OR “Urinary toxicity” OR “bladder system” OR “bladder effect” OR “bladder function” OR “bladder toxicity” OR “Urine volume” OR “blood urea nitrogen” OR bun OR nephropathy OR nephrotox* OR dermal OR “skin rash” OR “skin itch” OR “skin irritation” OR “skin redness” OR “skin effect” OR “skin necrosis” OR “skin exposure” OR “skin contact” OR acanthosis OR dermatitis OR psoriasis OR edema OR ulceration OR acne OR ocular OR “eye function” OR “eye effect” OR “eye irritation” OR “eye drainage” OR “eye tearing” OR blindness OR myopia OR cataracts OR endocrine OR “hormone changes” OR “hormone excess” OR “hormone deficiency” OR “hormone gland” OR “hormone secretion” OR “hormone toxicity” OR “sella turcica” OR thyroid OR adrenal OR pituitary OR immunological OR immunologic OR immune OR lymphoreticular OR lymph-node OR spleen OR thymus OR macrophage OR leukocyte* OR white-blood-cell OR immunotox* OR neurological OR neurologic OR neurotoxic OR neurotoxicity OR neurodegenerat* OR “nervous system” OR brain OR neurotoxicant OR neurochemistry OR neurophysiology OR neuropathology OR “motor activity” OR motor change* OR behavior-change* OR behavioral-change* OR sensory-change* OR cognitive OR vertigo OR drowsiness OR headache OR ataxia OR reproductive OR “reproduction system” OR “reproduction function” OR “reproduction effect” OR “reproduction toxicity” OR fertility OR “maternal toxicity” OR developmental OR “in utero” OR terata* OR terato* OR embryo* OR fetus* OR foetus* OR fetal* OR foetal* OR prenatal* OR “pre-natal” OR perinatal* OR “post-natal” OR postnatal* OR neonat* OR newborn* OR zygote* OR child OR children OR infant* OR offspring OR elderly OR “altered food consumption” OR “altered water consumption” OR “metabolic effect” OR “metabolic toxicity” OR fever OR cancer OR cancerous OR neoplas* OR tumor OR tumors OR tumour* OR malignan* OR carcinoma OR carcinogen OR carcinogen* OR angiosarcoma OR blastoma OR fibrosarcoma OR glioma OR leukemia OR leukaemia OR lymphoma OR melanoma OR meningioma OR mesothelioma OR myeloma OR neuroblastoma OR osteosarcoma OR sarcoma OR mutation OR mutations OR genotoxicity OR genotoxic OR mutagenicity OR mutagenic OR “mechanism of action”[tiab:~0] OR “mechanism of absorption”[tiab:~0] OR “mechanism of distribution”[tiab:~0] OR “mechanism of excretion”[tiab:~0] OR “mechanism of metabolism”[tiab:~0] OR “mechanism of toxic effect”[tiab:~0] OR “mechanism of toxicity” OR “adverse effect” OR “adverse effects” OR “health effects” OR noncancer OR poisoning OR morbidity OR inflammation OR antagonist OR inhibitor OR metabolism OR “environmental exposure” OR toxicokinetics OR pharmacokinetics OR “gene expression” OR “population health” OR epidemiology OR epidemiological OR case-control* OR case-referent OR case-report OR case-series OR cohort* OR correlation-stud* OR cross-sectional-stud* OR ecological-studies OR ecological-study OR follow-up-stud* OR longitudinal-stud* OR metaanalyses OR metaanalysis OR meta-analysis OR prospective-stud* OR record-link* OR retrospective-stud* OR seroepidemiologic-stud* OR occupation* OR worker* OR workmen* OR workplace* OR “human health” OR “oral intake” OR “oral feed” OR “oral ingestion” OR “oral exposure” OR “oral administration” OR ingest* OR gavage* OR “drinking-water” OR NHANES OR “National Health and Nutrition Examination Survey” OR (human AND (risk OR toxic* OR safety)) OR mammal* OR ape OR apes OR baboon* OR balb OR beagle* OR boar OR boars OR bonobo* OR bovine OR C57 OR C57bl OR callithrix OR canine OR canis OR capra OR capuchin* OR cats OR cattle OR cavia OR chicken OR chickens OR chimpanzee* OR chinchilla* OR cow OR cows OR cricetinae OR dog OR dogs OR equus OR feline OR felis OR ferret OR ferrets OR flying-fox OR Fruit-bat OR gerbil* OR gibbon* OR goat OR goats OR guinea-pig* OR guppy OR hamster OR hamsters OR horse OR horses OR jird OR jirds OR lagomorph* OR leontopithecus OR longevans OR macaque* OR marmoset* OR medaka OR merione OR meriones OR mice OR monkey OR monkeys OR mouse OR muridae OR murinae OR murine OR mustela-putorius OR nomascus OR non-human-primate* OR orangutan* OR pan-paniscus OR pan-troglodytes OR pig OR piglet* OR pigs OR polecat* OR pongopygmaeus OR quail OR rabbit OR rabbits OR rat OR rats OR rhesus OR rodent OR rodentia OR rodents OR saguinus OR sheep OR sheeps OR siamang* OR sow OR sows OR Sprague-Dawley OR swine OR swines OR symphalangus OR tamarin* OR vervet* OR wistar OR wood-mouse OR zebra-fish OR zebrafish)))
NTRL
10/2023 | Limited to 2020 to present; terms searched in title or keyword; “Nickel” OR “(Oxido)nickel” OR “Ammonium disulfatonickelate(II)” OR “Bunsenite” OR “Dicyanonickel” OR “Mononickel oxide” OR “Ni 210” OR “Nickelacetat” OR “Nickelcarbonat” OR “Nickelchlorid” OR “Nickeldi(acetat)” OR “Nickeldichlorid” OR “Nickelmonoxid” OR “Nickelous acetate” OR “Nickelous carbonate” OR “Nickelous chloride” OR “Nickelous nitrate” OR “Nickelous oxide” OR “Nickelous sulfate” OR “Nickelous sulphate” OR “Nickelsulfat” OR “Raney Ni”
Toxcenter
10/2023 | FILE ‘TOXCENTER’ ENTERED AT 10:29:54 ON 24 OCT 2023; L1 187783 SEA 7440-02-0 OR 373-02-4 OR 7718-54-9 OR 1313-99-1 OR 7786-81-4 OR 13138-45-9 OR 15699-18-0 OR 3333-67-3 OR 557-19-7 OR 13770-89-3; L2 33611 SEA L1 AND PY>2019; L3 28623 SEA L2 NOT PATENT/DT; ACT TOXQUERY/Q; -------; L4 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?); L5 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT,; IT); L6 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50); L7 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT; L8 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?); L9 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?); L10 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS OR; - DIETARY OR DRINKING(W)WATER?); L11 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE)); L12 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?); L13 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM? OR; OVUM?); L14 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?); L15 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?); L16 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR; SPERMATOB? OR SPERMATOC? OR SPERMATOG?); L17 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR; SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?); L18 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?); L19 QUE (ENDOCRIN? AND DISRUPT?); L20 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?); L21 QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?); L22 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?); L23 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR; NEOPLAS?); L24 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?); L25 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?); L26 QUE (NEPHROTOX? OR HEPATOTOX?); L27 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?); L28 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?); L29 QUE L4 OR L5 OR L6 OR L7 OR L8 OR L9 OR L10 OR L11 OR L12 OR L13 OR L14 OR L15 OR L16 OR L17 OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26 OR L27 OR L28; L30 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE; OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR SWINE; OR PORCINE OR MONKEY? OR MACAQUE?); L31 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA; OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE); L32 QUE L29 OR L30 OR L31; L33 QUE (NONHUMAN MAMMALS)/ORGN; L34 QUE L32 OR L33; L35 QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL? OR; PRIMATES OR PRIMATE?); L36 QUE L34 OR L35; -------; L38 11491 SEA L3 AND L32; L41 752 SEA L38 AND MEDLINE/FS; L42 2371 SEA L38 AND BIOSIS/FS; L43 8356 SEA L38 AND CAPLUS/FS; L44 10143 DUP REM L41 L42 L43 (1336 DUPLICATES REMOVED); L*** DEL 752 S L38 AND MEDLINE/FS; L*** DEL 752 S L38 AND MEDLINE/FS; L45 750 SEA L44; L*** DEL 2371 S L38 AND BIOSIS/FS; L*** DEL 2371 S L38 AND BIOSIS/FS; L46 2217 SEA L44; L*** DEL 8356 S L38 AND CAPLUS/FS; L*** DEL 8356 S L38 AND CAPLUS/FS; L47 7176 SEA L44; L48 9393 SEA (L45 OR L46 OR L47) NOT MEDLINE/FS

Table B-3 Strategies to Augment the Literature Search

Source | Query and number screened when available
TSCATS via ChemView
10/2023 | Compounds searched: 7440-02-0; 373-02-4; 7718-54-9; 1313-99-1; 7786-81-4; 13138-45-9; 3333-67-3; 13770-89-3; 557-19-7; 15699-18-0
NTP
10/2023 | 7440-02-0 7786-81-4 1313-99-1 373-02-4; 7718-54-9 3333-67-3; “Bunsenite” “Mononickel oxide” “Nickelous chloride” “Nickelous oxide” “Nickelous sulfate” “Nickelous sulphate”; 15699-18-0 557-19-7 13770-89-3 13138-45-9; “Ammonium disulfatonickelate(II)” “Dicyanonickel” “Ni 210” “Nickelacetat” “Nickelcarbonat” “Nickelous acetate” “Nickelchlorid” “Nickeldi(acetat)” “Nickeldichlorid” “Nickelmonoxid” “Nickelous carbonate” “Nickelous nitrate” “Nickelsulfat” “(Oxido)nickel” “Raney Ni”
Regulations.gov
10/2023 | “Nickel”; “Bunsenite”; “Mononickel oxide”; “Nickelous chloride”; “Nickelous oxide”; “Nickelous sulfate”; “Nickelous sulphate”; “Ammonium disulfatonickelate(II)”; “Dicyanonickel”; “Ni 210”; “Nickelacetat”; “Nickelcarbonat”; “Nickelous acetate”; “Nickelchlorid”; “Nickeldi(acetat)”; “Nickeldichlorid”; “Nickelmonoxid”; “Nickelous carbonate”; “Nickelous nitrate”; “Nickelsulfat”; “(Oxido)nickel”; “Raney Ni”; “7440-02-0”; “373-02-4”; “7718-54-9”; “1313-99-1”; “7786-81-4”; “13138-45-9”; “15699-18-0”; “3333-67-3”; “557-19-7”; “13770-89-3”
NIH RePORTER
03/2024 | Fiscal Year: Active Projects; Text Search: “(Oxido)nickel” OR “Ammonium disulfatonickelate(II)” OR “Bunsenite” OR “Dicyanonickel” OR “Mononickel oxide” OR “Ni 210” OR “Nickel” OR “Nickelacetat” OR “Nickelcarbonat” OR “Nickelchlorid” OR “Nickeldi(acetat)” OR “Nickeldichlorid” OR “Nickelmonoxid” OR “Nickelous acetate” OR “Nickelous carbonate” OR “Nickelous chloride” OR “Nickelous nitrate” OR “Nickelous oxide” OR “Nickelous sulfate” OR “Nickelous sulphate” OR “Nickelsulfat” OR “Raney Ni” OR “Carbonyl 255” OR “Carbonyl Ni 123” OR “Carbonyl Ni 283” OR “Celmet” OR “Cerac N 2003” OR “Fine Emerald” OR “Inco 210” OR “Incofoam” OR “Melbright EF 2201” OR “MG-Ni 50” OR “MG-Ni 600” OR “Ni 006021” OR “Ni 0901-S” OR “NI 0901-S (harshaw)” OR “NI 110104” OR “NI 123” OR “Ni 123J” OR “Ni 123T” OR “Ni 255” OR “NI 255AC” OR “NI 255T” OR “NI 255T280” OR “Ni 270” OR “NI 287” OR “NI 313324” OR “NI 313463” OR “NI 313551” OR “Ni 4303T” OR “NI 525” OR “Ni Celmet” OR “Ni Powder CuLox 5100A” OR “Niccolum metallicum” OR “Nichel(II) chloride” OR “Nicobraz LM BNI2” OR “Nicrobraz LM:BNi 2” OR “NiFL 5” OR “NiFLA 10” OR “Ni-Flake 95” OR “Ni-J 20” OR “Nikko 255” OR “Nikko Rica 123” OR “NiO-D” OR “NiO-FP” OR “NiO-G 39” OR “NiS 10” OR “Novamet 123” OR “Novamet 4SP” OR “Novamet 4SP10” OR “Novamet 525” OR “Novamet CNS 400” OR “Novamet HCA 1” OR “Novamet NI 255” OR “Raney 2400” OR “Raney 2486” OR “Raney 2800” OR “Raney 3110” OR “Raney 3202” OR “Raney 4200” OR “Raney 5831” OR “Raney 5886” OR “Raney alloy” OR “SF-Ni” OR “SFR-Ni” OR “Sun Ti-Ni” OR “Top Seal DX 300” OR “Top Seal H 298” (advanced) Limit to: Project Title, Project Terms, Project Abstracts
Other | Identified throughout the assessment process

The 2023 results were:

- Number of records identified from PubMed, NTRL, and TOXCENTER (after duplicate removal): 10,701
- Number of records identified from other strategies: 146
- Total number of records to undergo literature screening: 10,847

### B.1.2 Literature Screening

A two-step process was used to screen the literature search to identify relevant studies on nickel:

- Title and abstract screen
- Full text screen

Title and Abstract Screen. Within the reference library, titles and abstracts were screened manually for relevance. Studies that were considered relevant (see Table B-1 for inclusion criteria) were moved to the second step of the literature screening process. Studies were excluded when the title and abstract clearly indicated that the study was not relevant to the toxicological profile.

- Number of titles and abstracts screened: 10,847
- Number of studies considered relevant and moved to the next step: 256

Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the title and abstract screen step. Each study was reviewed to determine whether it was relevant for inclusion in the toxicological profile.

- Number of studies undergoing full text review: 256
- Number of studies cited in the pre-public draft of the toxicological profile: 1,002
- Total number of studies cited in the profile: 766

A summary of the results of the literature search and screening is presented in Figure B-1.

Figure B-1 October 2023 Literature Search Results and Screen for Nickel