# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. LOAELs for serious health effects (such as irreparable damage to the liver or kidneys, or serious birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substances than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Office of Innovation and Analytics, Toxicology Section, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Office of Innovation and Analytics, Toxicology Section, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S106-5, Atlanta, Georgia 30329-4027.

## Nickel Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Nickel
CAS Numbers: | 7440-02-0
Date: | October 2024
Profile Status: | Final
Route: | Inhalation
Duration: | Acute
MRL: | 1×10^−4^ mg Ni/m^3^
Critical Effect: | Bronchiole epithelial degeneration/hyperplasia
Reference: | Efremenko et al. 2017a, 2017b
Point of Departure: | LOAEL of 0.2244 mg Ni/m^3^ (LOAEL_HEC_ of 0.0403 mg Ni/m^3^)
Uncertainty Factor: | 300
LSE Graph Key: | 3
Species: | Rat

MRL Summary: An acute-duration inhalation MRL of 1×10^−4^ mg Ni/m^3^ was derived for nickel based on bronchiole epithelial degeneration/hyperplasia in male rats exposed to 0.2244 mg Ni/m^3^ as nickel sulfate hexahydrate 6 hours/day for 5 days (Efremenko et al. 2017a, 2017b). The MRL is based on a LOAEL of 0.2244 mg Ni/m^3^ adjusted to continuous duration exposure and converted to a human equivalent concentration (HEC) of 0.0403 mg Ni/m^3^ and divided by a total uncertainty factor of 300 (10 for the use of a LOAEL, 3 for extrapolation from animals to humans with dosimetric adjustment, and 10 for human variability).

Selection of the Critical Effect: Several case studies in workers who inhaled large amounts of nickel dust or fumes indicate that the respiratory system is the most sensitive endpoint for nickel toxicity (Bowman et al. 2018; Kunimasa et al. 2011). A single case of death from ARDS has been reported following a 90-minute exposure to a very high concentration (382 mg/m^3^) of metallic nickel of small particle size (<1.4 µm) (Rendall et al. 1994).

The acute inhalation toxicity of nickel sulfate, nickel subsulfide, nickel oxide, and nickel chloride has been evaluated in rats and/or mice. The available studies suggest that the respiratory tract and the immune system are the most sensitive targets of nickel toxicity; a summary of the NOAEL and LOAEL values for these endpoints is presented in Table A-1.

Table A-1 Summary of Relevant Acute-Duration Inhalation NOAEL and LOAEL Values^a^

Species (sex) | Frequency/duration | NOAEL (mg Ni/m^3^) | LOAEL (mg Ni/m^3^) | Effect | Reference (chemical form)
Respiratory
Rat (M) | 5 days; 6 hours/day | | 0.2244 | Bronchiole epithelial degeneration/hyperplasia | Efremenko et al. 2017a, 2017b (nickel sulfate hexahydrate)
Rat (M) | 5 days; 6 hours/day | | 0.44 | Peribronchiolar/perivascular inflammation and >250% increase of LDH in BALF | Efremenko et al. 2014 (nickel subsulfide)
Rat (B) | 12 days in 16-day period; 6 hours/day | | 0.44 | Chronic lung inflammation; olfactory epithelium atrophy | NTP 1996b (nickel subsulfide)
Rat (B) | 7 days; 6 hours/day | | 0.44 | Alveolitis | Benson et al. 1995b (nickel subsulfide)
Rat (B) | 12 days in 16-day period; 6 hours/day | | 0.7 (SLOAEL) | Labored breathing, chronic lung inflammation; olfactory epithelium atrophy | NTP 1996c (nickel sulfate hexahydrate)
Mouse (B) | 12 days in 16-day period; 6 hours/day | | 0.7 | Chronic lung inflammation; olfactory epithelium atrophy | NTP 1996c (nickel sulfate hexahydrate)
Mouse (B) | 12 days in 16-day period; 6 hours/day | 0.44 | 0.88 | Atrophy of olfactory epithelium | NTP 1996b (nickel subsulfide)
Rat (B) | 12 days in 16-day period; 6 hours/day | 3.9 | 7.9 | Lung inflammation | NTP 1996a (nickel oxide)
Mouse (B) | 12 days in 16-day period; 6 hours/day | 3.9 | 7.9 | Alveolar macrophage hyperplasia | NTP 1996a (nickel oxide)
Immunological
Mouse (F) | 24 hours | 0.08 | | Immunosuppressive effects | Buxton et al. 2021 (nickel chloride)
Mouse (F) | 2 hours | 0.1 | 0.25 | Impaired humoral immunity | Graham et al. 1978 (nickel chloride)
Mouse (F) | 2 hours | 0.37 | 0.5 | Increased susceptibility to Streptococcal infection | Adkins et al. 1979 (nickel chloride)
Mouse (B) | 12 days in 16-day period; 6 hours/day | 0.44 | 0.88 | Lymphoid hyperplasia in bronchial lymph nodes | NTP 1996b (nickel subsulfide)

a All concentrations are reported in mg Ni/m^3^; concentrations reported in terms of the nickel compound were converted by multiplying the concentration by a ratio of the nickel compound molecular weight to nickel molecular weight.

B = both males and females; BALF = bronchoalveolar lavage fluid; F = females; LDH = lactate dehydrogenase; LOAEL = lowest-observed-adverse-effect level; M = males; NOAEL = no-observed-adverse-effect level; SLOAEL = serious LOAEL

The respiratory tract effects observed in rats and/or mice include inflammation (peribronchiolar/perivascular inflammation, chronic lung inflammation, and alveolitis), bronchiole epithelial degeneration/hyperplasia, alveolar macrophage hyperplasia, labored breathing, and atrophy of the olfactory epithelium. Rats appear to be more sensitive than mice. In the available acute-duration database, the lower respiratory and nasal effects occur at similar concentrations. For a given effect, comparisons across studies reporting respiratory effects suggest differences in the toxicity of nickel compounds, which are likely due to differences in solubility and bioavailability. For example, the lowest LOAELs for lung inflammation in rats for the three nickel compounds tested by NTP were 0.44 mg Ni/m^3^ for nickel subsulfide (NTP 1996b), 0.7 mg Ni/m^3^ for nickel sulfate (NTP 1996c), and 7.9 mg Ni/m^3^ for nickel oxide (NTP 1996a). The 0.7 mg Ni/m^3^ concentration was considered a serious LOAEL for nickel sulfate because labored breathing was also observed at this concentration; labored breathing was not observed in the rats exposed to nickel subsulfide until concentrations of 3.65 mg Ni/m^3^. It is noted that a decrease in body weight of >20% was also observed in rats exposed to 0.7 mg Ni/m^3^ as nickel sulfate (NTP 1996c). Efremenko et al. (2017a, 2017b) did not report labored breathing in rats exposed to a lower nickel sulfate concentration (0.2244 mg Ni/m^3^). The lowest LOAEL for respiratory effects is 0.2244 mg Ni/m^3^ for bronchiole epithelial degeneration/hyperplasia identified in rats exposed to nickel sulfate hexahydrate 6 hours/day for 5 days (Efremenko et al. 2017a, 2017b).

Immunological effects observed in mice exposed to inhaled nickel include impaired immune function and lymphoid hyperplasia in bronchial lymph nodes. Immunological effects were observed at concentrations of ≥0.25 mg Ni/m^3^ as nickel chloride (Adkins et al. 1979; Graham et al. 1978).

The lowest LOAEL for immunological effects (0.25 mg Ni/m^3^) is similar to the LOAEL of 0.2244 mg Ni/m^3^ for respiratory effects; the lower respiratory tract was selected as the critical target because it has the lowest LOAEL and is well supported by other acute-duration inhalation studies with nickel sulfate and other nickel compounds.

Selection of the Principal Study: The Efremenko et al. (2017a, 2017b) study of nickel sulfate was selected as the principal study because it identified the lowest LOAEL of 0.2244 mg Ni/m^3^ for bronchiole epithelial degeneration/hyperplasia.

Summary of the Principal Study:

Efremenko AY, Campbell JL, Dodd DE, . 2017a. Time- and concentration-dependent genomic responses of the rat airway to inhaled nickel sulfate. Environ Mol Mutagen 58(8):607–618. 10.1002/em.22139. https://www.ncbi.nlm.nih.gov/pubmed/28862355.28862355

Efremenko AY, Campbell JL, Dodd DE, . 2017b. Supplemental material: Time- and concentration-dependent genomic responses of the rat airway to inhaled nickel sulfate. Environ Mol Mutagen 58(8):607–618. 10.1002/em.22139. https://www.ncbi.nlm.nih.gov/pubmed/28862355.28862355

Groups of five male Fischer 344 rats were whole-body exposed to analytical concentrations of 0.002 (control group), 0.128, 0.246, 0.496, or 1.020 mg/m^3^ nickel sulfate hexahydrate 6 hours/day for 5 days (0.0004, 0.0282, 0.0541, 0.109, and 0.2244 mg Ni/m^3^) (Efremenko et al. 2017a, 2017b). The particle size distributions (average mass median aerodynamic diameter, MMAD) and geometric standard deviations were 0.82 µm (1.41), 0.88 µm (1.36), 1.00 µm (1.40), and 1.09 µm (1.42) for the 0.0282, 0.0541, 0.109, and 0.2244 mg Ni/m^3^ groups, respectively. Animals were observed for overt clinical signs daily and body weight was measured at termination. At termination, groups of five animals in the control and 0.2244 mg Ni/m^3^ groups underwent BALF cytology and histopathology analysis (animals were sacrificed within 24 hours of exposure termination); groups of five animals in all concentration groups underwent BALF analysis. Additional groups of eight rats underwent gene expression analysis.

Significant increases in total protein and lactate dehydrogenase were observed in the BALF at 0.109 and 0.2244 mg Ni/m^3^; alkaline phosphatase levels were increased at all nickel concentrations. The toxicological significance of these findings is not known. Increases in lymphocytes and neutrophils were also increased in the BALF at 0.2244 mg Ni/m^3^. Lung histopathology was only evaluated in the 0 and 0.2244 mg Ni/m^3^ groups. An increase in bronchiole epithelial degeneration/hyperplasia was observed; the lesion was observed in five of five rats, as compared to zero of five controls, and the severity was graded as mild.

Selection of the Point of Departure for the MRL: The LOAEL of 0.2244 mg Ni/m^3^ as nickel sulfate for bronchiole epithelial degeneration/hyperplasia in rats (Efremenko et al. 2017a, 2017b) was selected as the basis of the acute-duration inhalation MRL for nickel.

Benchmark dose (BMD) modeling was not conducted because histopathological examinations were only conducted in controls and rats exposed to 0.2244 mg Ni/m^3^.

Adjustment for Intermittent Exposure: The LOAEL of 0.2244 mg Ni/m^3^ was adjusted to continuous exposure using the following equation:

B M C L_A D J_ = 0.2244 m g N i / m^3^ × (6 h o u r s)/(24 h o u r s) = 0.0561 m g N i / m^3^

Human Equivalent Concentration: A HEC was calculated using the following equation from Lee et al. (2019), adopted from NIOSH (2013):

L O A E L_H E C_ = L O A E L_A D J_ × (V R_R_)/(V R_H_) × (D F_R_)/(D F_H_) × ((1 − k_R_^n^)/(1 − k_R_))/((1 − k_H_^n^)/(1 − k_H_)) × (R H_R_)/(R H_H_) × (S A_H_)/(S A_R_)

Where VR= ventilation rate, DF = deposition fraction, k = 1-clearance rate, RH=particle retention half time, SA = alveolar surface area, n = exposure days, R = rat, and H = human.

For this equation, deposition fractions for rats and humans must be calculated. The regional deposited dose ratio (RDDR) for the thoracic region (combined tracheobronchial and pulmonary regions) is used to extrapolate deposited doses in rats to deposited doses in humans. The thoracic region was used since lesions were observed in bronchiolar and pulmonary tissues. The RDDR was calculated using the Multiple-Path Particle Dosimetry Model (MPPD, version 3.04) developed by Applied Research Associates, Inc. (ARA) to first calculate the deposition fraction (DF) for rats and humans. The MPPD model parameters and results for the rat and human deposition fractions are presented in Table A-2. For breathing frequency and tidal volume parameter values in humans, a time-weighted average (TWA) of default values in males (ICRP 1994) was calculated based on the following activity pattern over a 24-hour exposure period: 8 hours sleeping (nasal breathing) + 8 hours at rest/sitting (nasal breathing) + 8 hours of light activity (oronasal-mouth breather). Default values in males were selected to be health protective, as males are predicted to have higher deposition fractions than females.

Table A-2 MPPD Model (Version 3.04) Inputs and Results for Rat and Human Models

Parameters | Rats | Humans
Airway morphometry
Model | Asymmetric Multiple Path | Yem/Schum 5-Lobe
Functional residual capacity | 4 mL (default) | 3,300 mL (default)
Upper respiratory tract | 0.42 mL (default) | 50 mL (default)
Inhalant properties
Density^a^ | 2.07 g/cm^3^ | 2.07 g/cm3
Diameter, MMAD^b^ | 1.09 µm | 1.09 µm
GSD^b^ | 1.47 | 1.47
Inhalability adjustment | On | On
Exposure condition
Aerosol concentration (LOAEL_ADJ_) | 0.0561 mg Ni/m^3^ | 0.0561 mg Ni/m^3^
Breathing frequency | 102 breaths/minute (default) | 14.7 breaths/minute (calculated TWA)^c^
Tidal volume | 2.1 mL (default) | 875 mL (calculated TWA)^d^
Breathing scenario | Whole body | Nasal/oronasal breather^e^
Results
Thoracic region deposition fraction (total tracheobronchial and pulmonary deposition fraction) | 0.0846 | 0.1758

a Haynes et al. 2015, nickel sulfate.

b Efremenko et al. 2017a, 2017b.

c Breathing frequency is 12 breaths/minute at sleep/rest and 20 breaths/minute with light activity (ICRP 1994).

d Tidal volume is 625 mL at sleep, 750 mL at rest, and 1,250 mL with light activity (ICRP 1994).

e Breathing scenario is 8 hours of sleep (nasal breathing, on back), 8 hours at rest (nasal breathing, upright), and 8 hours light activity (oronasal-mouth breathing, upright).

GSD = geometric standard deviation; LOAEL_ADJ_ = lowest-observed-adverse-effect level adjusted for continuous exposure; MMAD = mass median aerodynamic diameter; MPPD = Multiple-Path Particle Dosimetry; TWA = time-weighted average

The deposition fractions calculated by the MPPD model and the daily ventilation rates were then used to calculate the LOAEL_HEC_. Table A-3 lists the values used within the equation and the source of these values. The exposure days (n) are 5 days to represent 24 hours of continuous exposure since the exposure concentration was adjusted from an intermittent to continuous exposure.

B M C L_H E C_ = 0.0561 m g N i / m^3^ × (0.20 (m^3^)/(d a y))/(20 (m^3^)/(d a y)) × (0.0846)/(0.1758) × ((1 − ( 1 − 0.289 d a y^− 1^ )^5^)/(1 − ( 1 − 0.289 d a y^− 1^ )))/((1 − ( 1 − 0.277 d a y^− 1^ )^5^)/(1 − ( 1 − 0.277 d a y^− 1^ ))) × (1)/(1.04) × (54 m^2^)/(0.34 m^2^)

L O A E L_H E C_ = 0.0403 m g N i / m^3^

Table A-3 Values Used to Calculate a Human Equivalent Concentration (HEC)

Variable | Rat value (R) | Human value (H) | Source
Ventilation rate (VR) | 0.20 m^3^/day | 20 m^3^/day | EPA 1994
Deposition fraction (DF) | 0.0846 | 0.1758 | Calculated using MPPD software
Clearance rate^a^ (k) | 0.289 day^−1^ | 0.277 day^−1^ | Oller et al. 2014
Retention half-time | 2.4 days | 2.5 days | Oller et al. 2014
Ratio of retention half-time (RH) (to rat half-time) | 1 | 1.04 | Calculated
Thoracic surface area (SA) | 0.342 m^2^ | 54.32 m^2^ | EPA 1994
Exposure days (n) | 5 days | 5 days | Efremenko et al. 2017a, 2017b

a Total clearance rate = ln2/retention half-time.

HEC = human equivalent concentration; MPPD = Multiple Path Particle Dosimetry

Uncertainty Factor: The LOAEL_HEC_ is divided by a total uncertainty factor of 300:

- 10 for the use of a LOAEL,
- 3 for extrapolation from rats to humans with dosimetric adjustments,
- 10 for human variability

Provisional MRL = (L O A E L_H E C_)/(U F s) = (0.0403 m g N i / m^3^)/(300) = 1.34 × 10^− 4^ m g N i / m^3^ ; r o u n d e d t o 1 × 10^− 4^ m g N i / m^3^

Other Additional Studies or Pertinent Information that Lend Support to this MRL: The respiratory tract is a well-established target of toxicity following inhalation exposure to soluble and insoluble nickel compounds. Studies of workers exposed to nickel have reported increased respiratory symptoms, impaired lung function, and lung disease (Berge and Skyberg 2003; Fishwick et al. 2004; Kilburn et al. 1990; Syurin and Vinnikov 2022; Wu et al. 2022). Pulmonary effects have been reported in several acute-duration studies in animals exposed to nickel sulfate, nickel subsulfide, or nickel oxide (Benson et al. 1995b; Efremenko et al. 2014, 2017a, 2017b; NTP 1996a, 1996b, 1996c).

Agency Contact (Chemical Managers): Custodio Muianga, Ph.D., M.P.H.

## Nickel Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Nickel
CAS Numbers: | 7440-02-0
Date: | October 2024
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate
MRL: | 3×10^−6^ mg Ni/m^3^
Critical Effect: | Alveolitis and perivascular/peribronchiolar inflammation
Reference: | Oller et al. 2023
Point of Departure: | BMDL of 0.0014 mg Ni/m^3^ (BMDL_HEC_ of 0.0000982 mg Ni/m^3^)
Uncertainty Factor: | 30
LSE Graph Key: | 28
Species: | Rat

MRL Summary: An intermediate-duration inhalation MRL of 3×10^−6^ mg Ni/m^3^ was derived for nickel based on alveolitis and perivascular/peribronchiolar inflammation observed in the lungs of rats exposed to ≥0.04 mg Ni/m^3^ as nickel subsulfide for 6 hours/day, 5 days/week for 90 days (Oller et al. 2023). The MRL is based on a benchmark dose lower confidence limit (BMCL) of 0.0014 mg Ni/m^3^ adjusted to continuous duration exposure and converted to a human equivalent concentration (HEC) of 0.0000982 mg Ni/m^3^ (9.82×10^−5^ mg Ni/m^3^) and divided by a total uncertainty factor of 30 (3 for extrapolation from rats to humans with dosimetric adjustments and 10 for human variability).

Selection of the Critical Effect: The intermediate-duration toxicity of nickel has been assessed in several animal studies involving exposure to metallic nickel, nickel sulfate, nickel sulfate hexahydrate, nickel chloride, nickel subsulfide, and nickel oxide. The available data suggest that the lower respiratory tract is the most sensitive target of toxicity following intermediate-duration inhalation exposure, with effects occurring at nickel concentrations of ≥0.04 mg Ni/m^3^. A summary of the NOAEL and LOAEL values for respiratory effects is presented in Table A-4. The respiratory effects include inflammatory changes in the lungs, alveolar macrophage hyperplasia, and atrophy of the nasal olfactory epithelium. Immune effects also occur at relatively low nickel concentrations (see Table A-2); the effects include lymphoid hyperplasia in the bronchial and mediastinal lymph nodes and altered impaired immune function. Other observed effects included developmental effects (decreased fetal body weight) (Weischer et al. 1980) at 1.6 mg Ni/m^3^ as nickel oxide and changes in hematological parameters (NTP 1996b; Weischer et al. 1980), which have been reported at nickel concentrations associated with lung inflammation.

Table A-4 Summary of Relevant Intermediate-Duration Inhalation NOAEL and LOAEL Values^a^

Species (sex) | Frequency/duration | NOAEL (mg Ni/m^3^) | LOAEL (mg Ni/m^3^) | Effect | Reference; (chemical form)
Respiratory
Rat (M) | 13 weeks; 5 days/week; 6 hours/day | | 0.04 | Alveolitis and perivascular/peribronchiolar inflammation and protein accumulation | Oller et al. 2023; (nickel subsulfide)
Rat (M) | 4 weeks; 5 days/week; 6 hours/day | 0.06 | 0.11 | Lung inflammation | Efremenko et al. 2014; (nickel subsulfide)
Rat (M) | 4 weeks; 5 days/week; 6 hours/day | 0.05412 | 0.1104 | Alveolus inflammation | Efremenko et al. 2017a, 2017b; (nickel sulfate)
Rat (M) | 2–6 months; 5 days/week; 6 hours/day | 0.03 | 0.11 | Alveolitis | Benson et al. 1995a; (nickel sulfate)
Rat (B) | 13 weeks; 5 days/week; 6 hours/day | 0.06 | 0.11 | Chronic active lung inflammation and interstitial infiltrates | NTP 1996c; (nickel sulfate)
Rat (M) | 13 weeks; 5 days/week; 6 hours/day | 0.03 | 0.11 | Alveolitis and perivascular/peribronchiolar inflammation | Oller et al. 2023; (nickel sulfate)
Rat (B) | 13 weeks; 5 days/week; 6 hours/day | 0.11 | 0.22 | Chronic active lung inflammation | NTP 1996b; (nickel subsulfide)
Rat (M) | 3 weeks; 5 days/week; 6 hours/day | 0.11 | 0.22 | Alveolitis, perivascular inflammation, bronchiolar epithelial degeneration | Oller et al. 2023; (nickel sulfate)
Mouse (M) | 2–6 months; 5 days/week; 6 hours/day | 0.06 | 0.22 | Interstitial pneumonia | Benson et al. 1995a; (nickel sulfate)
Rat (B) | 13weeks; 5 days/week; 6 hours/day | 0.11 | 0.22 | Olfactory epithelial atrophy | NTP 1996c; (nickel sulfate)
Rat (B) | 22 days; 6 hours/day | | 0.44 | Alveolitis, alveolar proteinosis; olfactory epithelium degeneration | Benson et al. 1995b; (nickel subsulfide)
Rat (B) | 13 weeks; 5 days/week; 6 hours/day | 0.22 | 0.44 | Olfactory epithelial atrophy | NTP 1996b; (nickel subsulfide)
Mouse (B) | 13 weeks; 5 days/week; 6 hours/day | 0.22 | 0.44 | Olfactory epithelial atrophy | NTP 1996a; (nickel subsulfide)
Mouse (B) | 13 weeks; 5 days/week; 6 hours/day | 0.22 | 0.44 | Chronic lung inflammation, fibrosis, and interstitial infiltrates | NTP 1996a; (nickel sulfate)
Rat (M) | 4 weeks; 5 days/week; 6 hours/day | | 0.5 | Bronchial gland hyperplasia and squamous metaplasia | Horie et al. 1985; (nickel oxide)
Rabbit (M) | 4 months; 5 days/week; 6 hours/day | | 0.6 | Interstitial inflammation and intraalveolar accumulation of macrophages | Johansson et al. 1988a, 1989; (nickel chloride)
Rat (M) | 16 days; 6 hours/day | | 0.64 | Olfactory epithelial atrophy | Evans et al. 1995; (nickel sulfate)
Mouse (M) | 2–6 months; 5 days/week; 6 hours/day | | 0.98 | Interstitial pneumonia | Benson et al. 1995a; (nickel oxide)
Rat (M) | 2–6 months; 5 days/week; 6 hours/day | 0.49 | 1.96 | Moderate alveolitis | Benson et al. 1995a; (nickel oxide)
Rat (B) | 13 weeks; 5 days/week; 6 hours/day | 2 | 3.9 | Chronic active lung inflammation, granulomatous inflammation, and lung interstitial infiltrate | NTP 1996a; (nickel oxide)
Mouse (B) | 13 weeks; 5 days/week; 6 hours/day | 2 F; 3.9 M | 3.9 F; 7.6 M | Perivascular lymphocytic infiltrates | NTP 1996a; (nickel oxide)
Immunological
Rat (M) | 4 months continuous | 0.025 | 0.145 | Impaired response to sRBC exposure | Spiegelberg et al. 1984; (nickel oxide)
Rat (M) | 4 weeks continuous | 0.093 | 0.216 | Impaired response to sRBC exposure | Spiegelberg et al. 1984; (nickel oxide)
Rat (B) | 13 weeks; 5 days/week; 6 hours/day | 0.11 | 0.22 | Lymphoid hyperplasia in bronchial and mediastinal lymph nodes | NTP 1996c; (nickel sulfate)
Rat (B) | 13 weeks; 5 days/week; 6 hours/day | 0.22 | 0.44 | Lymphoid hyperplasia in bronchial and mediastinal lymph nodes | NTP 1996b; (nickel subsulfide)
Mouse (B) | 13 weeks; 5 days/week; 6 hours/day | 0.22 | 0.44 | Bronchial lymph node hyperplasia | NTP 1996a; (nickel sulfate)
Mouse (F) | 65 days; 5 days/week; 6 hours/day | | 0.45 | Decreased resistance to tumor challenge | Haley et al. 1990; (nickel sulfate)
Mouse (F) | 65 days; 5 days/week; 6 hours/day | | 0.45 | Decreased alveolar macrophage activity | Haley et al. 1990; (nickel subsulfide)
Mouse (F) | 65 days; 5 days/week; 6 hours/day | | 0.47 | Decreased alveolar macrophage activity | Haley et al. 1990; (nickel oxide)
Mouse (B) | 13 weeks; 5 days/week; 6 hours/day | 0.44 F; 0.88 M | 0.88 F; 1.83 M | Bronchial lymph node hyperplasia | NTP 1996a; (nickel subsulfide)
Rat (B) | 13 weeks; 5 days/week; 6 hours/day | 2 | 3.9 | Lymphoid hyperplasia in mediastinal lymph nodes | NTP 1996a; (nickel oxide)
Mouse (B) | 13 weeks; 5 days/week; 6 hours/day | 3.9 | 7.9 | Bronchial lymph node hyperplasia | NTP 1996a; (nickel oxide)
Rat (M) | 4 weeks; 5 days/week; 8 hours/day | | 9.2 | Increased production of tumor necrosis factor by alveolar macrophages | Morimoto et al. 1995; (nickel oxide)

a All concentrations are reported in mg Ni/m^3^; concentrations reported in terms of the nickel compound were converted by multiplying the concentration by a ratio of the nickel compound molecular weight to nickel molecular weight.

B = both males and females; F = females; LDH = lactate dehydrogenase; LOAEL = lowest-observed-adverse-effect level; M = males; NOAEL = no-observed-adverse-effect level; sRBC = sheep red blood cell

Studies conducted by NTP (1996a, 1996b, 1996c), Oller et al. (2023), and Benson et al. (1995a, 1995b) allow for comparisons across nickel compounds and animal species. Of the three nickel compounds tested in these studies, nickel oxide was the least toxic (Benson et al. 1995a, 1995b; NTP 1996a, 1996b, 1996c). Although the results of the NTP (1996b, 1996c) and Benson et al. (1995a, 1995b) studies suggest that lung toxicity of nickel sulfate is greater than nickel subsulfide, the Oller et al. (2023) study identified a lower LOAEL for lung effects associated with nickel subsulfide than with nickel sulfate. The NTP (1996a, 1996b, 1996c) and Benson et al. (1995a, 1995b) studies also provide suggestive evidence that rats are more sensitive than mice.

Selection of the Principal Study: The Oller et al. (2023) study of nickel subsulfide was selected as the principal study because it identified the lowest LOAEL of 0.04 mg Ni/m^3^ for lung effects (alveolitis, perivascular/peribronchiolar inflammation, and protein accumulation).

Summary of the Principal Study:

Oller AR, Buxton S, March TH, . 2023. Comparative pulmonary and genotoxic responses to inhaled nickel subsulfide and nickel sulfate in F344 rats. J Appl Toxicol 43(5):734–751. 10.1002/jat.4422.36482046

Groups of 13 male F344 rats were whole-body exposed to 0, 0.05, 0.15, or 0.6 mg/m^3^ nickel subsulfide (0, 0.04, 0.11, or 0.44 mg Ni/m^3^) 6 hours/day, 5 days/week for 13 weeks. Additional groups of animals (13/group) were exposed to 0 or 0.22 mg Ni/m^3^ for 13 weeks followed by a 13-week observation period. Actual concentrations were 0.02, 0.06, 0.15, and 0.59 mg/m^3^ nickel subsulfide (0.01, 0.04, 0.11, and 0.44 mg Ni/m^3^); the particle sizes (MMAD) were 1.90 µm (geometric standard deviation [GSD] of 2.28) and 1.89 µm (2.38) for the 0.11 and 0.44 Ni/m^3^ concentrations, respectively; particle size was not determined at the control or 0.04 mg Ni/m^3^ concentrations. The following parameters were used to assess toxicity: clinical signs, body weight, histopathology of the lung and lung weights (n=8/group), and evaluation of bronchoalveolar lavage fluid (BALF) (n=5/group).

No clinical signs of toxicity or alterations in terminal body weights were observed. Concentration-related increased absolute lung weights were observed at ≥0.04 mg Ni/m^3^ (24, 48, and 86% at 0.04, 0.11, and 0.44 mg Ni/m^3^, respectively). Histological alterations in the lungs consisted of alveolitis, protein accumulation, and perivascular/peribronchiolar inflammation at ≥0.04 mg Ni/m^3^. The incidences of these lesions are presented in Table A-5. Type II cell hyperplasia was also observed at 0.44 mg Ni/m^3^. Alveolar septal infiltrates, histiocytosis, and type II epithelial cell hyperplasia were observed in the 0.44 mg Ni/m^3^ recovery group. BALF alterations consisted of increased LDH at 0.11 mg Ni/m^3^ and increased total protein, beta-glucuronidase, RBC phagocytosis, and total nucleated cell levels at 0.22 mg Ni/m^3^. No BALF alterations were observed in the recovery group.

Table A-5 Incidence of Select Lung Lesions in Rats Exposed to Nickel Subsulfide for 13 Weeks via Inhalation

Concentration (mg Ni/m^3^) | Alveolitis | Perivascular/peribronchiolar inflammation | Protein accumulation
0.01 (control group) | 1/8 (0.1)^a^ | 2/8 (0.3)^a^ | 0/8
0.04 | 7/8^b^ (1.1) | 7/8^b^ (0.9) | 8/8^b^ (2.0)
0.11 | 7/8^b^ (1.6) | 8/8^b^ (1.8) | 8/8^b^ (3.1)
0.44 | 8/8^b^ (2.1) | 8/8^b^ (2.3) | 8/8^b^ (3.5)

a Average severity of lesion: 1 = minimal; 2 = mild; 3 = moderate; 4 = marked.

b Statistically different from control group, p<0.05 (Fischer Exact test conducted by ATSDR).

Source: Oller et al. 2023

Selection of the Point of Departure for the MRL: The BMCL_10_ of 0.0014 mg Ni/m^3^ for perivascular/peribronchiolar inflammation in rats (Oller et al. 2023) was selected as the basis of the intermediate-duration inhalation MRL for nickel.

Incidence data for alveolitis and perivascular/peribronchiolar inflammation (Table A-5) were fit to all dichotomous models in EPA’s Benchmark Dose Software (BMDS) (version 3.3.2) using a benchmark response (BMR) of 10% extra risk. Adequate model fit was judged by four criteria: chi-square goodness-of-fit p-value (p≥0.1), visual inspection of the dose-response curve, BMDL <10 times the lowest non-zero dose, and scaled residual (>-2 and <+2) at the data point (except the control) closest to the predefined BMR. The incidence data for protein accumulation was not modeled due to the 100% incidence at all non-control nickel concentrations.

Although several models of the alveolitis incidence data met three of the model fit criteria, the models failed the visual inspection of the dose-response curve. Most of the models of the perivascular/peribronchiolar inflammation incidence data provided adequate fit; the results are presented in Table A-6. The Multistage Degree 1 and Quantal Linear identified the lowest Akaike Information Criterion (AIC) and were selected; both models estimated a benchmark concentration (BMC) of 0.0024 mg Ni/m^3^ and a BMCL of 0.0014 mg Ni/m^3^. The model fit for the Multistage 1 Degree model is presented in Figure A-1.

Table A-6 Results of BMD Analysis of Perivascular/Peribronchiolar Inflammation Incidence Data in Male F344 rats Exposed to Nickel Subsulfide via Inhalation 6 Hours/Day, 5 Days/Week for 13 Weeks (Oller et al. 2023)

Model | BMC_10_^a^ | BMCL_10_^a^ | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMC_10_^a^ | BMCL_10_^a^ | p-Value^b^ | AIC | Dose group near BMC | Control dose group
Dichotomous Hill | 0.0230 | 0.0020 | 0.9734 | 21.03 | −7.1×10^−5^ | −7.1×10^−5^
Gamma^d^ | 0.0162 | 0.0015 | 0.9966 | 21.03 | 6.19×10^−6^ | 6.19×10^−6^
Log-Logistic^e^ | 0.0230 | 0.0020 | 0.9734 | 21.03 | −7.1×10^−5^ | −7.1×10^−5^
Multistage Degree 3^f^ | | | NA | 23.03 | −6.1×10^−9^ | −6.1×10^−9^
Multistage Degree 2^f^ | 0.0094 | 0.0015 | 1.0000 | 19.03 | 5.11×10^−6^ | 5.11×10^−6^
Multistage Degree 1 ^f^ ^,^ ^g^ | 0.0024 | 0.0014 | 0.9006 | 17.70 | −0.63669 | −0.63669
Weibull^d^ | 0.0067 | 0.0015 | 0.9890 | 21.03 | 9.36×10^−5^ | 9.36×10^−5^
Logistic | 0.0070 | 0.0035 | 0.9995 | 19.03 | 0.001763 | 0.001763
Log-Probit | 0.0259 | 0.0018 | 1.0000 | 21.03 | 6.04×10^−9^ | −2.9×10^−8^
Probit | 0.0062 | 0.0037 | 0.7546 | 19.64 | −0.50568 | −0.50568
Quantal Linear ^g^ | 0.0024 | 0.0014 | 0.9006 | 17.70 | −0.63669 | −0.63669

a BMC and BMCLs not providing adequate fit are not included in this table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses near the BMC and for the control dose group.

d Power restricted to ≥1.

e Slope restricted to ≥1.

f Betas restricted to ≥0.

g Recommended model. Of the models providing adequate fit, the BMDLs were sufficiently close (differed by <3-fold); therefore, the models with the lowest AIC were selected (Multistage Degree 1 and Quantal Linear models).

AIC = Akaike Information Criterion; BMC = benchmark concentration (maximum likelihood estimate of the concentration associated with the selected benchmark response); BMCL_10_ = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., 10 = dose associated with 10% extra risk); NA = not applicable

Figure A-1 Predicted (Frequentist Multistage 1 Degree Model) and Observed Incidence of Perivascular/Peribronchiolar Inflammation in Male Rats Exposed to Nickel Subsulfide

Two potential PODs were considered for MRL derivation: BMCL_10_ of 0.0014 mg Ni/m^3^ for perivascular/peribronchiolar inflammation and a LOAEL of 0.04 mg Ni/m^3^ for alveolitis and protein accumulation in the lung. The BMCL_10_ of 0.0014 mg Ni/m^3^ was selected as the POD for the MRL because it results in the most-health protective MRL.

Adjustment for Intermittent Exposure: The BMCL_10_ of 0.0014 mg Ni/m^3^ was adjusted from intermittent exposure to continuous exposure using the following equation:

B M C L_A D J_ = 0.0014 m g N i / m^3^ × (6 h o u r s)/(24 h o u r s) × (5 d a y s)/(7 d a y s) = 0.0025 m g N i / m^3^

Human Equivalent Concentration: A HEC was calculated using the following equation from Lee et al. (2019), adopted from NIOSH (2013):

B M C L_H E C_ = B M C L_A D J_ × (V R_R_)/(V R_H_) × (D F_R_)/(D F_H_) × ((1 − k_R_^n^)/(1 − k_R_))/((1 − k_H_^n^)/(1 − k_H_)) × (R H_R_)/(R H_H_) × (S A_H_)/(S A_R_)

Where VR= ventilation rate, DF = deposition fraction, k = 1-clearance rate, RH=particle retention half time, SA = alveolar surface area, n = exposure days, R = rat, and H = human.

For this equation, deposition fractions for rats and humans must be calculated. The RDDR for the thoracic region (combined tracheobronchial and pulmonary regions) is used to extrapolate deposited doses in rats to deposited doses in humans. The RDDR was calculated using ARA MPDD Model (version 3.04) to first calculate the deposition fraction (DF) for rats and humans. The MPPD model parameters and results for the rat and human deposition fractions are presented in Table A-7. For breathing frequency and tidal volume parameter values in humans, a TWA of default values in males (ICRP 1994) was calculated based on the following activity pattern over a 24-hour exposure period: 8 hours sleeping (nasal breathing) + 8 hours at rest/sitting (nasal breathing) + 8 hours of light activity (oronasal-mouth breather). Default values in males were selected to be health protective, as males are predicted to have higher deposition fractions than females.

Table A-7 MPPD Model (Version 3.04) Inputs and Results for Rat and Human Models

Parameters | Rats | Humans
Airway morphometry
Model | Asymmetric Multiple Path | Yem/Schum 5-Lobe
Functional residual capacity | 4 mL (default) | 3,300 mL (default)
Upper respiratory tract | 0.42 mL (default) | 50 mL (default)
Inhalant properties
Density^a^ | 5.87 g/cm^3^ | 5.87 g/cm^3^
Diameter, MMAD^b^ | 1.90 µm | 1.90 µm
GSD^b^ | 2.28 | 2.28
Inhalability adjustment | On | On
Exposure condition
Aerosol concentration (BMCL_ADJ_) | 0.00025 mg Ni/m^3^ | 0.00025 mg Ni/m^3^
Breathing frequency | 102 breaths/minute (default) | 14.7 breaths/minute (calculated TWA)^c^
Tidal volume | 2.1 mL (default) | 875 mL (calculated TWA)^d^
Breathing scenario | Whole body | Nasal/oronasal breather^e^
Results
Thoracic region deposition fraction (total tracheobronchial and pulmonary deposition fraction) | 0.0610 | 0.2273 (TWA)^f^

a Haynes et al. (2015), nickel subsulfide.

b Oller et al. (2023).

c Breathing frequency is 12 breaths/minute at sleep/rest and 20 breaths/minute with light activity (ICRP 1994).

d Tidal volume is 625 mL at sleep, 750 mL at rest, and 1,250 mL with light activity (ICRP 1994).

e Breathing scenario is 8 hours of sleep (nasal breathing, on back), 8 hours at rest (nasal breathing, upright), and 8 hours light activity (oronasal-mouth breathing, upright).

f TWA = deposition fraction at sleep + rest + light activity/3 = (0.2131 + 0.2122 + 0.2567)/3 = 0.2273.

BMCL_ADJ_ = lower 95% confidence interval of the benchmark concentration adjusted for continuous exposure; GSD = geometric standard deviation; MMAD = mass median aerodynamic diameter; MPPD = Multiple-Path Particle Dosimetry; TWA = time-weighted average

The deposition fractions calculated by the MPPD model and the daily ventilation rates were then used to calculate the BMCL_HEC_. Table A-8 lists the values used within the equation and the source of these values. The exposure days (n) are 91 days to represent 24 hours of continuous exposure since the exposure concentration was adjusted from an intermittent to continuous exposure. Clearance data are not available for nickel subsulfide but are available for nickel oxide and nickel sulfate (Oller et al. 2014). Although nickel subsulfide and nickel oxide are both less soluble compounds, pulmonary clearance data for these three nickel compounds suggest that nickel subsulfide toxicokinetic properties may be more similar to nickel sulfate than nickel oxide. As reviewed by NTP (1996b), pulmonary clearance half-times in rats following intratracheal administration were 5 days for nickel subsulfide, 120 days for nickel oxide, and 1–3 days for nickel sulfate. Nickel subsulfide and nickel sulfate were distributed to extrarespiratory tissues, whereas nickel oxide was not distributed to extrarespiratory tissues. Using the clearance rates for nickel sulfate over those for nickel oxide is supported by the lung burden data from the NTP studies. The lung burdens in male rats exposed to approximately 0.4 mg Ni/m^3^ for 13 weeks (6 hours/day, 5 days/week) were 7 µg Ni/g lung for nickel subsulfide (NTP 1996b), 3.348 µg Ni/g lung for nickel sulfate (NTP 1996c), and 80 µg Ni/g lung for nickel oxide (NTP 1996a). ICRP (1994) assigned nickel sulfate and nickel subsulfide to the same dissolution/absorption class F (fast, absorption half-time <10 days) based on a review of literature on retention kinetics of inhaled nickel sulfate and nickel subsulfide in cynomolgus monkeys and rats.

B M C L_H E C_ = 0.0025 m g / m^3^ × (0.20 (m^3^)/(d a y))/(20 (m^3^)/(d a y)) × (0.0610)/(0.2273) × ((1 − ( 1 − 0.289 d a y^− 1^ )^91^)/(1 − ( 1 − 0.289 d a y^− 1^ )))/((1 − ( 1 − 0.277 d a y^− 1^ )^91^)/(1 − ( 1 − 0.277 d a y^− 1^ ))) × (1)/(1.04) × (54 m^2^)/(0.34 m^2^)

B M C L_H E C_ = 0.0000982 m g / m^3^

Table A-8 Values Used to Calculate a Human Equivalent Concentration (HEC) for Nickel

Variable | Rat value (R) | Human value (H) | Source
Ventilation rate (VR) | 0.20 m^3^/day | 20 m^3^/day | EPA 1994
Deposition fraction (DF) | 0.0456 | 0.2273 | Calculated using MPPD software
Clearance rate^a^ (k) | 0.289 day^−1^ | 0.277 day^−1^ | Oller et al. 2014
Ratio of retention half-time (RH) (to rat half-time) | 1 | 1.04 | Calculated
Alveolar surface area (SA) | 0.34 m^2^ | 54 m^2^ | EPA 1994
Exposure days (n) | 91 days | 91 days | Oller et al. 2023

a Total clearance rate = ln2/retention half-time.

HEC = human equivalent concentration; MPPD = Multiple Path Particle Dosimetry

Uncertainty Factor: The BMCL_HEC_ is divided by a total uncertainty factor of 30:

- 3 for extrapolation from rats to humans with dosimetric adjustments
- 10 for human variability

M R L = (B M C L_H E C_)/(U F s) = (0.0000982 m g N i / m^3^)/(30) = 3.3 × 10^− 6^ m g N i / m^3^ , r o u n d e d t o 3 × 10^− 6^ m g N i / m^3^

Other Additional Studies or Pertinent Information that Lend Support to this MRL: The respiratory tract is a well-established target of toxicity following inhalation exposure to soluble and insoluble nickel compounds. Studies of workers exposed to nickel have reported increased respiratory symptoms, impaired lung function, and lung disease (Berge and Skyberg 2003; Fishwick et al. 2004; Kilburn et al. 1990; Syurin and Vinnikov 2022; Wu et al. 2022). Lung inflammation has been reported in a number of intermediate-duration studies in animals exposed to nickel subsulfide, nickel sulfate, nickel chloride, or nickel oxide (Benson et al. 1995a, 1995b; Efremenko et al. 2014, 2017a, 2017b; Johansson et al. 1988a; NTP 1996a, 1996b, 1996c; Oller et al. 2023). Olfactory epithelial atrophy has also been observed in rats and mice exposed to nickel sulfate or nickel subsulfide (NTP 1996b, 1996c).

Agency Contact (Chemical Managers): Custodio Muianga, Ph.D., M.P.H.

## Nickel Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Nickel
CAS Numbers: | 7440-02-0
Date: | October 2024
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: A chronic-duration inhalation MRL was not derived for nickel. Although several chronic-duration inhalation studies are available, an MRL based on the study with the lowest LOAEL resulted in an MRL that was higher than the intermediate-duration inhalation MRL.

Rationale for Not Deriving an MRL: Numerous studies in workers have examined respiratory tract toxicity following chronic-duration exposure to nickel. Several studies of workers such as welders and nickel refinery workers have reported respiratory effects, which include reduced vital capacity, respiratory symptoms, chronic bronchitis, pulmonary fibrosis, and asthma (Berge and Skyberg 2003; Fishwick et al. 2004; Kilburn et al. 1990; Syurin and Vinnikov 2022; Wu et al. 2022).

Several animal studies (NTP 1996a, 1996b, 1996c; Oller et al. 2008; Ottolenghi et al. 1975; Takenaka et al. 1985; Tanaka et al. 1988) assessed the toxicity of nickel sulfate, nickel chloride, nickel subsulfide, nickel oxide, and metallic nickel. The respiratory system is a sensitive target of chronic-duration exposure with LOAELs ranging from 0.06 to 1.0 mg Ni/m^3^. Respiratory effects observed include inflammatory changes in the lungs (NTP 1996a, 1996b, 1996c; Oller et al. 2008; Ottolenghi et al. 1975; Tanaka et al. 1988), atrophy of the nasal olfactory epithelium (NTP 1996b, 1996c), congestion, and increased lung weight (Takenaka et al. 1985). A summary of the NOAEL and LOAEL values for respiratory effects is presented in Table A-9. Rats exposed to ≥0.06–0.2 mg Ni/m^3^ as nickel oxide had decreased survival time compared to controls (Takenaka et al. 1985). Other noncancerous health effects due to nickel exposure include evidence of changes in hematological parameters (increased hemoglobin, hematocrit, and erythrocytes) at ≥0.1 mg Ni/m^3^ (NTP 1996b; Oller et al. 2008), lymphoid hyperplasia in bronchial lymph nodes at ≥0.1 mg Ni/m^3^ (NTP 1996a, 1996b, 1996c; Oller et al. 2008), and decreased body weight gain at ≥0.1 mg Ni/m^3^ (NTP 1996b, 1996c). The hematological and body weight effects were likely secondary to the lung damage. The available chronic-duration inhalation database provides strong support for identifying the respiratory tract, in particular the lungs, as the critical effect for deriving an MRL.

Table A-9 Summary of Relevant Chronic-Duration Inhalation NOAEL and LOAEL Values for Respiratory Effects in Animals Exposed to Nickel^a^

Species (sex) | Frequency/duration | NOAEL (mg Ni/m^3^) | LOAEL (mg Ni/m^3^) | Effect | Reference; (chemical form)
Respiratory
Rat (B) | 2 years; 5 days/week; 6 hours/day | 0.03 | 0.06 | Chronic lung inflammation, fibrosis, alveolar proteinosis | NTP 1996c; (nickel sulfate)
Mouse (F) | 2 years; 5 days/week; 6 hours/day | | 0.06 | Chronic lung inflammation and bronchiolization | NTP 1996c; (nickel sulfate)
Rat (M) | 31 months; 7 days/week; 23 hours/day | | 0.06 | Increased lung weight, congestion, alveolar proteinosis | Takenaka et al. 1985; (nickel oxide)
Rat (B) | 2 years; 5 days/week; 6 hours/day | | 0.1 (SLOAEL) | Labored breathing, alveolar proteinosis, histiocytosis, chronic lung inflammation, bronchiolar alveolar hyperplasia (females) | Oller et al. 2008; (metallic nickel)
Rat (B) | 2 years; 5 days/week; 6 hours/day | | 0.11 (SLOAEL) | Rapid shallow breathing, chronic lung inflammation, lung fibrosis | NTP 1996b; (nickel subsulfide)
Mouse (M) | 2 years; 5 days/week; 6 hours/day | 0.06 | 0.11 | Chronic lung inflammation and bronchiolization | NTP 1996c; (nickel sulfate)
Mouse (M) | 2 years; 5 days/week; 6 hours/day | 0.06 | 0.11 | Atrophy of olfactory epithelium | NTP 1996c; (nickel sulfate)
Rat (B) | 2 years; 5 days/week; 6 hours/day | 0.06 | 0.11 | Atrophy of olfactory epithelium | NTP 1996c; (nickel sulfate)
Rat | 12 months; 5 days/week; 7 hours/day | | 0.235 (SLOAEL) | Pneumonia, increased lung weight | Tanaka et al. 1988; (nickel oxide)
Mouse (B) | 2 years; 5 days/week; 6 hours/day | | 0.44 | Chronic lung inflammation and bronchiolization, alveolar proteinosis, fibrosis; Atrophy of olfactory epithelium | NTP 1996b; (nickel subsulfide)
Rat (B) | 2 years; 5 days/week; 6 hours/day | | 0.5 | Chronic lung inflammation and lung alveolus pigmentation | NTP 1996a; (nickel oxide)
Rat (B) | 78–80 weeks; 5 days/week; 6 hours/day | | 0.63 (SLOAEL) | Pneumonitis, bronchitis, emphysema, hyperplasia | Ottolenghi et al. 1975; (nickel sulfide)
Rat (B) | 2 years; 5 days/week; 6 hours/day | 0.11 | 0.73 | Atrophy of olfactory epithelium | NTP 1996b; (nickel subsulfide)
Mouse (B) | 2 years; 5 days/week; 6 hours/day | | 1.0 | Chronic lung inflammation, bronchiolization, and alveolar proteinosis | NTP 1996a; (nickel oxide)

a All concentrations are reported in mg Ni/m^3^; concentrations reported in terms of the nickel compound were converted by multiplying the concentration by a ratio of the nickel compound molecular weight to nickel molecular weight.

B = both males and females; F = females; LOAEL = lowest-observed-adverse-effect level; M = males; NOAEL = no-observed-adverse-effect level; SLOAEL = serious LOAEL

The NTP (1996c) rat and mouse studies and the Takenaka et al. (1985) rat study identified the lowest LOAEL value (0.06 mg Ni/m^3^) for lung effects. The NTP (1996c) rat study was selected as the principal study over the other two studies. The rat study was selected over the mouse study since it identified a NOAEL; the available data suggest that the rat is more sensitive than the mouse; thus, derivation of an MRL based on the rat NOAEL should be protective. The NTP (1996c) study was selected over the Takenaka et al. (1985) study because the latter study is poorly reported and the LOAEL_ADJ_ (0.057 mg Ni/m^3^) is higher than the LOAEL_ADJ_ for the NTP (1996c) study (0.011 mg Ni/m^3^).

Incidence data for chronic active inflammation and lung fibrosis (presented in Table A-10) were fit to all dichotomous models in EPA’s BMDS (version 3.3.2) using a BMR of 10% extra risk. Adequate model fit was judged by four criteria: chi-square goodness-of-fit p-value (p≥0.1), visual inspection of the dose-response curve, BMCL <10 times the lowest non-zero dose, and scaled residual (>-2 and <+2) at the data point (except the control) closest to the predefined BMR. None of the models provided adequate fit. Therefore, the NOAEL of 0.03 mg Ni/m^3^ was selected as the point of departure (POD) for the MRL.

Table A-10 Incidence of Select Nonneoplastic Lung Lesions in Rats Exposed to Nickel Sulfate Hexahydrate for 2 Years via Inhalation

Concentration (mg Ni/m^3^) | Incidence (severity)^a^
Concentration (mg Ni/m^3^) | Chronic active inflammation | | Lung fibrosis
Concentration (mg Ni/m^3^) | Females | Males | Females | Males
0 | 14/52 (1.4) | 14/54 (1.1) | 8/52 (1.4) | 3/54 (1.0)^b^
0.03 | 13/53 (1.2) | 11/53 (1.2) | 7 53(1.3) | 6/53 (1.2)
0.06 | 49/53^b^ (2.1) | 42/53^b^ (1.9) | 45/53^b^ (1.7) | 35/53^b^ (1.7)
0.11 | 52/54^b^ (2.3) | 46/53^b^ (2.2) | 49/54^b^ (1.9) | 43/53^b^ (1.8)

a Average severity of lesions in affected animals: 1=minimal; 2=mild; 3=moderate; and 4=marked.

b Statistically different from control group (p≤0.01).

Source: NTP 1996c

The NOAEL of 0.03 mg Ni/m^3^ was adjusted for continuous exposure (6 hours/24 hours; 5 days/7 days) to a NOAEL_ADJ_ of 0.0053 mg Ni/m^3^ and converted to a NOAEL_HEC_ of 0.0033 mg Ni/m^3^ using the methodology and equations shown in the intermediate-duration MRL section and the values shown in Tables A-11 and A-12. Using the NOAEL_HEC_ of 0.0033 mg Ni/m^3^ as the final POD and a total uncertainty factor of 30 (3 for extrapolation from animals to humans with dosimetric adjustments and 10 for human variability) would result in a chronic-duration inhalation MRL of 0.0001 mg Ni/m^3^ (1×10^−4^ mg Ni/m^3^). However, this value is higher than the intermediate-duration inhalation MRL of 3×10^−6^ mg Ni/m^3^. A comparison of the intermediate and chronic inhalation databases offers an explanation for why the intermediate MRL is lower than the chronic-duration MRL. The intermediate-duration MRL is based on a study that identified a LOAEL of 0.04 mg Ni/m^3^ as nickel subsulfide (Oller et al. 2023); this LOAEL is lower than the intermediate-duration LOAELs for other nickel compounds. In the chronic-duration MRL database, the lowest LOAEL is 0.06 mg Ni/m^3^ (NOAEL of 0.03 mg Ni/m^3^) as nickel sulfate; for nickel subsulfide, the lowest LOAEL is 0.11 mg Ni/m^3^, a NOAEL was not identified. The intermediate-duration MRL was considered more protective and thus, a chronic-duration inhalation MRL was not derived.

Table A-11 MPPD Model (Version 3.04) Inputs and Results for Rat and Human Models

Parameters | Rats | Humans
Airway morphometry
Model | Asymmetric Multiple Path | Yem/Schum 5-Lobe
Functional residual capacity | 4 mL (default) | 3,300 mL (default)
Upper respiratory tract | 0.42 mL (default) | 50 mL (default)
Inhalant properties
Density^a^ | 2.07 g/cm^3^ | 2.07 g/cm^3^
Diameter, MMAD^b^ | 2.5 µm | 2.5 µm
GSD^b^ | 2.38 | 2.38
Inhalability adjustment | On | On
Exposure condition
Aerosol concentration (NOAEL_ADJ_) | 0.0053 mg Ni/m^3^ | 0.0053 mg Ni/m^3^
Breathing frequency | 102 breaths/minute (default) | 14.7 breaths/minute (calculated TWA)^c^
Tidal volume | 2.1 mL (default) | 875 mL (calculated TWA)^d^
Breathing scenario | Whole body | Nasa/oronasal breather^e^
Results
Alveolar region deposition fraction (total pulmonary deposition fraction) | 0.0330 | 0.1419

a NLM (2024l), nickel sulfate hexahydrate.

b NTP (1996c), Table K1.

c Breathing frequency is 12 breaths/minute at sleep/rest and 20 breaths/minute with light activity (ICRP 1994).

d Tidal volume is 625 mL at sleep, 750 mL at rest, and 1,250 mL with light activity (ICRP 1994).

e Breathing scenario is assumed nasal with sleep and at rest and oronasal-mouth with light activity.

GSD = geometric standard deviation; MMAD = mass median aerodynamic diameter; MPPD = Multiple-Path Particle Dosimetry; NOAEL_ADJ_ = no-observed-adverse-effect level adjusted for continuous exposure; TWA = time-weighted average

Table A-12 Values Used to Calculate a Human Equivalent Concentration (HEC) for Nickel

Variable | Rat value (R) | Human value (H) | Source
Ventilation rate (VR) | 0.3616 m^3^/day | 20 m^3^/day | EPA 1994
Deposition fraction (DF) | 0.0330 | 0.1419 | Calculated using MPPD software
Clearance rate^a^ (k) | 0.289 day^−1^ | 0.277 day^−1^ | Oller et al. 2014
Ratio of retention half-time (RH) (to rat half-time) | 1 | 1.04 | Oller et al. 2014
Alveolar surface area (SA) | 0.34 m^2^ | 54 m^2^ | EPA 1994, Table 4-4
Exposure days (n) | 730 days | 730 days | NTP 1996c

a Total clearance rate = ln2/retention half-time.

MPPD = Multiple Path Particle Dosimetry; NOAEL = no-observed-adverse-effect level

Agency Contact (Chemical Managers): Custodio Muianga, Ph.D., M.P.H.

## Nickel Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Nickel
CAS Numbers: | 7440-02-0
Date: | October 2024
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL. Data in humans are limited by small sample sizes and are not appropriate for extrapolation to a large population. Data from animals in the acute-duration oral database does not provide sufficient information to derive an MRL because serious health effects are seen at the lowest doses tested for critical endpoints in animals.

Rationale for Not Deriving an MRL: Several studies in humans (Gawkrodger et al. 1986; Hindsén et al. 2001; Jensen et al. 2003) examined allergic dermatitis in nickel sensitized subjects at various challenge doses. These studies were not considered for MRL development as sample sizes for doses tested were no more than 10 individuals in any study, and Jensen et al. (2003) noted that extrapolation of these results to larger populations would not be statistically adequate. Jensen et al. (2003) calculated that a sample size of 36 individuals per dose would be required to reach statistical significance. In nickel-sensitized individuals, allergic dermatitis occurred from ingesting a single challenge dose ≥0.058 mg Ni/kg as nickel sulfate (Gawkrodger et al. 1986; Hindsén et al. 2001; Jensen et al. 2003). Sunderman et al. (1988) reported nausea and abdominal cramps in approximately half of the workers ingesting water contaminated with nickel sulfate, nickel chloride, and boric acid; estimated exposure was 7.1–35.7 mg Ni/kg.

Developmental, reproductive, and neurological effects have been observed at the lowest doses tested in acute-duration oral animal studies. A summary of the NOAEL and LOAEL values for the sensitive targets of toxicity is presented in Table A-13. The observed developmental effects include increased resorptions, decreased litter size, increased pup mortality, decreased pup body weight, and skeletal abnormalities. The lowest LOAEL is approximately 46 mg Ni/kg/day as nickel chloride. Two studies reported serious effects at this dose level (increased resorptions/decreased implantation site and decreased number of live fetuses) (El-Sekily et al. 2020; Saini et al. 2014a); skeletal abnormalities have also been observed at this dose level (Saini et al. 2013, 2014a). However, a series of studies conducted by Saini et al. (2014b) reported no developmental effects at 46.125 mg Ni/kg/day in mice administered nickel chloride on GDs 0–5, 6–13, or 14–18; increased mortality and decreased birth weight were observed at the next highest dose tested (92.25 mg Ni/kg/day). Neurological effects (alterations in memory and decreased activity) were observed in mice following a single dose of 50 mg Ni/kg/day as nickel chloride.

Table A-13 Effect Levels for Select Acute-Duration Oral Exposure to Nickel Studies

Species (sex) | Frequency/duration | NOAEL (mg Ni/kg/day) | LOAEL (mg Ni/kg/day) | Effect | Reference (nickel compound)
Developmental
Mouse (F) | GDs 0–5 | | 46 | Skeletal abnormalities | Saini et al. 2014a (nickel chloride hexahydrate)
Mouse (F) | GDs 6–13 | | 46.125 | Skeletal abnormalities | Saini et al. 2013 (nickel chloride hexahydrate)
Mouse (F) | GDs 6–13 | | 46.125 (SLOAEL) | Increased resorption sites; incomplete skeletal and limb ossification; and supernumerary ribs | El-Sekily et al. 2020 (nickel chloride hexahydrate)
Mouse (F) | GDs 0–5 | 46.125 | 92.25 (SLOAEL) | Decreased litter size/dam | Saini et al. 2014b (nickel chloride hexahydrate)
Mouse (F) | GDs 14–18 | 46.125 | 92.25 (SLOAEL) | Offspring mortality (11.11%) and decreased birth weight (16%) | Saini et al. 2014b (nickel chloride hexahydrate)
Mouse (F) | GDs 6–13 | 46.125 | 92.25 (SLOAEL) | Increased offspring mortality (9.52%) and decreased birth weight (16%) | Saini et al. 2014b (nickel chloride hexahydrate)
Mouse (F) | GDs 8–12 | 45.3 | | No alteration in locomotor activity in offspring | Gray et al. 1986 (nickel chloride)
Reproductive
Mouse (F) | GDs 0–5 | | 46 (SLOAEL) | Decreased number of implantation sites and number of live fetuses/dam | Saini et al. 2014a (nickel chloride hexahydrate)
Neurological
Mouse (M) | Once | 5 | 50 | Reduced spatial memory performance; reduced locomotor activity | He et al. 2013 (nickel chloride hexahydrate)

F = females; GD = gestation day; LOAEL = lowest-observed-adverse-effect level; M = males; NOAEL = no-observed-adverse-effect level; SLOAEL = serious lowest-observed-adverse-effect level

Several animal studies reported serious developmental and reproductive effects at the lowest doses tested (46 mg Ni/kg/day). This precludes MRL derivation from these endpoints due to the ATSDR practice of not deriving MRLs from serious LOAELs. The conflicting results reported in studies testing 46 mg Ni/kg/day may be indicative that the dose is near the NOAEL/LOAEL boundary. Deriving an MRL on this value may not be health protective for the serious developmental effects, and further data on developmental toxicity at lower doses are needed.

Agency Contact (Chemical Managers): Custodio Muianga, Ph.D., M.P.H.

## Nickel Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Nickel
CAS Numbers: | 7440-02-0
Date: | October 2024
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration oral MRL as a NOAEL has not been identified in the database and the lowest LOAEL is associated with serious effects, precluding MRL derivation.

Rationale for Not Deriving an MRL: An MRL cannot be derived from human studies as only one study examined effects of intermediate-duration oral nickel exposure. No dermal reactions were reported among eight women sensitized to nickel and exposed to oral doses of 0.02 mg Ni/kg/day as nickel sulfate (Santucci et al. 1994).

Among experimental animal studies, neurological, body weight, reproductive, and developmental effects have been observed at the lowest doses tested. A summary of studies evaluating these endpoints is presented in Table A-14. Alterations in sperm parameters (decreased sperm motility and count and increased sperm abnormalities) and decreased fertility have been reported in male rats and mice exposed to ≥1.1 mg Ni/kg/day as nickel sulfate or nickel chloride (Käkelä et al. 1999; Pandey and Srivastava 2000; Pandey et al. 1999). Decreased fertility was also observed in a study in which males and females were exposed to 3.6 mg Ni/kg/day as nickel chloride for 28–76 days (Käkelä et al. 1999) but was not observed when only females were exposed to doses up to 13 mg Ni/kg/day as nickel chloride (Käkelä et al. 1999). Developmental effects have been observed at similar doses. Decreased pup survival, increased post-implantation loss, and decreased litter size were observed at doses of ≥1.3 mg Ni/kg/day as nickel chloride or nickel sulfate. The developmental effects were considered to be serious health effects. Other effects observed at higher doses included decreased body weight gain at ≥7.6 mg Ni/kg/day (Adeyemi et al. 2017; American Biogenics Corporation 1988; Dieter et al. 1988; Mahmoud et al. 2011; Springborn Laboratories 2002; Whanger 1973) and histological alterations in the kidneys and/or alterations in function parameters (plasma creatinine and urea, blood urea nitrogen, urine volume) at ≥7.6 mg Ni/kg/day (Adeyemi and Elebiyo 2014; Dahdouh et al. 2016; Dieter et al. 1988; Obone et al. 1999).

Table A-14 Summary of NOAEL and LOAEL Values for Sensitive Targets of Intermediate-Duration Oral Exposure to Nickel

Species (sex) | Frequency/duration | NOAEL (mg Ni/kg/day) | LOAEL (mg Ni/kg/day) | Effect | Reference (nickel compound)
Neurological
Rat (M) | 90 days; 3 days/week | | 0.2 | Impaired performance on test of learning and spatial memory | Anyachor et al. 2023
Body weight
Rat (M) | 28 days | | 0.23 (SLOAEL) | Decreased body weight gain (20%) | Weischer et al. 1980
Reproductive
Mouse (M) | 35 days; 5 days/week | | 1.1 | Decreased sperm motility and sperm count; increased sperm abnormalities | Pandey et al. 1999 (nickel sulfate)
Mouse (M) | 35 days; 5 days/week | 1.1 | 2.2 | Decreased sperm count and motility, increased sperm abnormalities | Pandey and Srivastava 2000 (nickel sulfate)
Mouse (M) | 35 days; 5 days/week | 1.2 | 2.5 | Decreased sperm count and motility, increased sperm abnormalities | Pandey and Srivastava 2000 (nickel chloride)
Rat (M) | 10 weeks prior to mating | 2.2 | | No alteration in sperm count, concentration, or motility | Springborn Laboratories 2000b (nickel sulfate)
Rat (B) | 10 weeks prior to mating | 2.2 | | No effect on fertility | Springborn Laboratories 2000b (nickel sulfate)
Rat (M) | 28 or 42 days before mating | | 3.6 (SLOAEL) | Decreased fertility | Käkelä et al. 1999 (nickel chloride)
Rat (B) | 28–76 days | | 3.6 (SLOAEL) | Decreased fertility | Käkelä et al. 1999 (nickel chloride)
Mouse (M) | 3–12 weeks | | 4.5 | Degeneration of seminiferous epithelium | Toman et al. 2012 (nickel chloride)
Rat (B) | 2 weeks prior to mating | 16.8 | | No effect on fertility | Springborn Laboratories 2000a (nickel sulfate)
Rat (F) | 11 weeks prior to mating | 31.6 | | No effect on fertility | Smith et al. 1993 (nickel chloride)
Rat (B) | 11 weeks prior to mating | 40 (M); 55 (F) | | No effect on fertility | EPA 1988a, 1988b (nickel chloride)
Developmental
Rat (F) | 11 weeks (breeding through lactation); two litters | | 1.3 (SLOAEL) | Decreased pup survival | Smith et al. 1993 (nickel chloride)
Mouse (M) | 35 days; 5 days/week | | 2.2 (SLOAEL) | Increased post-implantation loss | Pandey et al. 1999 (nickel sulfate)
Rat (M) | 28 or 42 days before mating | | 3.6 (SLOAEL) | Decreased number of pups born alive per dam, decreased litter size | Käkelä et al. 1999 (nickel chloride)
Rat (B) | 28–76 days | | 3.6 (SLOAEL) | Decreased number of pups born alive per dam, decreased litter size | Käkelä et al. 1999 (nickel chloride)
Rat (F) | 2 weeks prior to mating and during gestation and lactation | 4.5 | 6.7 (SLOAEL) | Increased post-implantation loss | Springborn Laboratories 2000a (nickel sulfate hexahydrate)
Rat (B) | 2-generation study, 10 weeks prior to mating and during gestation and lactation | 2.2 | | No developmental effects | Springborn Laboratories 2000b (nickel sulfate hexahydrate)

B = both males and females; F = females; GD = gestation day; LOAEL = lowest-observed-adverse-effect level; M = males; NOAEL = no-observed-adverse-effect level; SLOAEL = serious lowest-observed-adverse-effect level

The available intermediate-duration data are not considered suitable for MRL derivation because serious body weight and developmental effects were observed at some of the lowest doses tested. Although a slightly lower less serious LOAEL was identified for neurological effects, this dose of 0.2 mg Ni/kg/day is only slightly lower than the serious LOAEL of 0.23 mg Ni/kg/day. Therefore, deriving an MRL based on the neurological effects may not be protective of the developmental effects. It is noted that the neurological effects data from the Anyachor et al. (2023) study is not amenable to BMD modeling because only one dose was tested.

Agency Contact (Chemical Managers): Custodio Muianga, Ph.D., M.P.H.

## Nickel Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Nickel
CAS Numbers: | 7440-02-0
Date: | October 2024
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL as the database indicates that serious adverse health effects are associated with the lowest levels of exposure, and no critical effect can be identified as the basis of an MRL.

Rationale for Not Deriving an MRL: No studies were located that exposed humans to nickel for chronic duration. Two animal studies have evaluated the chronic oral toxicity of nickel sulfate. A study in rats (Heim et al. 2007) reported increased mortality in females and decreased terminal body weights in males administered via gavage 6.7 mg Ni/kg/day as nickel sulfate for 2 years; the NOAEL for body weight effects in females was 2.2 mg Ni/kg/day. No other biologically relevant adverse effects were reported in the study. In the second chronic-duration study, body weight, respiratory (cholesterol granulomas, emphysema, and bronchiolectasis), and renal effects (polyuria) were observed in dogs exposed to 62.5 mg Ni/kg/day as nickel sulfate in the diet (Ambrose et al. 1976). The database also includes a 2-year study in rats conducted by Ambrose et al. (1976), which reported a 34% decrease in terminal body weights in female rats exposed to 75 mg Ni/kg/day as nickel sulfate in the diet; however, the study quality is considered poor due to the high mortality in the control group.

The database was not considered suitable for derivation of a chronic-duration oral MRL. The rat (Heim et al. 2007) and dog (Ambrose et al. 1976) were not considered suitable principal studies because increased mortality was observed at the lowest adverse effect level. Although the Heim et al. (2007) study identified a NOAEL for body weight effects at 2.2 mg/kg/day, alterations in body weight are not considered primary effects of nickel and are likely secondary effects; therefore, the Heim et al. (2007) was not considered suitable as the basis for MRL derivation.

Agency Contact (Chemical Managers): Custodio Muianga, Ph.D., M.P.H.