# CHAPTER 8 REFERENCES

Abbritti G, Siracusa A, Cianchetti C, . 1976. Shoe-makers’ polyneuropathy in Italy: the aetiological problem. Br J Ind Med 33(2):92–99. 10.1136/oem.33.2.92.1276096
Abou-Donia MB, Lapadula DM. 1990. Mechanisms of organophosphorus ester-induced delayed neurotoxicity: type I and type II. Annu Rev Pharmacol Toxicol 30:405–440. 10.1146/annurev.pa.30.040190.002201.2188574
Abou-Donia MB, Makkawy HA, Graham DG. 1982. The relative neurotoxicities of n-hexane, methyl n-butyl ketone, 2,5-hexanediol, and 2,5-hexanedione following oral or intraperitoneal administration in hens. Toxicol Appl Pharmacol 62(3):369–389. 10.1016/0041-008x(82)90139-9.7071856
Abou-Donia MB, Lapadula DM, Campbell G, . 1985. The synergism of n-hexane-induced neurotoxicity by methyl isobutyl ketone following subchronic (90 days) inhalation in hens: induction of hepatic microsomal cytochrome P-450. Toxicol Appl Pharmacol 81(1):1–16. 10.1016/0041-008x(85)90114-0.4049411
Abou-Donia MB, Lapadula DM, Suwita E. 1988. Cytoskeletal proteins as targets for organophosphorus compound and aliphatic hexacarbon-induced neurotoxicity. Toxicology 49(2–3):469–477. 10.1016/0300-483x(88)90033-9.2836976
Abou-Donia MB, Hu ZH, Lapadula DM, . 1991. Mechanisms of joint neurotoxicity of n-hexane, methyl isobutyl ketone and O-ethyl O-4-nitrophenyl phenylphosphonothioate in hens. J Pharmacol Exp Ther 257(1):282–289.2019992
Agnesi R, Valentini F, Mastrangelo G. 1997. Risk of spontaneous abortion and maternal exposure to organic solvents in the shoe industry. Int Arch Occup Environ Health 69(5):311–316. 10.1007/s004200050153.9192214
Ahearn DG, Crow SA, Simmons RB, . 1996. Fungal colonization of fiberglass insulation in the air distribution system of a multi-story office building: VOC production and possible relationship to a sick building syndrome. J Ind Microbiol 16(5):280–285. 10.1007/BF01570035.8757941
Ali N, Tardif R. 2006. Toxicokinetic modeling of the combined exposure to toluene and n-hexane in rats and humans. J Occup Health 41(2):95–103. 10.1539/joh.41.95.
Allen N, Mendell JR, Billmaier DJ, . 1975. Toxic polyneuropathy due to methyl n-butyl ketone. Arch Neurol 32:209–218. 10.1001/archneur.1975.00490460025001.164846
Altenkirch H, Mager J, Stoltenburg G, . 1977. Toxic polyneuropathies after sniffing a glue thinner. J Neurol 214(2):137–152. 10.1007/BF02430351.64597
Altenkirch H, Wagner HM, Stoltenburg G, . 1982. Nervous system responses of rats to subchronic inhalation of N-hexane and N-hexane + methyl-ethyl-ketone mixtures. J Neurol Sci 57(2–3):209–219. 10.1016/0022-510x(82)90028-4.6891717
Amoore JE, Hautala E. 1983. Odor as an aid to chemical safety: odor thresholds compared with threshold limit values and volatilities for 214 industrial chemicals in air and water dilution. J Appl Toxicol 3(6):272–290. 10.1002/jat.2550030603.6376602
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York, NY: Marcel Dekker, Inc, 9–25.
Anthony DC, Boekelheide K, Anderson CW, . 1983. The effect of 3,4-dimethyl substitution on the neurotoxicity of 2,5-hexanedione. II. Dimethyl substitution accelerates pyrrole formation and protein crosslinking. Toxicol Appl Pharmacol 71(3):372–382. 10.1016/0041-008x(83)90024-8.6658787
API. 1978. 26 Week inhalation toxicity study of n-hexane in the rat. American Petroleum Institute. Submitted to the U.S. Environmental Protection Agency under TSCA Section FYI. OTS0000137-0. FYI-AX-1081-0137. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS00001370.xhtml. February 23, 2023.
API. 1979. Teratology study in rats: n-hexane. Submitted to the U.S. Environmental Protection Agency under TSCA section FYI. OTS0000231-0. FYIAX01830231. LBI Project No. 20698-9. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS00002310.xhtml. February 16, 2023.
API. 1980. Mutagenicity evaluation of n-hexane in the mouse dominant lethal assay final report. American Petroleum Institute. Submitted to the U.S. Environmental Protection Agency under TSCA Section FYI. OTS0000137-0. FYI-AX-1081-0137. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS00001370.xhtml. February 23, 2023.
API. 1981. Six-month continuous inhalation exposure of rats to hexane mixtures-Phase II. American Petroleum Institute. Submitted to the U.S. Environmental Protection Agency under TSCA section FYI. OTS00001660. FYI-AX-0282-0166. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS00001660.xhtml. February 23, 2023.
Ashworth RA, Howe GB, Mullins ME, . 1988. Air-water partitioning coefficients of organics in dilute aqueous solutions. J Hazard Mater 18:25–33. 10.1016/0304-3894(88)85057-X.
Atkinson R. 1985. Kinetics and mechanisms of the gas-phase reactions of the hydroxyl radical with organic compounds under atmospheric conditions. Chem Rev 86(1):69–201. 10.1021/cr00071a004.
Atkinson R, Carter WPL. 1984. Kinetics and mechanisms of the gas phase reactions of ozone with organic compounds under atmospheric conditions. Chem Rev 84:437–470. 10.1021/cr00063a002.
Atkinson R, Aschmann SM, Carter WPL, . 1982. Kinetics of the reactions of OH radicals with n-alkanes at 299 ± 2 K. Int J Chem Kinet 14(7):781–788. 10.1002/kin.550140706.
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles. Agency for Toxic Substances and Disease Registry. Fed Reg 54(174):37618–37634. https://archives.federalregister.gov/issue_slice/1989/9/11/37613-37634.pdf#page=6. February 23, 2023.
ATSDR. 2022a. n-Hexane. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/SPL/resources/index.html. June 8, 2023.
ATSDR. 2022b. Sanders2015 HLCs used in SHOWER Model v3 and PHAST. Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/phaguidance/toolbox/ATSDR_SHOWER_Model_v3_0_0.zip. May 3, 2023.
Bachmann MO, De Beer Z, Myers JE. 1993. n-Hexane neurotoxicity in metal can manufacturing workers. Occup Med 43(3):149–154. 10.1093/occmed/43.3.149.
Baelum J, Mølhave L, Hansen SH, . 1998. Metabolic interaction between toluene, trichloroethylene and n-hexane in humans. Scand J Work Environ Health 24(1):30–37. 10.5271/sjweh.275.9562398
Baker TS, Rickert DE. 1981. Dose-dependent uptake, distribution, and elimination of inhaled n-hexane in the Fischer-344 rat. Toxicol Appl Pharmacol 61(3):414–422. 10.1016/0041-008x(81)90364-1.7330882
Barnes DG, Dourson M. 1988. Reference dose (RfD): description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486. 10.1016/0273-2300(88)90047-5.3222488
Barrefors G, Petersson G. 1993. Assessment of ambient volatile hydrocarbons from tobacco smoke and from vehicle emissions. J Chromatogr 643(1–2):71–76. 10.1016/0021-9673(93)80542-g.7689578
Bates MN, Reed BR, Liu S, . 2016. Solvent exposure and cognitive function in automotive technicians. Neurotoxicology 57:22–30. 10.1016/j.neuro.2016.08.009.27545874
Bates MN, Pope K, So YT, . 2019. Hexane exposure and persistent peripheral neuropathy in automotive technicians. Neurotoxicology 75:24–29. 10.1016/j.neuro.2019.08.008.31445054
Bavazzano P, Apostoli P, Balducci C, . 1998. Determination of urinary 2,5-hexanedione in the general Italian population. Int Arch Occup Environ Health 71(4):284–288. 10.1007/s004200050282.9638486
Beall C, Delzell E, Rodu B, . 2001. Case-control study of intracranial tumors among employees at a petrochemical research facility. J Occup Environ Med 43(12):1103–1113. 10.1097/00043764-200112000-00012.11765681
Beckman S, Eisen EA, Bates MN, . 2016. Acquired color vision defects and hexane exposure: a study of San Francisco Bay area automotive mechanics. Am J Epidemiol 183(11):969–976. 10.1093/aje/kwv328.27188942
Bhagya S, Srinivas H. 1992. Extraction of soybean (Glycine max.) with hexane-acetic acid: Effect on oil quality. Food Chemistry 44(2):123–125. 10.1016/0308-8146(92)90323-t.
Bishop GA, Zhang Y, McLaren SE, . 1994. Enhancement of remote sensing for vehicle emissions in tunnels. Air Waste 44:169–175. 10.1080/1073161X.1994.10467246.
Biziuk M, Namiesnik J, Czerwinski J, . 1996. Occurrence and determination of organic pollutants in tap and surface waters of the Gdansk district. J Chromatogr A 733(1–2):171–183. 10.1016/0021-9673(95)00905-1.8814789
Boggess A, Faber S, Kern J, . 2016. Mean serum-level of common organic pollutants is predictive of behavioral severity in children with autism spectrum disorders. Sci Rep 6:26185. 10.1038/srep26185.27174041
Bottenheim JW, Shepherd MF. 1995. C_2_-C_6_ Hydrocarbon measurements at four rural locations across Canada. Atmos Environ 29(6):647–664. 10.1016/1352-2310(94)00318-F.
Bouakkaz I, Khelili K, Rebai T, . 2018. Pulmonary toxicity induced by n-hexane in Wistar male rats after oral subchronic exposure. Dose Response 16(4):1559325818799560. 10.1177/1559325818799560.30349425
Bouhamra WS. 1995. Estimation of volatile organic compounds in Kuwaiti houses after the Gulf war. Environ Pollut 90(1):121–125. 10.1016/0269-7491(94)00086-s.15091509
Brosseau J, Heitz M. 1994. Trace gas compound emissions from municipal landfill sanitary sites. Atmos Environ 28(2):285–293. 10.1016/1352-2310(94)90103-1.
Brugnone F, Maranelli G, Romeo L, . 1991. Ubiquitous pollution by n-hexane and reference biological levels in the general population. Int Arch Occup Environ Health 63(3):157–160. 10.1007/BF00381562.1917064
Buchdahl R, Willems CD, Vander M, . 2000. Associations between ambient ozone, hydrocarbons, and childhood wheezy episodes: a prospective observational study in south east London. Occup Environ Med 57(2):86–93. 10.1136/oem.57.2.86.10711275
Budavari S, O’Neill MJ, Smith A, . 1989. n-Hexane. In: Merck index: An encyclopedia of chemicals, drugs, and biologicals. 11^th^ ed. Rahway NJ: Merck & Co., Inc, 741.
Burk T, Zarus G. 2013. Community exposures to chemicals through vapor intrusion: a review of past ATSDR public health evaluations. J Environ Health 75(9):36–41.
Bus JS, White EL, Tyl RW, . 1979. Perinatal toxicity and metabolism of n-hexane in Fischer-344 rats after inhalation exposure during gestation. Toxicol Appl Pharmacol 51(2):295–302. 10.1016/0041-008x(79)90472-1.531893
Bus JS, White EL, Gillies PJ, . 1981. Tissue distribution of n-hexane, methyl n-butyl ketone, and 2,5-hexanedione in rats after single or repeated inhalation exposure to n-hexane. Drug Metab Dispos 9(4):386–387.6114840
Bus JS, Deyo D, Cox M. 1982. Dose-dependent disposition of n-hexane in F-344 rats after inhalation exposure. Fundam Appl Toxicol 2(5):226–229. 10.1016/s0272-0590(82)80031-6.6821041
Cardona A, Marhuenda D, Marti J, . 1993. Biological monitoring of occupational exposure to n-hexane by measurement of urinary 2,5-hexanedione. Int Arch Occup Environ Health 65(1):71–74. 10.1007/BF00586062.8354578
Cardona A, Marhuenda D, Prieto MJ, . 1996. Behaviour of urinary 2,5-hexanedione in occupational co-exposure to n-hexane and acetone. Int Arch Occup Environ Health 68(2):88–93. 10.1007/BF00381240.8720278
Carelli V, Franceschini F, Venturi S, . 2007. Grand rounds: could occupational exposure to n-hexane and other solvents precipitate visual failure in leber hereditary optic neuropathy? Environ Health Perspect 115(1):113–115. 10.1289/ehp.9245.17366829
Cavender FL, Casey HW, Salem H, . 1984. A 13-week vapor inhalation study of n-hexane in rats with emphasis on neurotoxic effects. Fundam Appl Toxicol 4(2 Pt 1):191–201. 10.1016/0272-0590(84)90119-2.6724193
CDC. 2017. Volatile organic compounds (VOCs) - Blood (VOCWB_F). National Health and Nutrition Examination Survey: 2009-2010 Data documentation, codebook, and frequencies. Centers for Disease Control and Prevention. https://wwwn.cdc.gov/Nchs/Nhanes/2009-2010/VOCWB_F.htm. October 24, 2024.
Chalansonnet M, Carabin N, Boucard S, . 2013. Study of the potential oxidative stress induced by six solvents in the rat brain. Neurotoxicology 35:71–83. 10.1016/j.neuro.2012.12.002.23270871
Chan C, Liu S, Her G. 1994. Office workers exposure to volatile organic compounds while commuting and working in Taipei City. Atmos Environ 28(14):2351–2359. 10.1016/1352-2310(94)90489-8.
Chang YC. 1987. Neurotoxic effects of n-hexane on the human central nervous system: evoked potential abnormalities in n-hexane polyneuropathy. J Neurol Neurosurg Psychiatry 50(3):269–274. 10.1136/jnnp.50.3.269.3031221
Chang YC, Yip PK. 1987. N-hexane-induced electroneurographic changes and early detection of N-hexane intoxication. Taiwan Yi Xue Hui Za Zhi 86(2):194–200.3033122
Chang CM, Yu CW, Fong KY, . 1993. N-hexane neuropathy in offset printers. J Neurol Neurosurg Psychiatry 56(5):538–542. 10.1136/jnnp.56.5.538.8505647
Chapin RE, Norton RM, Popp JA, . 1982. The effects of 2,5-hexanedione on reproductive hormones and testicular enzyme activities in the F-344 rat. Toxicol Appl Pharmacol 62(2):262–272. 10.1016/0041-008x(82)90124–7.6120587
Chen D, Werder EJ, Stewart PA, . 2023a. Exposure to volatile hydrocarbons and neurologic function among oil spill workers up to 6 years after the Deepwater Horizon disaster. Environ Res 231(Pt 1):116069. 10.1016/j.envres.2023.116069.37149022
Chen D, Werder EJ, Stewart PA, . 2023b. Supplemental material: Exposure to volatile hydrocarbons and neurologic function among oil spill workers up to 6 years after the Deepwater Horizon disaster. Environ Res 231(Pt 1). 10.1016/j.envres.2023.116069.
Chiou CT, Kile DE, Malcolm RL. 1988. Sorption of vapors of some organic liquids on soil humic acid and its relation to partitioning of organic compounds in soil organic matter. Environ Sci Technol 22(3):298–303. 10.1021/es00168a010.22288864
Cianchetti C, Abbritti G, Perticoni G, . 1976. Toxic polyneuropathy of shoe-industry workers. A study of 122 cases. J Neurol Neurosurg Psychiatry 39(12):1151–1161. 10.1136/jnnp.39.12.1151.1011025
Clewell HJ. 1995. The application of physiologically based pharmacokinetic modeling in human health risk assessment of hazardous substances. Toxicol Lett 79(1–3):207–217. 10.1016/0378-4274(95)03372-r.7570658
Coates M, Connell DW, Barron DM. 1985. Aqueous solubility and octan-1-ol-water partition coefficients of aliphatic hydrocarbons. Environ Sci Technol 19(7):628–632. 10.1021/es00137a008.22148306
Conkerton EJ, Wan PJ, Richard OA. 1995. Hexane and heptane as extraction solvents for cottonseed: A laboratory-scale study. J Am Oil Chem Soc 72(8):963–965. 10.1007/bf02542075.
Cravotto C, Fabiano-Tixier AS, Claux O, . 2022. Towards substitution of hexane as extraction solvent of food products and ingredients with no regrets. Foods 11(21):3412. 10.3390/foods11213412.36360023
Crawford DW, Bonnevie NL, Wenning RJ. 1995. Sources of pollution and sediment contamination in Newark Bay, New Jersey. Ecotoxicol Environ Saf 30(1):85–100. 10.1006/eesa.1995.1010.7540541
Creaser C, Welch J, Bishop K. 1983. Letters to the editor: n-Hexane in petroleum ether fractions. Ann Occup Hyg 27(2):229–230. 10.1093/annhyg/27.2.229.6614733
Crosbie SJ, Blain PG, Williams FM. 1997. Metabolism of n-hexane by rat liver and extrahepatic tissues and the effect of cytochrome P-450 inducers. Hum Exp Toxicol 16(3):131–137. 10.1177/096032719701600301.9088965
Daisey JM, Hodgson AT, Fisk WJ, . 1994. Volatile organic compounds in twelve California office buildings: Classes, concentrations and sources. Atmos Environ 28(22):3557–3562. 10.1016/1352-2310(94)00200-5.
De Martino C, Malorni W, Amantini MC, . 1987. Effects of respiratory treatment with n-hexane on rat testis morphology. I. A light microscopic study. Experimental and Molecular Pathology 46(2):199–216. 10.1016/0014-4800(87)90066-9.3556533
DeCaprio AP, O’Neill EA. 1985. Alterations in rat axonal cytoskeletal proteins induced by in vitro and in vivo 2,5-hexanedione exposure. Toxicol Appl Pharmacol 78(2):235–247. 10.1016/0041-008x(85)90287-x.3929425
DeCaprio AP, Olajos EJ, Weber P. 1982. Covalent binding of a neurotoxic n-hexane metabolite: conversion of primary amines to substituted pyrrole adducts by 2,5-hexanedione. Toxicol Appl Pharmacol 65(3):440–450. 10.1016/0041-008x(82)90389-1.7157375
DeLuchi MA. 1993. Emissions from the production, storage, and transport of crude oil and gasoline. Air Waste 43(11):1486–1495. 10.1080/1073161X.1993.10467222.
DeWalle FB, Chian ESK. 1981. Detection of trace organics in well water near a solid waste landfill. J Am Water Works Assoc 73(4):206–211. 10.1002/j.1551-8833.1981.tb04681.x.
DOE. 2024a. Protective action criteria (PAC) based on AEGLs, ERPGs, or TEELs. U.S. Department of Energy. https://edms3.energy.gov/pac/TeelDocs. September 13, 2024.
DOE. 2024b. Definition of PACs (AEGLs, ERPGs or TEELs). U.S. Department of Energy. https://edms3.energy.gov/pac/TeelDef. September 13, 2024.
Domínguez H, Núñez MJ, Lema JM. 1995. Enzyme-assisted hexane extraction of soya bean oil. Food Chemistry 54(2):223–231. 10.1016/0308-8146(95)00018-e.
Dunnick JK, Graham DG, Yang RS, . 1989. Thirteen-week toxicity study of n-hexane in B6C3F1 mice after inhalation exposure. Toxicology 57(2):163–172. 10.1016/0300-483x(89)90162-5.2749745
Eiceman GA, McConnon JT, Zaman M, . 1986. Hydrocarbons and aromatic hydrocarbons in groundwater surrounding an earthen waste disposal pit for produced water in the Duncan oil field of New Mexico. Int J Environ Anal Chem 24(2):143–162. 10.1080/03067318608076465.3710677
Eisenreich SJ, Looney BB, Thornton JD. 1981. Airborne organic contaminants in the Great Lakes ecosystem. Environ Sci Technol 15(1):30–38. 10.1021/es00083a002.
El-Masri HA, Mumtaz MM, Yushak ML. 2004. Application of physiologically-based pharmacokinetic modeling to investigate the toxicological interaction between chlorpyrifos and parathion in the rat. Environ Toxicol Pharmacol 16(1–2):57–71. 10.1016/j.etap.2003.10.002.21782694
EPA. 1993. Determination of reportable quantities for hazardous substances. U.S. Environmental Protection Agency. Fed Reg 58(203):54840–54862. https://www.govinfo.gov/app/details/FR-1993-10-22. May 2, 2023.
EPA. 1994a. Automobile emissions: an overview. Ann Arbor, MI: U.S. Environmental Protection Agency. EPA400F92007. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P10001KF.txt. February 21, 2023.
EPA. 1994b. Methods for derivation inhalation reference concentrations and application of inhalation dosimetry. Washington, DC: U.S. Environmental Protection Agency. PB2000100284. EPA600890066F. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB2000100284.xhtml. February 17, 2023.
EPA. 1996. National emission standards for hazardous air pollutants; final standards for hazardous air pollutant emissions from the printing and publishing industry. U.S. Environmental Protection Agency. Fed Reg 61(105):27132–27159. https://www.govinfo.gov/content/pkg/FR-1996-05-30/pdf/96-13084.pdf. May 4, 2023.
EPA. 2000. Hexane: 110-54-3. Health effects notebook for hazardous air pollutants. U.S. Environmental Protection Agency. https://www.epa.gov/sites/default/files/2016-09/documents/hexane.pdf. February 20, 2023.
EPA. 2004. Exposure analysis modeling system (EXAMS). Athens, GA: U.S. Environmental Protection Agency. EPA600R00081. https://www.epa.gov/ceam/exposure-analysis-modeling-system-exams-user-manual-and-system-documentation. June 4, 2023.
EPA. 2009. Provisional peer-reviewed toxicity values for 1,2-dichloroethane (CASRN 107-06-2). Cincinnati, OH: U.S. Environmental Protection Agency. EPA690R09025F. https://cfpub.epa.gov/ncea/pprtv/documents/HexaneN.pdf. January 30, 2023.
EPA. 2012. n-Hexane. Estimation Programs Interface Suite™ for Microsoft® Windows, v 4.11. Washington, DC: U.S. Environmental Protection Agency. https://www.epa.gov/tsca-screening-tools/epi-suitetm-estimation-program-interface. October 20, 2022.
EPA. 2018a. 2018 Edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency. EPA822F18001. https://www.epa.gov/system/files/documents/2022-01/dwtable2018.pdf. June 15, 2022.
EPA. 2018b. Compiled AEGL values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2018-08/documents/compiled_aegls_update_27jul2018.pdf. April 12, 2020.
EPA. 2018c. About acute exposure guideline levels (AEGLs). U.S. Environmental Protection Agency. https://www.epa.gov/aegl/about-acute-exposure-guideline-levels-aegls. July 26, 2018.
EPA. 2022a. 2017 NEI data. U.S. Environmental Protection Agency. https://www.epa.gov/air-emissions-inventories/2017-national-emissions-inventory-nei-data. May 3, 2023.
EPA. 2022b. Toxic chemical release inventory reporting forms and instructions: Revised 2021 version. U.S. Environmental Protection Agency. EPA740B22002. https://ordspub.epa.gov/ords/guideme_ext/guideme_ext/guideme/file/ry_2021_rfi.pdf. August 22, 2023.
EPA. 2023a. Innovations in site characterization: Streamlining cleanup at vapor intrusion and product removal sites using the triad approach: Hartford Plume Site, Hartford, Illinois. Washington, DC: U.S. Environmental Protection Agency. EPA542R10006. https://www.epa.gov/remedytech/innovations-site-characterization-streamlining-cleanup-vapor-intrusion-and-product. June 9, 2023.
EPA. 2023b. National primary drinking water regulations. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141. https://www.govinfo.gov/content/pkg/CFR-2023-title40-vol25/pdf/CFR-2023-title40-vol25-part141.pdf. May 3, 2024.
EPA. 2024. Annual summary data: n-hexane. Air quality system: Concentration by monitor. U.S. Environmental Protection Agency. https://aqs.epa.gov/aqsweb/airdata/download_files.html. January 18, 2024.
Farmer TH. 1996. Occupational hygiene limits for hydrocarbon solvents. Ann Occup Hyg 40(2):237–242. 10.1093/annhyg/40.2.237.
FDA. 2024. Hexane. Substances added to food. U.S. Food and Drug Administration. https://www.cfsanappsexternal.fda.gov/scripts/fdcc/index.cfm?set=FoodSubstances&id=HEXANE. October 14, 2024.
Fedtke N, Bolt HM. 1986. Detection of 2,5-hexanedione in the urine of persons not exposed to n-hexane. Int Arch Occup Environ Health 57(2):143–148. 10.1007/BF00381382.3949398
Fedtke N, Bolt HM. 1987. The relevance of 4,5-dihydroxy-2-hexanone in the excretion kinetics of n-hexane metabolites in rat and man. Arch Toxicol 61:131–137. 10.1007/BF00661371.3439885
Feenstra S, Mackay DM, Cherry JA. 1991. A method for assessing residual NAPL based on organic chemical concentrations in soil samples. Ground Water Monit Remediat 11(2):128–136. 10.1111/j.1745-6592.1991.tb00374.x.
Filser JG, Bolt HM, Muliawan H, . 1983. Quantitative evaluation of ethane and n-pentane as indicators of lipid peroxidation in vivo. Arch Toxicol 52:135–147. 10.1007/BF00354773.6847379
Filser JG, Peter H, Bolt HM, . 1987. Pharmacokinetics of the neurotoxin n-hexane in rat and man. Arch Toxicol 60(1–3):77–80. 10.1007/BF00296952.3619648
Fisher J, Mahle D, Bankston L, . 1997. Lactational transfer of volatile chemicals in breast milk. Am Ind Hyg Assoc J 58(6):425–443. 10.1080/15428119791012667.9183837
Frontali N, Amantini MC, Spagnolo A, . 1981. Experimental neurotoxicity and urinary metabolites of the C5-C7 aliphatic hydrocarbons used as glue solvents in shoe manufacture. Clin Toxicol 18(12):1357–1367. 10.3109/15563658108990344.
Gao JF, Zhang XY, Lin Q, . 2019. [Changes to learning and memory ability and the expression of NGF/NGF-R mRNA in the brain tissue in mice exposed to n-hexane]. Clin J Ind Hyg Occup Dis 37(3):217–221. 10.3760/cma.j.issn.1001-9391.2019.03.013. (Chinese)
Gargas ML, Burgess RJ, Voisard DE, . 1989. Partition coefficients of low-molecular-weight volatile chemicals in various liquids and tissues. Toxicol Appl Pharmacol 98(1):87–99. 10.1016/0041-008x(89)90137-3.2929023
Genter St. Clair MB, Amarnath V, Moody MA, . 1988. Pyrrole oxidation and protein cross-linking as necessary steps in the development of gamma-diketone neuropathy. Chem Res Toxicol 1(3):179–185. 10.1021/tx00003a009.2979729
Gillies PJ, Norton RM, Baker TS, . 1981. Altered lipid metabolism in 2,5-hexanedione-induced testicular atrophy and peripheral neuropathy in the rat. Toxicol Appl Pharmacol 59(2):293–299. 10.1016/0041-008x(81)90201-5.6266077
Goldman SM, Quinlan PJ, Ross GW, . 2012. Solvent exposures and Parkinson disease risk in twins. Ann Neurol 71(6):776–784. 10.1002/ana.22629.22083847
Gong Y, Kishi R, Kasai S, . 2003. Visual dysfunction in workers exposed to a mixture of organic solvents. Neurotoxicology 24(4–5):703–710. 10.1016/S0161-813X(03)00034-2.12900083
Gong X, Lin Y, Bell ML, . 2018. Associations between maternal residential proximity to air emissions from industrial facilities and low birth weight in Texas, USA. Environ Int 120:181–198. 10.1016/j.envint.2018.07.045.30096612
Governa M, Calisti R, Coppa G, . 1987. Urinary excretion of 2,5-hexanedione and peripheral polyneuropathies workers exposed to hexane. J Toxicol Environ Health 20(3):219–228. 10.1080/15287398709530976.3029393
Graham DG, Anthony DC, Boekelheide K, . 1982. Studies of the molecular pathogenesis of hexane neuropathy. II. Evidence that pyrrole derivatization of lysyl residues leads to protein crosslinking. Toxicol Appl Pharmacol 64(3):415–422. 10.1016/0041-008x(82)90237-x.6814014
Graham DG, Amarnath V, Valentine WM, . 1995. Pathogenetic studies of hexane and carbon disulfide neurotoxicity. Crit Rev Toxicol 25(2):91–112. 10.3109/10408449509021609.7612176
Hageman G, van der Hoek J, van Hout M, . 1999. Parkinsonism, pyramidal signs, polyneuropathy, and cognitive decline after long-term occupational solvent exposure. J Neurol 246(3):198–206. 10.1007/s004150050334.10323318
Hansch C, Leo A, Hoekman D. 1995. n-Hexane. In: Exploring QSAR: Hydrophobic, electronic, and steric constants. Vol. 2. Washington, DC: American Chemical Society, 24.
Hautfenne A, Pocklington WD, Wolfe JP. 1987. Determination of hexane residues in oils: Results of a collaborative study and the standardised method. Pure Appl Chem 59(11):1561–1570. 10.1351/pac198759111561.
Heath JS, Koblis K, Sager SL, . 1993. Risk assessment for total petroleum hydrocarbons. In: Kostecki PT, Calabrese EJ, eds. Hydrocarbon contaminated soils and groundwater. Vol. 3. Chelsea MI: Lewis Publisher, 267–301.
Herbert R, Gerr F, Luo J, . 1995. Peripheral neurological abnormalities among roofing workers: Sentinel case and clinical screening. Arch Environ Health 50(5):349–354. 10.1080/00039896.1995.9935966.7574888
Heringa JW, Huybregtse R, van der Linden AC. 1961. n-Alkane oxidation by a Pseudomonas formation and B-oxidation of intermediate fatty acids. Antonie Van Leeuwenhoef 27:51–58. 10.1007/BF02538422.
Hernandez JE, Machado LT, Corbella R, . 1995. n-Alkanes and polynuclear aromatic hydrocarbons in fresh-frozen and precooked-frozen mussels. Bull Environ Contam Toxicol 55(3):461–468. 10.1007/BF00206687.8520155
Herskowitz A, Ishii N, Schaumburg H. 1971. n-Hexane neuropathy: A syndrome occurring as a result of industrial exposure. N Engl J Med 285:82–85. 10.1056/NEJM197107082850204.4326704
Houk VS, Schalkowsky S, Claxton LD. 1989. Development and validation of the spiral Salmonella assay: an automated approach to bacterial mutagenicity testing. Mutat Res 223(1):49–64. 10.1016/0165-1218(89)90062-1.2497344
Howd RA, Rebert CS, Dickinson J, . 1983. A comparison of the rates of development of functional hexane neuropathy in weanling and young adult rats. Neurobehav Toxicol Teratol 5(1):63–68.6304548
Huang J, Kato K, Shibata E, . 1989. Effects of chronic n-hexane exposure on nervous system-specific and muscle-specific proteins. Arch Toxicol 63(5):381–385. 10.1007/BF00303127.2818202
Huang CC, Shih TS, Cheng SY, . 1991. n-Hexane polyneuropathy in a ball-manufacturing factory. J Occup Med 33(2):139–142.2016652
Hunt JR, Sitar N, Udell KS. 1988. Nonaqueous phase liquid transport and cleanup: 1. Analysis of mechanisms. Water Resour Res 24(8):1247–1258. 10.1029/WR024i008p01247.
IARC. 2024. Agents classified by the IARC monographs. International Agency for Research on Cancer. https://monographs.iarc.fr/list-of-classifications. September 13, 2024.
Iba MM, Fung J, Gonzalez FJ. 2000. Functional Cyp2e1 is required for substantial in vivo formation of 2,5-hexanedione from n-hexane in the mouse. Arch Toxicol 74(10):582–586. 10.1007/s002040000182.11201664
Ichihara G, Saito I, Kamijima M, . 1998. Urinary 2,5-hexanedione increases with potentiation of neurotoxicity in chronic coexposure to n-hexane and methyl ethyl ketone. Int Arch Occup Environ Health 71(2):100–104. 10.1007/s004200050255.9553785
IDPH. 2002. Public health assessment: Response to vapors in Hartford Homes, IL. Illinois Department of Public Health. http://www.idph.state.il.us/envhealth/pdf/Hartford%20PHA%20PC%20R.pdf. June 8, 2023.
Iida M. 1982. Neurophysiological studies of n-hexane polyneuropathy in the sandal factory. Electroencephalogr Clin Neurophysiol Suppl 36:671–681.6297875
Imai T, Omoto M. 1999. A preliminary report on the tumorigenic effect of long-term exposure to n-hexane in the rat testis. J Occup Health 41(4):261–262. 10.1539/joh.41.261.
IRIS. 2005. n-Hexane; CASRN 110-54-3. Integrated risk information system: Chemical assessment summary. Washington, DC: U.S. Environmental Protection Agency. https://iris.epa.gov/static/pdfs/0486_summary.pdf. January 30, 2023.
Ishidate M, Sofuni T, Yoshikawa K, . 1984. Primary mutagenicity screening of food additives currently used in Japan. Food Chem Toxicol 22(8):623–636. 10.1016/0278-6915(84)90271-0.6381265
Isidorov VA, Zenkevich IG, Ioffe BV. 1985. Volatile organic compounds in the atmosphere of forest. Atmos Environ 19(1):1–8. 10.1016/0004-6981(85)90131-3.
Issever H, Malat G, Sabuncu HH, . 2002. Impairment of colour vision in patients with n-hexane exposure-dependent toxic polyneuropathy. Occup Med 52(4):183–186. 10.1093/occmed/52.4.183.
Ithnin A, Shaari RAH, Sahani M, . 2011. Effects of pollutant diesel fuels on neurobehavioral performance among workers in locomotive depot. Am J Environ Sci 7(3):248–253. 10.3844/ajessp.2011.248.253.
Iyadomi M, Ichiba M, Zhang J, . 2000. Evaluation of skin irritants caused by organic solvents by means of the mouse ear thickness measurement method. J Occup Health 42(1):44–46. 10.1539/joh.42.44.
Jackson JR, deKechoue G, Karakaya A. 1997. Letter to the editor [Changes in immunoglobulin concentrations and urinary 2,5-hexanedione concentrations]. Hum Exp Toxicol 16(5):284–285. 10.1177/096032719701600511.9192211
Johnson DJ, Lack L, Ibrahim S, . 1995. Protein-bound pyrroles in rat hair following subchronic intraperitoneal injections of 2,5-hexanedione. J Toxicol Environ Health 45(3):313–324. 10.1080/15287399509531998.7609005
Jørgensen NK, Cohr KH. 1981. n-Hexane and its toxicologic effects: a review. Scand J Work Environ Health 7(3):157–168. 10.5271/sjweh.3107.20120580
Juarez-Perez CA, Torres-Valenzuela A, Haro-Garcia LC, . 2014. Ototoxicity effects of low exposure to solvent mixture among paint manufacturing workers. Int J Audiol 53(6):370–376. 10.3109/14992027.2014.888597.24684406
Kanatharana P, Chindarasamee C, Kaewnarong B. 1993. Extracting solvents for pesticide residues. J Environ Sci Health 28(10):2323–2332. 10.1080/10934529309376012.
Kanavouras K, Tzatzarakis MN, Mastorodemos V, . 2011. A case report of motor neuron disease in a patient showing significant level of DDTs, HCHs and organophosphate metabolites in hair as well as levels of hexane and toluene in blood. Toxicol Appl Pharmacol 256(3):399–404. 10.1016/j.taap.2011.07.022.21851830
Karakaya A, Yucesoy B, Burgaz S, . 1996. Some immunological parameters in workers occupationally exposed to n-hexane. Hum Exp Toxicol 15(1):56–58. 10.1177/096032719601500110.8845211
Kim IH, Yoon SH. 1990. Effect of extraction solvents on oxidative stability of crude soybean oil. J Am Oil Chem Sot 67(3):165–167. 10.1007/BF02539618.
Kimura ET, Ebert DM, Dodge PW. 1971. Acute toxicity and limits of solvent residue for sixteen organic solvents. Toxicol Appl Pharmacol 19(4):699–704. 10.1016/0041-008x(71)90301-2.5132037
Kopczynski SL, Lonneman WA, Sutterfield FD, . 1972. Photochemistry of atmospheric samples in Los Angeles. Environ Sci Technol 6(4):342–347. 10.1021/es60063a005.
Krasavage WJ, O’Donoghue JL, DiVincenzo GD, . 1980. The relative neurotoxicity of methyl-n-butyl ketone, n-hexane and their metabolites. Toxicol Appl Pharmacol 52(3):433–441. 10.1016/0041-008x(80)90338-5.7368216
Ladefoged O, Perbellini L. 1986. Acetone-induced changes in the toxicokinetics of 2,5-hexanedione in rabbits. Scand J Work Environ Health 12(6):627–629. 10.5271/sjweh.2092.3823813
Ladefoged O, Hass U, Simonsen L. 1989. Neurophysiological and behavioural effects of combined exposure to 2,5-hexanedione and acetone or ethanol in rats. Pharmacol Toxicol 65(5):372–375. 10.1111/j.1600-0773.1989.tb01191.x.2622868
Ladefoged O, Roswall K, Larsen JJ. 1994. Acetone potentiation and influence on the reversibility of 2,5-hexanedione-induced neurotoxicity studied with behavioural and morphometric methods in rats. Pharmacol Toxicol 74(4–5):294–299. 10.1111/j.1600-0773.1994.tb01114.x.8090702
Lam CW, Galen TJ, Boyd JF, . 1990. Mechanism of transport and distribution of organic solvents in blood. Toxicol Appl Pharmacol 104(1):117–129. 10.1016/0041-008x(90)90287-5.2360202
Lapadula DM, Irwin RD, Suwita E, . 1986. Cross-linking of neurofilament proteins of rat spinal cord in vivo after administration of 2,5-hexanedione. J Neurochem 46(6):1843–1850. 10.1111/j.1471-4159.1986.tb08503.x.3084709
Latimer JS, Hoffman EJ, Hoffman G, . 1990. Sources of petroleum hydrocarbons in urban runoff. Water Air Soil Pollut 52:1–21. 10.1007/BF00283111.
Lawson H. 1995. Processing technology. In: Food oils and fats: Technology, utilization, and nutrition. New York, NY: Springer, 49–65. 10.1007/978-1-4757-2351-9.
Leahy JG, Colwell RR. 1990. Microbial degradation of hydrocarbons in the environment. Microbiol Rev 54(3):305–315. 10.1128/mr.54.3.305-315.1990.2215423
Leeder JS, Kearns GL. 1997. Pharmacogenetics in pediatrics. Implications for practice. Pediatr Clin North Am 44(1):55–77. 10.1016/s0031-3955(05)70463-6.9057784
Lehman EJ, Hein MJ. 2006. Mortality of workers employed in shoe manufacturing: an update. Am J Ind Med 49(7):535–546. 10.1002/ajim.20322.16732556
Lehmann I, Thoelke A, Rehwagen M, . 2002. The influence of maternal exposure to volatile organic compounds on the cytokine secretion profile of neonatal T cells. Environ Toxicol 17(3):203–210. 10.1002/tox.10055.12112628
Li H, Liu J, Sun Y, . 2014. N-hexane inhalation during pregnancy alters DNA promoter methylation in the ovarian granulosa cells of rat offspring. J Appl Toxicol 34(8):841–856. 10.1002/jat.2893.23740543
Li H, Zhang C, Ni F, . 2015. Gestational n-hexane inhalation alters the expression of genes related to ovarian hormone production and DNA methylation states in adult female F1 rat offspring. Toxicol Lett 239(3):141–151. 10.1016/j.toxlet.2015.09.018.26410608
Li X, Wang Q, Li M, . 2018. Hair pyrrole adducts serve as biomarkers for peripheral nerve impairment induced by 2,5-hexanedione and n-hexane in rats. PLoS One 13(12):e0209939. 10.1371/journal.pone.0209939.30596762
Li X, Yu T, Wang S, . 2020a. Diallyl sulfide-induced attenuation of n-hexane-induced peripheral nerve impairment is associated with metabolic inhibition of n-hexane. Food Chem Toxicol 137:111167. 10.1016/j.fct.2020.111167.32007468
Li X, Jiang L, Yu T, . 2020b. No-observed-adverse-effect level of hair pyrrole adducts in chronic n-hexane intoxication in rats. Neurotoxicology 78:11–20. 10.1016/j.neuro.2020.02.002.32045579
Lide DR. 2005. Hexane. In: CRC handbook of chemistry and physics. 74^th^ ed. Boca Raton, FL: CRC Press Inc., 3–308.
Linder RE, Strader LF, Slott VL, . 1992. Endpoints of spermatotoxicity in the rat after short duration exposures to fourteen reproductive toxicants. Reprod Toxicol 6(6):491–505. 10.1016/0890-6238(92)90034-q.1288759
Liu J, Huang HL, Pang F, . 2012. The effect of n-hexane on the gonad toxicity of female mice. Biomed Environ Sci 25(2):189–196. 10.3967/0895-3988.2012.02.010.22998826
Loden M. 1986. The in vitro permeability of human skin to benzene, ethylene glycol, formaldehyde, and n-hexane. Acta Pharmacol Toxicol (Copenh) 58(5):382–389. 10.1111/j.1600-0773.1986.tb00126.x.3739733
Lungarella G, Barni-Comparini I, Fonzi L. 1984. Pulmonary changes induced in rabbits by long-term exposure to n-hexane. Arch Toxicol 55(4):224–228. 10.1007/BF00341015.6517698
Lyman WJ, Reehl WF, Rosenblatt DH. 1982. Rate of hydrolysis. In: Handbook of chemical property estimation methods: Environmental behavior of organic compound. New York, NY: McGraw-Hill Book Company, 7–1 to 7–48.
Marks TA, Fisher PW, Staples RE. 1980. Influence of n-hexane on embryo and fetal development in mice. Drug Chem Toxicol 3(4):393–406. 10.3109/01480548009030128.7215199
Mathews JM, Raymer JH, Etheridge AS, . 1997. Do endogenous volatile organic chemicals measured in breath reflect and maintain CYP2E1 levels in vivo? Toxicol Appl Pharmacol 146(2):255–260. 10.1006/taap.1997.8257.9344893
Mayan O, Teixeira JP, Pires AF. 2001. Biological monitoring of n-hexane exposure in Portuguese shoe manufacturing workers. Appl Occup Environ Hyg 16(7):736–741. 10.1080/10473220116711.11458920
Mayan O, Teixeira JP, Alves S, . 2002. Urinary 2,5 hexanedione as a biomarker of n-hexane exposure. Biomarkers 7(4):299–305. 10.1080/13547500210136796.12171757
Mayer VW, Goin CJ. 1994. Induction of chromosome loss in yeast by combined treatment with neurotoxic hexacarbons and monoketones. Mutat Res 341(2):83–91. 10.1016/0165-1218(94)90090-6.7527491
McCann MF. 1992. Occupational and environmental hazards in art. Environ Res 59(1):139–144. 10.1016/s0013-9351(05)80233-6.1425504
McCarroll NE, Keech BH, Piper CE. 1981a. A microsuspension adaptation of the Bacillus subtilis “ret” assay. Environ Mutagen 3(6):607–616. 10.1002/em.2860030603.
McCarroll NE, Piper CE, Keech BH. 1981b. An E coli microsuspension assay for the detection of DNA damage induced by direct-acting agents and promutagens. Environ Mutagen 3(4):429–444. 10.1002/em.2860030404.7021147
McClay K, Streger SH, Steffan RJ. 1995. Induction of toluene oxidation activity in Pseudomonas mendocina KRl and Pseudomonas sp. Strain ENVPCS by chlorinated solvents and alkanes. Appl Environ Microbial 61(9):3479–3481. 10.1128/aem.61.9.3479-3481.1995.
McKay WA, Turner MF, Jones BMR, . 1996. Emission of hydrocarbons from marine phytoplankton - Some results from controlled laboratory experiments. Atmos Environ 30(14):2583–2593. 10.1016/1352-2310(95)00433-5.
Mendola P, Wallace M, Liu D, . 2016. Air pollution exposure and preeclampsia among US women with and without asthma. Environ Res 148:248–255. 10.1016/j.envres.2016.04.004.27085496
Montgomery JH. 1991. n-Hexane. In: Groundwater chemicals desk reference. Vol. 2. Ann Arbor: Lewis Publisher, 570–572.
Morgenroth E, Schroeder ED, Chang DP, . 1996. Nutrient limitation in a compost biofilter degrading hexane. J Air Waste Manag Assoc 46(4):300–308. 10.1080/10473289.1996.10467464.28079480
Mortelmans K, Haworth S, Lawlor T, . 1986. Salmonella mutagenicity tests: II. Results from the testing of 270 chemicals. Environ Mutagen 8(Suppl 7):1–119. 10.1002/em.2860080703.3516675
Mortensen B, Nilsen OG. 1998. Allometric species comparison of toluene and n-hexane metabolism: prediction of hepatic clearance in man from experiments with rodent liver S9 in a head space vial equilibration system. Pharmacol Toxicol 82(4):183–188. 10.1111/j.1600-0773.1998.tb01422.x.9584332
Moschonas N, Glavas S. 1996. C_3_-C_10_ Hydrocarbons in the atmosphere of Athens, Greece. Atmos Environ 30(15):2769–7272. 10.1016/1352-2310(95)00488-2.
Mumtaz MM, Ray M, Crowell SR, . 2012a. Translational research to develop a human PBPK models tool kit-volatile organic compounds (VOCs). J Toxicol Environ Health A 75(1):6–24. 10.1080/15287394.2012.625546.22047160
Mumtaz M, Fisher J, Blount B, . 2012b. Application of physiologically based pharmacokinetic models in chemical risk assessment. J Toxicol 2012:904603. 10.1155/2012/904603.22523493
Murata K, Araki S, Yokoyama K, . 1994. Changes in autonomic function as determined by ECG R-R interval variability in sandal, shoe and leather workers exposed to n-hexane, xylene and toluene. Neurotoxicology 15(4):867–875.7715857
Mustajbegovic J, Zuskin E, Schachter EN, . 2000. Respiratory findings in chemical workers exposed to low concentrations of organic and inorganic air pollutants. Am J Ind Med 38(4):431–440. 10.1002/1097-0274(200010)38:4<431::aid-ajim9>3.0.co;2-q.10982984
Mutti A, Cavatorta A, Lommi G, . 1982a. Neurophysiological effects of long-term exposure to hydrocarbon mixtures. Arch Toxicol Suppl 5:120–124. 10.1007/978-3-642-68511-8_22.6954890
Mutti A, Ferri F, Lommi G, . 1982b. n-Hexane-induced changes in nerve conduction velocities and somatosensory evoked potentials. Int Arch Occup Environ Health 51(1):45–54. 10.1007/BF00378409.7152701
Mutti A, Falzoi M, Lucertini S, . 1984. n-Hexane metabolism in occupationally exposed workers. Br J Ind Med 41(4):533–538. 10.1136/oem.41.4.533.6498115
Nakajima T, Elovaara E, Park SS, . 1991. Immunochemical detection of cytochrome P450 isozymes induced in rat liver by n-hexane, 2-hexanone and acetyl acetone. Arch Toxicol 65:542–547. 10.1007/BF01973714.1781736
NAS/NRC. 2006. Human biomonitoring for environmental chemicals. Washington, DC: National Academy of Sciences/National Research Council. National Academy Press. 10.17226/11700.
Neghab M, Soleimani E, Khamoushian K. 2012. Electrophysiological studies of shoemakers exposed to sub-TLV levels of n-hexane. J Occup Health 54(5):376–382. 10.1539/joh.12-0029-fs.22863898
Neligan RE. 1962. Hydrocarbons in the Los Angeles atmosphere. A comparison between the hydrocarbons in automobile exhaust and those found in the Los Angeles atmosphere. Arch Environ Health 5:581–591. 10.1080/00039896.1962.10663334.13938007
Nelson KW, Ege JF, Ross M, . 1943. Sensory response to certain industrial solvent vapors. J Ind Hyg Toxicol 25:282–285.
NFPA. 1991. Hexane. In: Fire protection guide to hazardous materials. 10^th^ ed. Quincy, MA: National Fire Protection Association, 325M-58.
NIEHS. 1987. Inhalation developmental toxicology studies: Teratology study of n-hexane in rats: Final report. Washington, DC: National Institute of Environmental Health Sciences. DE88006812. PNL-645. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/DE88006812.xhtml. October 20, 2022.
NIEHS. 1988a. Inhalation reproductive toxicology studies: Sperm morphology study of n-hexane in B6C3F1 mice. Washington, DC: National Institute of Environmental Health Sciences. DE89000262. PNL-667. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/DE89000262.xhtml. October 20, 2022.
NIEHS. 1988b. Inhalation reproductive toxicology studies: Male dominant lethal study of n-hexane in Swiss (CD-1) mice. Washington, DC: National Institute of Environmental Health Sciences. DE89000271. PNL-667. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/DE89000271.xhtml. October 20, 2022.
NIEHS. 1988c. Inhalation developmental toxicology studies: Teratology study of n-hexane in mice. Washington, DC: National Institute of Environmental Health Sciences. PB2003107682. PNL-6590. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB2003107682.xhtml. October 20, 2022.
Nijem K, Kristensen P, al-Khatib A, . 2000. Prevalence of self-reported health complaints among shoe workers of small workshop exposed to organic solvents in Hebron City, West Bank: A cross-sectional survey. Med Lav 91(3):206–216.10965669
Nijem K, Kristensen P, Al-Khatib A, . 2001. Prevalence of neuropsychiatric and mucous membrane irritation complaints among Palestinian shoe factory workers exposed to organic solvents and plastic compounds. Am J Ind Med 40(2):192–198. 10.1002/ajim.1087.11494347
NIOSH. 1994. Hexane. Immediately dangerous to life or health concentrations (IDLH). National Institute of Occupational Safety and Health. https://www.cdc.gov/niosh/idlh/110543.html. October 14, 2024.
NIOSH. 2019. n-Hexane. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health. RTECS No. MN9275000. https://www.cdc.gov/niosh/npg/npgd0322.html. January 30, 2023.
NLM. 2023. n-Hexane. PubChem. U.S. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/8058. February 20, 2023.
Nobles CJ, Williams A, Ouidir M, . 2019. Differential effect of ambient air pollution exposure on risk of gestational hypertension and preeclampsia. Hypertension 74(2):384–390. 10.1161/HYPERTENSIONAHA.119.12731.31230552
NTP. 1991. Toxicity studies of n-hexane in B6C3F1 (inhalation studies). Research Triangle Park, NC: National Toxicology Program. PB91185322. NIH Publication No. 91–3121 https://ntp.niehs.nih.gov/ntp/htdocs/st_rpts/tox002.pdf. July 25, 2022.
NTP. 2013. Draft OHAT approach for systematic review and evidence integration for literature-based health assessments - February 2013. National Toxicology Program. https://ntp.niehs.nih.gov/ntp/ohat/evaluationprocess/draftohatapproach_february2013.pdf. February 20, 2023.
NTP. 2015. OHAT risk of bias rating tool for human and animal studies. National Toxicology Program. https://ntp.niehs.nih.gov/ntp/ohat/pubs/riskofbiastool_508.pdf. March 19, 2019.
NTP. 2021. CASRN index. Report on carcinogens. 15^th^ ed. National Toxicology Program. https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html#P. January 10, 2022.
Nylen P, Hagman M. 1994. Function of the auditory and visual systems, and of peripheral nerve, in rats after long-term combined exposure to n-hexane and methylated benzene derivatives. II. Xylene. Pharmacol Toxicol 74(2):124–129. 10.1111/j.1600-0773.1994.tb01086.x.8190700
Nylen P, Ebendal T, Eriksdotter-Nilsson M, . 1989. Testicular atrophy and loss of nerve growth factor-immunoreactive germ cell line in rats exposed to n-hexane and a protective effect of simultaneous exposure to toluene or xylene. Arch Toxicol 63(4):296–307. 10.1007/BF00278643.2764718
Nylen P, Hagman M, Johnson AC. 1994. Function of the auditory and visual systems, and of peripheral nerve, in rats after long-term combined exposure to n-hexane and methylated benzene derivatives. I. Toluene. Pharmacol Toxicol 74(2):116–123. 10.1111/j.1600-0773.1994.tb01085.x.8190699
O’Leary P, Walsh P. 1995. Landfill gas: Movement, control, and uses. Waste Age 17(4):114–123.
Ong CN, Koh D, Foo SC, . 1993. Volatile organic solvents in correction fluids: identification and potential hazards. Bull Environ Contam Toxicol 50(6):787–793. 10.1007/BF00209939.8495053
Ono Y, Takeuchi Y, Hisanaga N. 1981. A comparative study on the toxicity of n-hexane and its isomers on the peripheral nerve. Int Arch Occup Environ Health 48(3):289–294. 10.1007/BF00405616.7251182
OSHA. 2010. Organic vapor sampling group 1 (OVSG-1): Carbon disulfide-extracted analytes collected on coconut charcoal sorbent tubes. Occupational Safety and Health Administration. OSHA Method 5000. https://www.osha.gov/sites/default/files/methods/5000.pdf. November 28, 2023.
OSHA. 2023a. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z-2. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. https://www.govinfo.gov/content/pkg/CFR-2023-title29-vol6/pdf/CFR-2023-title29-vol6-sec1910-1000.pdf. September 13, 2024.
OSHA. 2023b. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. https://www.govinfo.gov/content/pkg/CFR-2023-title29-vol7/pdf/CFR-2023-title29-vol7-sec1915-1000.pdf. September 13, 2024.
OSHA. 2023c. Safety and health regulations for construction. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55. https://www.govinfo.gov/content/pkg/CFR-2023-title29-vol8/pdf/CFR-2023-title29-vol8-sec1926-55.pdf. September 13, 2024.
Otson R, Fellin P, Tran Q. 1994. VOCs in representative Canadian residences. Atmos Environ 28(22):3563–3569. 10.1016/1352-2310(94)00201-U.
Paciencia I, Cavaleiro Rufo J, Silva D, . 2019. Exposure to indoor endocrine disrupting chemicals and childhood asthma and obesity. Allergy 74(7):1277–1291. 10.1111/all.13740.30740706
Paciencia I, Cavaleiro Rufo J, Silva D, . 2020. Effects of indoor endocrine-disrupting chemicals on childhood rhinitis. J Investig Allergol Clin Immunol 30(3):195–197. 10.18176/jiaci.0471.
Park JB, Lee KJ, Lee KW, . 2009. Neurotoxic effect of occupational exposure to mixed organic solvents in Korea: posturographic study. Am J Ind Med 52(5):429–437. 10.1002/ajim.20679.19212948
Pastore C, Marhuenda D, Marti J, . 1994. Early diagnosis of n-hexane-caused neuropathy. Muscle Nerve 17(9):981–986. 10.1002/mus.880170904.8065400
Pastore C, Izura V, Marhuenda D, . 2002. Partial conduction blocks in n-hexane neuropathy. Muscle Nerve 26(1):132–135. 10.1002/mus.10183.12115958
Patten CJ, Ning SM, Lu AY, . 1986. Acetone-inducible cytochrome P-450: purification, catalytic activity, and interaction with cytochrome b5. Arch Biochem Biophys 251(2):629–638. 10.1016/0003-9861(86)90373-5.3800390
Paulson GW, Waylonis GW. 1976. Polyneuropathy due to n-hexane. Arch Intern Med 136(8):880–882. 10.1001/archinte.1976.03630080022008.182098
Pellizzari ED, Hartwell TD, Harris BS, . 1982. Purgeable organic compounds in mother’s milk. Bull Environ Contam Toxicol 28(3):322–328. 10.1007/BF01608515.7082873
PennWell. 1994. Motor gasoline produced from n-hexane fraction. In: Energy statistics sourcebook. 9^th^ ed. Tulsa, OK: PennWell Publishing Company, 297–342.
Perbellini L, Brugnone F, Faggionato G. 1981. Urinary excretion of the metabolites of n-hexane and its isomers during occupational exposure. Br J Ind Med 38(1):20–26. 10.1136/oem.38.1.20.7470400
Perbellini L, Brugnone F, Caretta D, . 1985. Partition coefficients of some industrial aliphatic hydrocarbons (C5-C7) in blood and human tissues. Br J Ind Med 42(3):162–167. 10.1136/oem.42.3.162.3970880
Perbellini L, Mozzo P, Brugnone F, . 1986. Physiologicomathematical model for studying human exposure to organic solvents: kinetics of blood/tissue n-hexane concentrations and of 2,5-hexanedione in urine. Br J Ind Med 43(11):760–768. 10.1136/oem.43.11.760.3790456
Perbellini L, Marhuenda Amoros DM, Cardona Llorens AC, . 1990a. An improved method of analysing 2,5-hexanedione in urine. Br J Ind Med 47(6):421–424. 10.1136/oem.47.6.421.2378820
Perbellini L, Mozzo P, Olivato D, . 1990b. “Dynamic” biological exposure indexes for n-hexane and 2,5-hexanedione, suggested by a physiologically based pharmacokinetic model. Am Ind Hyg Assoc J 51(7):356–362. 10.1080/15298669091369781.2382638
Perbellini L, Pezzoli G, Brugnone F, . 1993. Biochemical and physiological aspects of 2,5-hexanedione: endogenous or exogenous product? Int Arch Occup Environ Health 65(1):49–52. 10.1007/BF00586058.8354575
Periago JF, Cardona A, Marhuenda D, . 1993. Biological monitoring of occupational exposure to n-hexane by exhaled air analysis and urinalysis. Int Arch Occup Environ Health 65(4):275–278. 10.1007/BF00381203.8144240
Perocco P, Bolognesi S, Alberghini W. 1983. Toxic activity of seventeen industrial solvents and halogenated compounds on human lymphocytes cultured in vitro. Toxicol Lett 16(1–2):69–75. 10.1016/0378-4274(83)90012-7.6836616
Pezzoli G, Antonini A, Barbieri S, . 1995. n-Hexane-induced parkinsonism: pathogenetic hypotheses. Mov Disord 10(3):279–282. 10.1002/mds.870100308.7651443
Potter TL. 1993. Analysis of petroleum contaminated soil and water: An overview. In: Calabrese EJ, Kostecki PT, eds. Principles and practices for petroleum contaminated soils. Ann Arbor MI: Lewis Publishers, 1–14.
Pradhan S, Tandon R. 2015. N-hexane neuropathy with vertigo and cold allodynia in a silk screen printer: A case study. Int J Occup Med Environ Health 28(5):915–919. 10.13075/ijomeh.1896.00327.26224503
Pryor GT, Rebert CS. 1992. Interactive effects of toluene and hexane on behavior and neurophysiologic responses in Fischer-344 rats. Neurotoxicology 13(1):225–234.1508424
Pryor GT, Dickinson J, Howd RA, . 1983. Neurobehavioral effects of subchronic exposure of weanling rats to toluene or hexane. Neurobehav Toxicol Teratol 5(1):47–52.6856009
Puri V, Chaudhry N, Tatke M. 2007. N-hexane neuropathy in screen printers. Electromyogr Clin Neurophysiol 47(3):145–152.17557647
Pyle SJ, Amarnath V, Graham DG, . 1993. Decreased levels of the high molecular weight subunit of neurofilaments and accelerated neurofilament transport during the recovery phase of 2,5-hexanedione exposure. Cell Motil Cytoskeleton 26(2):133–143. 10.1002/cm.970260205.8287499
Raitta C, Seppalainen AN, Huuskonen MS. 1978. N-hexane maculopathy in industrial workers. Albrecht Von Graefes Arch Klin Exp Ophthalmol 209(2):99–110. 10.1007/BF00407843.311172
Rastogi SC. 1993. Organic solvent levels in model and hobby glues. Bull Environ Contam Toxicol 51(4):501–507. 10.1007/BF00192164.8400651
Raymer JH, Pellizzari ED. 1996. Estimation of recent exposures to volatile organic chemicals using alveolar air measurements. Toxicol Ind Health 12(2):201–210. 10.1177/074823379601200208.8794533
Rebert C, Sorenson SS. 1983. Concentration-related effects of hexane on evoked responses from brain and peripheral nerve of the rat. Neurobehav Toxicol Teratol 5(1):69–76.6856011
RePORTER. 2024. n-Hexane. Research Portfolio Online Reporting Tools. National Institutes of Health. https://reporter.nih.gov/. September 23, 2024.
Roberts NJ, Burton HR. 1994. Volatile compounds in meromictic Antarctic lakes and basins. Chemosphere 29(8):1627–1637. 10.1016/0045-6535(94)90310-7.
Roberts MT, Etherington D. 1996. Hexane. In: Bookbinding and the conservation of books: A dictionary of descriptive terminology. Menlo Park, CA: Stanford University, 131.
Robertson P, White EL, Bus JS. 1989. Effects of methyl ethyl ketone pretreatment on hepatic mixed-function oxidase activity and on in vivo metabolism of n-hexane. Xenobiotica 19(7):721–729. 10.3109/00498258909042310.2773508
Rooney AA, Boyles AL, Wolfe MS, . 2014. Systematic review and evidence integration for literature-based environmental health science assessments. Environ Health Perspect 122(7):711–718. 10.1289/ehp.1307972.24755067
Rosenberg E, Legmann R, Kushmaro A, . 1992. Petroleum bioremediation - a multiphase problem. Biodegradation 3(2–3):337–350. 10.1007/bf00129092.
Ruiz P, Ray M, Fisher J, . 2011. Development of a human Physiologically Based Pharmacokinetic (PBPK) Toolkit for environmental pollutants. Int J Mol Sci 12(11):7469–7480. 10.3390/ijms12117469.22174611
Ruiz-García L, Figueroa-Vega N, Malacara JM, . 2020. Possible role of n-hexane as an endocrine disruptor in occupationally exposed women at reproductive age. Toxicol Lett 330:73–79. 10.1016/j.toxlet.2020.04.022.32439582
Sack TM, Steele DH, Hammerstrom K, . 1992. A survey of household products for volatile organic compounds. Atmos Environ 26A(6):1063–1070. 10.1016/0960-1686(92)90038-M.
Sallmen M, Neto M, Mayan ON. 2008. Reduced fertility among shoe manufacturing workers. Occup Environ Med 65(8):518–524. 10.1136/oem.2007.032839.17989205
Sanagi S, Seki Y, Sugimoto K, . 1980. Peripheral nervous system functions of workers exposed to n-hexane at a low level. Int Arch Occup Environ Health 47(1):69–79. 10.1007/BF00378330.6253405
Sauer TC, Sackett WM, Jeffrey LM. 1978. Volatile liquid hydrocarbons in the surface coastal waters of the Gulf of Mexico. Mar Chem 7(1):1–16. 10.1016/0304-4203(78)90039-7.
Sauer TC, Brown JS, Boehm PD, . 1993. Hydrocarbon source identification and weathering characterization of intertidal and subtidal sediments along the Saudi Arabian coast after the Gulf War Oil Spill. Mar Pollut Bull 27:117–134. 10.1016/0025-326X(93)90016-D.
Schaumburg HH, Spencer PS. 1976. Degeneration in central and peripheral nervous systems produced by pure n-hexane: an experimental study. Brain 99(2):183–192. 10.1093/brain/99.2.183.186151
Sendur OF, Turan Y, Bal S, . 2009. Toxic neuropathy due to n-hexane: report of three cases. Inhal Toxicol 21(3):210–214. 10.1080/08958370802311169.18991102
Seppalainen AM, Raitta C, Huuskonen MS. 1979. n-Hexane-induced changes in visual evoked potentials and electroretinograms of industrial workers. Electroencephalogr Clin Neurophysiol 47(4):492–498. 10.1016/0013-4694(79)90165-2.89953
Shaw DG, Hogan TE, McIntosh DJ. 1986. Hydrocarbons in the sediments of Port Valdez, Alaska: Consequences of five years’ permitted discharge. Estuar Coast Shelf Sci 21:131–144. 10.1016/0272-7714(85)90093-9.
Shibata E, Johanson G, Löf A, . 2002. Changes in n-hexane toxicokinetics in short-term single exposure due to co-exposure to methyl ethyl ketone in volunteers. Int Arch Occup Environ Health 75(6):399–405. 10.1007/s00420-002-0325-5.12070636
Sliwinska-Kowalska M, Zamyslowska-Szmytke E, Szymczak W, . 2005. Exacerbation of noise-induced hearing loss by co-exposure to workplace chemicals. Environ Toxicol Pharmacol 19(3):547–553. 10.1016/j.etap.2004.12.018.21783525
Smith AG, Albers JW. 1997. n-Hexane neuropathy due to rubber cement sniffing. Muscle Nerve 20(11):1445–1450. 10.1002/(sici)1097-4598(199711)20:11<1445::aidmus13>3.0.co;2-0.9342162
Sobue T, Iida M, Yamamura Y, . 1978. n-Hexane polyneuropathy. Int J Neurol 11(4):317–330.232498
Speight JG. 2006. Introduction to refining processes. In: The chemistry and technology of petroleum. 2^nd^ ed. New York, NY: M. Dekker, 430–431.
Spencer PS, Schaumburg HH. 1977a. Ultrastructural studies of the dying-back process. III. The evolution of experimental peripheral giant axonal degeneration. J Neuropathol Exp Neurol 36(2):276–299. 10.1097/00005072-197703000-00005.190357
Spencer PS, Schaumburg HH. 1977b. Ultrastructural studies of the dying-back process. IV. Differential vulnerability of PNS and CNS fibers in experimental central-peripheral distal axonopathies. J Neuropathol Exp Neurol 36(2):300–320. 10.1097/00005072-197703000-00006.190358
Spencer PS, Schaumburg HH, Sabri MI, . 1980. The enlarging view of hexacarbon neurotoxicity. Crit Rev Toxicol 7(4):279–356. 10.3109/10408448009037489.7002473
Srinivas H, Swamylingappa B, Chand N. 1992. Secondary extraction of soybeans using hexane-acetic acid: Effect on beany flavor removal and physiochemical properties. J Agric Food Chem 40:276–279. 10.1021/jf00014a022.
Stelljes ME, Watkin GE. 1993. Comparison of environmental impacts posed by different hydrocarbon mixtures: A need for site-specific composition analyses. In: Kostecki PT, Calabrese EJ, eds. Hydrocarbon contaminated soils and groundwater. Vol. 3. Chelsea MI: Lewis Publishers, 549–569.
Stevens P. 1988. Refining. In: Oil and gas dictionary. New York, NY: Nichols Publishing, 174–178.
Stoltenburg-Didinger G, Altenkirch H, Wagner M. 1990. Neurotoxicity of organic solvent mixtures: embryotoxicity and fetotoxicity. Neurotoxicol Teratol 12(6):585–589. 10.1016/0892-0362(90)90066-l.2255301
Sun Y, Wu X, Chen J, . 2020. The effect of rehabilitation in patients with polyneuropathy induced by occupational intoxication with n-hexane: a report of 9 cases. Ann Palliat Med 9(6):4179–4186. 10.21037/apm-20-2176.33302679
Sundell J. 1996. What we know, and don’t know, about sick building syndrome. ASHRAE Journal 38(6):51–57.
Swann RL, Laskowski DA, McCall PJ, . 1983. A rapid method for the estimation of the environmental parameters octanol/water partition coefficient, soil sorption constant, water to air ratio, and water solubility. Res Rev 85:17–28. 10.1007/978-1-4612-5462-1_3.
Sweeney LM, Gearhart JM. 2020. Examples of physiologically based pharmacokinetic modeling applied to risk assessment. In: Fisher JW, Gearhart JM, Lin Z, eds. Physiologically based pharmacokinetic (PBPK) modeling. Academic Press: 281–299. 10.1016/B978-0-12-818596-4.00011-4.
Takeuchi Y, Ono Y, Hisanaga N, . 1980. A comparative study on the neurotoxicity of n-pentane, n-hexane, and n-heptane in the rat. Br J Ind Med 37(3):241–247. 10.1136/oem.37.3.241.7426474
Takeuchi Y, Ono Y, Hisanaga N, . 1983. An experimental study of the combined effects of n-hexane and methyl ethyl ketone. Br J Ind Med 40(2):199–203. 10.1136/oem.40.2.199.6830718
Takeuchi Y, Hisanaga N, Ono Y, . 1993. Modification of metabolism and neurotoxicity of hexane by co-exposure of toluene. Int Arch Occup Environ Health 65(1 Suppl):S227–230. 10.1007/BF00381347.8406932
Talbott EO, Marshall LP, Rager JR, . 2015. Air toxics and the risk of autism spectrum disorder: the results of a population based case-control study in southwestern Pennsylvania. Environ Health 14:80. 10.1186/s12940-015-0064-1.26444407
Tan YM, Chan M, Chukwudebe A, . 2020. PBPK model reporting template for chemical risk assessment applications. Regul Toxicol Pharmacol 115:104691. 10.1016/j.yrtph.2020.104691.32502513
Thulasirajah S, Michaud J, Doja A, . 2020. Inhaled solvent abuse mimicking chronic inflammatory demyelinating polyradiculoneuropathy. Child Neurol Open 7:2329048x20934914. 10.1177/2329048x20934914.
Toftgard R, Halpert J, Gustafsson JA. 1983. Xylene induces a cytochrome P-450 isozyme in rat liver similar to the major isozyme induced by phenobarbital. Mol Pharmacol 23(1):265–271.6865901
Toftgard R, Haaparanta T, Eng L, . 1986. Rat lung and liver microsomal cytochrome P-450 isozymes involved in the hydroxylation of n-hexane. Biochem Pharmacol 35(21):3733–3738. 10.1016/0006-2952(86)90658-1.3778502
Tomei F, Giuntoli P, Biagi M, . 1999. Liver damage among shoe repairers. Am J Ind Med 36(5):541–547. 10.1002/(sici)1097-0274(199911)36:5<541::aid-ajim6>3.0.co;2-4.10506736
TRI23. 2024. n-Hexane. TRI search. Washington, DC: U.S. Environmental Protection Agency. https://www.epa.gov/enviro/tri-search. October 21, 2024.
Tsai SY, Chen JD, Chao WY, . 1997. Neurobehavioral effects of occupational exposure to low-level organic solvents among Taiwanese workers in paint factories. Environ Res 73(1–2):146–155. 10.1006/enrs.1997.3704.9311540
Tseng HW, Lu LY. 2024. Short-term impact of exposure to ambient air volatile organic compounds on daily clinic visits for urticaria in Kaohsiung, Taiwan. Asian Pac J Allergy Immunol:Online ahead of print. 10.12932/ap-270923-1701.
Umicevic N, Kotur-Stevuljevic J, Paleksic V, . 2022. Liver function alterations among workers in the shoe industry due to combined low-level exposure to organic solvents. Drug Chem Toxicol 45(4):1907–1914. 10.1080/01480545.2021.1894703.33715556
Valentino M. 1996. Residual electroneurographic modifications in subjects with n-hexane induced polyneuropathy: a follow-up study. Med Lav 87(4):289–296.8956541
van Engelen JG, Rebel-de Haan W, Opdam JJ, . 1997. Effect of coexposure to methyl ethyl ketone (MEK) on n-hexane toxicokinetics in human volunteers. Toxicol Appl Pharmacol 144(2):385–395. 10.1006/taap.1997.8149.9194423
Van Ert MD, Arp EW, Harris RL, . 1980. Worker exposures to chemical agents in the manufacture of rubber tires: solvent vapor studies. Am Ind Hyg Assoc J 41(3):212–219. 10.1080/15298668091424627.7395732
Vanacore N, Gasparini M, Brusa L, . 2000. A possible association between exposure to n-hexane and parkinsonism. Neurol Sci 21(1):49–52. 10.1007/s100720070118.10938202
Verberk MM, Brons JT, Salle HJ. 2004. Visual evoked potentials in workers with chronic solvent encephalopathy. Int Arch Occup Environ Health 77(5):328–334. 10.1007/s00420-004-0511-8.15133677
Verma DK, Shaw DS, McLean JD. 1992. An evaluation of airborne concentrations of selected hydrocarbons at an oil refinery land reclamation operation. Ann Occup Hyg 36(3):307–315. 10.1093/annhyg/36.3.307.
Veulemans H, Van Vlem E, Janssens H, . 1982. Experimental human exposure to n-hexane. Study of the respiratory uptake and elimination, and of n-hexane concentrations in peripheral venous blood. Int Arch Occup Environ Health 49(3–4):251–263. 10.1007/BF00377934.7068237
Veulemans H, Groeseneken D, Masschelein R, . 1987. Survey of ethylene glycol ether exposure in Belgian industries and workshops. Am Ind Hyg Assoc J 48(8):671–676. 10.1080/15298668791385390.3630916
Villeneuve PJ, Jerrett M, Su J, . 2013. A cohort study of intra-urban variations in volatile organic compounds and mortality, Toronto, Canada. Environ Pollut 183:30–39. 10.1016/j.envpol.2012.12.022.23369806
Wadden RA, Scheff PA, Franke JE, . 1995. VOC emission rates and emission factors for a sheetfed offset printing shop. Am Ind Hyg Assoc J 56(4):368–376. 10.1080/15428119591016999.7726102
Wahlberg JE. 1984. Erythema-inducing effects of solvents following epicutaneous administration to man-studied by laser Doppler flowmetry. Scand J Work Environ Health 10(3):159–162. 10.5271/sjweh.2351.6236553
Wahlberg JE, Boman A. 1979. Comparative percutaneous toxicity of ten industrial solvents in the guinea pig. Scand J Work Environ Health 5(4):345–351. 10.5271/sjweh.2647.538425
Wanasundara JPD, Shahidi F. 1994. Alkanol-ammonia-water/hexane extraction of flaxseed. Food Chem 49(1):39–44. 10.1016/0308-8146(94)90230-5.
Wang JD, Chang YC, Kao KP, . 1986. An outbreak of n-hexane induced polyneuropathy among press proofing workers in Taipei. Am J Ind Med 10(2):111–118. 10.1002/ajim.4700100202.3752095
Wang S, Li M, Wang X, . 2017. Diallyl trisulfide attenuated n-hexane induced neurotoxicity in rats by modulating P450 enzymes. Chem Biol Interact 265:1–7. 10.1016/j.cbi.2017.01.013.28115069
Watts JO, Holswade W. 1967. Gas chromatographic determination of residual hydrocarbon solvents in solvent-extracted edible oils. J AOAC Int 50(3):717–726. 10.1093/jaoac/50.3.717.
White EL, Bus JS, Heck HD. 1979. Simultaneous determination of n-hexane, 2-hexanone and 2,5-hexanedione in biological tissues by gas chromatography mass spectrometry. Biomed Mass Spectrom 6(4):169–172. 10.1002/bms.1200060408.385075
WHO. 1991. n-Hexane. Geneva, Switzerland: World Health Organization. Environmental Health Criteria 122. https://apps.who.int/iris/bitstream/handle/10665/41283/9241571225-eng.pdf?sequence=1&isAllowed=y. February 17, 2023.
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. World Health Organization. https://www.who.int/publications/i/item/9789289002134. September 13, 2024.
WHO. 2022. Guidelines for drinking-water quality. Fourth edition incorporating the first and second addenda. World Health Organization. https://www.who.int/publications/i/item/9789240045064. June 22, 2022.
Wichmann FA, Muller A, Busi LE, . 2009. Increased asthma and respiratory symptoms in children exposed to petrochemical pollution. J Allergy Clin Immunol 123(3):632–638. 10.1016/j.jaci.2008.09.052.19111332
Wilson MP, Hammond SK, Nicas M, . 2007. Worker exposure to volatile organic compounds in the vehicle repair industry. J Occup Environ Hyg 4(5):301–310. 10.1080/15459620701258021.17454499
Winer AM, Arey J, Atkinson R, . 1992. Emission rates of organics from vegetation in California’s Central Valley. Atmos Environ A Gen Top 26(14):2647–2659. 10.1016/0960-1686(92)90116-3.
Yamamura Y. 1969. n-Hexane polyneuropathy. Folia Psychiatr Neurol Jpn 23(1):45–57. 10.1111/j.1440-1819.1969.tb01441.x.5820368
Yin H, Zhang C, Guo Y, . 2014. Biological exposure indices of pyrrole adducts in serum and urine for hazard assessment of n-hexane exposure. PLoS One 9(1):e86108. 10.1371/journal.pone.0086108.24465904
Yokoyama K, Feldman RG, Sax DS, . 1990. Relation of distribution of conduction velocities to nerve biopsy findings in n-hexane poisoning. Muscle Nerve 13(4):314–320. 10.1002/mus.880130406.2355944
Yokoyama K, Araki S, Murata K, . 1997. Postural sway frequency analysis in workers exposed to n-hexane, xylene, and toluene: assessment of subclinical cerebellar dysfunction. Environ Res 74(2):110–115. 10.1006/enrs.1997.3769.9339223
Yu RC, Hattis D, Landaw EM, . 2002. Toxicokinetic interaction of 2,5-hexanedione and methyl ethyl ketone. Arch Toxicol 75(11–12):643–652. 10.1007/s00204-001-0298-2.11876497
Yücesoy B, Yücel A, Erdem O, . 1999. Effects of occupational chronic co-exposure to n-hexane, toluen, and methyl ethyl ketone on NK cell activity and some immunoregulatory cytokine levels in shoe workers. Hum Exp Toxicol 18(9):541–546. 10.1191/096032799678845115.10523867
Zhang Y, Liu Q, Liu Q, . 2006. Study on the damage of peripheral nerve in the workers exposed to n-hexane. Biomarkers 11(1):61–69. 10.1080/13547500500451176.16484137
Zhao W, Misumi J, Yasui T, . 1998. Effects of methyl ethyl ketone, acetone, or toluene coadministration on 2,5-hexanedione concentration in the sciatic nerve, serum, and urine of rats. Int Arch Occup Environ Health 71(4):236–244. 10.1007/s004200050275.9638479
Zhu X, Suidan MT, Pruden A, . 2004. Effect of substrate Henry’s constant on biofilter performance. J Air Waste Manag Assoc 54(4):409–418. 10.1080/10473289.2004.10470918.15115369
Zielinska B, Sagebiel JC, Harshfield G, . 1996. Volatile organic compounds up to C_20_ emitted from motor vehicles: Measurement methods. Atmos Environ 30(12):2269–2286. 10.1016/1352-2310(95)00116-6.