# CONTRIBUTORS & REVIEWERS

## CHEMICAL MANAGER TEAM

- Obaid Faroon, D.V.M., Ph.D. (Lead)
  Malcolm Williams, D.V.M., Ph.D.
  Rae T. Benedict, Ph.D.
  Melanie Buser, M.P.H.
  ATSDR, Office of Innovation and Analytics, Toxicology Section, Atlanta, GA

- Lisa Ingerman, Ph.D., D.A.B.T.
  Jessica L. Myers, Ph.D.
  Ramsey Hanna, Ph.D.
  SRC, Inc., North Syracuse, NY

## REVIEWERS

- Interagency Minimal Risk Level Workgroup:
  Includes ATSDR; National Center for Environmental Health (NCEH); National Institute for Occupational Safety and Health (NIOSH); U.S. Environmental Protection Agency (EPA); National Toxicology Program (NTP).
- Additional reviews for science and/or policy:
  ATSDR, Office of Community Health Hazard Assessment; ATSDR, Office of Capacity Development and Applied Prevention Science; ATSDR, Office of Science; NCEH, Division of Laboratory Sciences; NCEH, Division of Environmental Health Science and Practice; EPA, Office of Research and Development; EPA, Office of Water.

## PEER REVIEWERS

1. Chunping Yang, Ph.D., PE (Ohio), Professor; School of Environmental Science and Engineering; Guangdong University of Petrochemical Technology; Maoming, Guangdong 525000, China and College of Environmental Science and Engineering; Hunan University; Changsha, Hunan 410082, China.
2. Marina Oktapodas Feiler, Ph.D., M.S.; Assistant Professor; Principal Investigator, Pediatric Environmental Health and Development Studies (PEDS) Laboratory; Department of Epidemiology and Environmental Health; School of Public Health and Health Professions; University at Buffalo; Buffalo, New York.
3. Hermann M. Bolt, Ph.D.; Leibnix Research Centre for Working Environment and Human Factors at TU Dortmund (IfADo), Ardeystr. 67; 44579 Dortmund, Germany.

These experts collectively have knowledge of toxicology, chemistry, and/or health effects. All reviewers were selected in conformity with Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

ATSDR scientists review peer reviewers’ comments and determine whether changes will be made to the profile based on comments. The peer reviewers’ comments and responses to these comments are part of the administrative record for this compound.

The listing of peer reviewers should not be understood to imply their approval of the profile’s final content. The responsibility for the content of this profile lies with ATSDR.