# VERSION HISTORY

Date | Description
April 2025 | Final toxicological profile released
May 2024 | Draft for public comment toxicological profile released
July 1999 | Final toxicological profile released