# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding n-hexane in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for n-hexane.

Table 7-1 Regulations and Guidelines Applicable to n-Hexane

Agency | Description | Information | Reference
Air
EPA | RfC | 0.7 mg/m^3^ (0.2 ppm) | IRIS 2005
EPA | Provisional peer reviewed toxicity values
EPA | Provisional subchronic RfC | 2 mg/m^3^ (0.6 ppm) | EPA 2009
WHO | Air quality guidelines | No data | WHO 2010
Water & Food
EPA | Drinking water standards and health advisories | | EPA 2018a
| 1-Day health advisory (10-kg child) | 10 mg/L
| 10-Day health advisory (10-kg child) | 4 mg/L
| Lifetime health advisory | No data
| National primary drinking water regulations | Not listed | EPA 2023b
| RfD | Not assessed | IRIS 2005
| Provisional peer reviewed toxicity values | | EPA 2009
| Provisional subchronic RfD | 0.3 mg/kg/day
WHO | Drinking water quality guidelines | No data | WHO 2022
FDA | Substances added to food (formerly EAFUS) | Allowed as extractant in the preparation of several food/color additives, with restrictions on residue levels; allowed in some indirect food additives (particular coatings used in food packaging) | FDA 2024
Cancer
HHS | Carcinogenicity classification | Not evaluated | NTP 2021
EPA | Carcinogenicity classification | Inadequate information to assess carcinogenic potential | IRIS 2005
IARC | Carcinogenicity classification | Not evaluated | IARC 2024
Occupational
OSHA | PEL (8-hour TWA) for general industry, shipyards, and construction | 500 ppm (1800 mg/m³) | OSHA 2023a, 2023b, 2023c
NIOSH | REL (up to 10-hour TWA) | 50 ppm (180 mg/m³) | NIOSH 2019
| IDLH | 1,100 ppm^a^ | NIOSH 1994
Emergency Criteria
EPA | AEGLs-air | | EPA 2018b
| AEGL 1^b^
| 10-minute, 30-minute, 60-minute, 4-hour, 8-hour | No recommendation due to insufficient data
| AEGL 2^b^
| 10-minute | 4,000 ppm^c^
| 30-minute | 2,900 ppm^c^
| 60-minute | 2,900 ppm^c^
| 4-hour | 2,900 ppm^c^
| 8-hour | 2,900 ppm^c^
| AEGL 3^b^
| 10-minute | 12,000 ppm^d^
| 30-minute | 8,600 ppm^e^
| 60-minute | 8,600 ppm^e^
| 4-hour | 8,600 ppm^e^
| 8-hour | 8,600 ppm^e^
DOE | PACs-air | | DOE 2024a
| PAC-1^f^ | 260 ppm
| PAC-2^f^ | 2,900 ppm^c^
| PAC-3^f^ | 8,600 ppm^e^

a Based strictly on safety considerations; IDLH is 10% of LEL of n-hexane in air (11,000 ppm).

b Definitions of AEGL terminology are available from EPA (2018c).

c Value is greater than 10% of the LEL; safety considerations against explosion hazard must be taken into account.

d Value is greater than the LEL; extreme safety considerations against explosion hazard must be taken into account.

e Value is greater than 50% of the LEL; extreme safety considerations against explosion hazard must be taken into account.

f Definitions of PAC terminology are available from DOE (2024b).

AEGL = acute exposure guideline levels; DOE = Department of Energy; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; LEL = lower explosive limit; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TWA = time-weighted average; WHO = World Health Organization