# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

n-Hexane is a very volatile aliphatic hydrocarbon. It is a constituent in the paraffin fraction of crude oil and natural gas and is also used as an industrial chemical and laboratory solvent. Laboratory-grade n-hexane contains approximately 99% n-hexane. “Hexane” or “hexanes” is a commercial and industrial product consisting of a mixture of hydrocarbons with six carbon atoms and includes n-hexane and its isomers, 2-methylpentane and 3-methylpentane, as well as small amounts of other hydrocarbons (Brugnone et al. 1991). Laboratory and industrial solvents such as “hexane” and petroleum ether contain n-hexane from <0.1% to as much as 33% (Creaser et al. 1983). Information regarding the chemical identity of n-hexane is presented in Table 4-1.

Table 4-1 Chemical Identity of n-Hexane

Characteristic | Information | Reference
Chemical name | n-Hexane | Budavari et al. 1989
Synonym(s) and registered trade name(s) | Hexane; Hexyl hydride; Skellysolve B; Gettysolve-B | IUPAC name; NFPA 1991; NLM 2023 NLM 2023
Chemical formula | C_6_H_14_ | Lide 2005
SMILES | CCCCCC | NLM 2023
Chemical structure | CH_3_CH_2_CH_2_CH_2_CH_2_CH_3_
CAS Registry Number | 110-54-3 | NLM 2023

CAS = Chemical Abstracts Service; SMILES = simplified molecular-input line-entry system

Many commercial grades of n-hexane contain appreciable amounts of other hydrocarbons in addition to n-hexane (for instance, toluene or such solvents as acetone or MEK; see below for other chemicals in such mixtures). Various types of commercial grades of n-hexane are available, and the constituents besides n-hexane are usually an intentional part of the process for preparing these commercial mixtures. Where intended for specialized oil extraction or laboratory uses, the purity of the n-hexane products may be in the range of 95–99% n-hexane. For a variety of uses where purity is not as important, commercial n-hexane mixtures (in the range of 20–80% of n-hexane) may contain small amounts of chemicals such as acetone, MEK, dichloromethane, 2- or 3-methylpentane, 2,3-dimethylbutane, cyclohexane, methyl cyclopentane, trichloroethylene, aromatics such as toluene, and other types of petroleum hydrocarbons (Jørgensen and Cohr 1981; Takeuchi et al. 1993; WHO 1991). In commercial grades of n-hexane, some of the constituents are purposefully added as denaturants, often to discourage the misuse of the chemical to induce “highs” through sniffing or inhalation (Altenkirch et al. 1982).

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

The National Fire Protection Association (NFPA) has assigned n-hexane a health hazard identification code of 1 (slight) and flammability code of 3 (serious) (NFPA 1991). n-Hexane is flammable and may be ignited by heat, sparks, and flames. Flammable vapor may spread away from a spill. The vapor may be an explosion hazard. n-Hexane can react vigorously with oxidizing materials such as liquid chlorine, concentrated oxygen, and sodium hypochlorite. n-Hexane will attack some forms of plastics, rubber, and coatings. Virtually all n-hexane is obtained from petroleum mixtures through controlled fractional distillation and other refinery-based processes (Speight 2006). The presence of many types of hydrocarbon impurities in many commercial grades of n-hexane, combined with the intentional denaturing of n-hexane preparations to discourage substance misuse, make it difficult to establish odor thresholds for many products containing n-hexane. Information regarding the physical and chemical properties of n-hexane is presented in Table 4-2.

Table 4-2 Physical and Chemical Properties of n-Hexane

Property | Information | Reference
Molecular weight | 86.18 | Lide 2005
Color | Colorless | Budavari et al. 1989
Physical state | Liquid | Budavari et al. 1989
Melting point | -95°C | Lide 2005
Boiling point | 69°C | Lide 2005
Density at 20°C | 0.6606 g/cm^3^ | Lide 2005
Odor | Faint, peculiar odor | Budavari et al. 1989
Odor threshold:
Water | 0.0064 mg/L | Amoore and Hautala 1983
Air | 130 ppm | Amoore and Hautala 1983
Taste threshold | No data
Solubility:
Water | Insoluble; 9.5 mg/L | Budavari et al. 1989; NLM 2023
Organic solvent(s) | Miscible with alcohol, chloroform, ether | Budavari et al. 1989
Partition coefficients:
Log K_ow_ | 3.90, 2.90 | Coates et al. 1985;; Hansch et al. 1995
Vapor pressure | 138 mmHg at 24°C | Chiou et al. 1988
Henry’s law constant at 25°C | 1.003 atm-m^3^/mole; 1.3 atm-m^3^/mole | Ashworth et al. 1988; Zhu et al. 2004
Autoignition temperature | 225°C | NFPA 1991
Flashpoint | -22°C | NFPA 1991
Flammability limits | 1.1–7.5% | NFPA 1991
Explosive limits | 1.1–7.5% | WHO 1991
Conversion factors | 1 ppm = 3.52 mg/m^3^; 1 mg/m^3^ = 0.284 ppm | WHO 1991