# APPENDIX C FRAMEWORK FOR ATSDR’S SYSTEMATIC REVIEW OF HEALTH EFFECTS DATA FOR n-HEXANE

To increase the transparency of ATSDR’s process of identifying, evaluating, synthesizing, and interpreting the scientific evidence on the health effects associated with exposure to n-hexane, ATSDR utilized a slight modification of NTP’s Office of Health Assessment and Translation (OHAT) systematic review methodology (NTP 2013, 2015; Rooney et al. 2014). ATSDR’s framework is an eight-step process for systematic review with the goal of identifying the potential health hazards of exposure to n-hexane:

- Step 1. Problem Formulation
- Step 2. Literature Search and Screen for Health Effects Studies
- Step 3. Extract Data from Health Effects Studies
- Step 4. Identify Potential Health Effect Outcomes of Concern
- Step 5. Assess the Risk of Bias for Individual Studies
- Step 6. Rate the Confidence in the Body of Evidence for Each Relevant Outcome
- Step 7. Translate Confidence Rating into Level of Evidence of Health Effects
- Step 8. Integrate Evidence to Develop Hazard Identification Conclusions

## C.1 PROBLEM FORMULATION

The objective of the toxicological profile and this systematic review was to identify the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to n-hexane. The inclusion criteria used to identify relevant studies examining the health effects of n-hexane are presented in Table C-1.

Data from human and laboratory animal studies were considered relevant for addressing this objective. Human studies were divided into two broad categories: observational epidemiology studies and controlled exposure studies. The observational epidemiology studies were further divided: cohort studies (retrospective and prospective studies), population studies (with individual data or aggregate data), and case-control studies.

Table C-1 Inclusion Criteria for Identifying Health Effects Studies

Species
Human
Laboratory mammals
Route of exposure
Inhalation
Oral
Dermal (or ocular)
Parenteral (these studies will be considered supporting data)
Health outcome
Death
Systemic effects
Body weight effects
Respiratory effects
Cardiovascular effects
Gastrointestinal effects
Hematological effects
Musculoskeletal effects
Hepatic effects
Renal effects
Dermal effects
Ocular effects
Endocrine effects
Immunological effects
Neurological effects
Reproductive effects
Developmental effects
Other noncancer effects
Cancer

## C.2 LITERATURE SEARCH AND SCREEN FOR HEALTH EFFECTS STUDIES

A literature search and screen were conducted to identify studies examining the health effects of n-hexane. The literature search framework for the toxicological profile is discussed in detail in Appendix B.

### C.2.1 Literature Search

As noted in Appendix B, the literature searches were intended to update the Toxicological Profile for n-Hexane. See Appendix B for the databases searched and the search strategy.

A total of 7,489 and 1,578 records relevant to all sections of the toxicological profile were identified in the initial and update literature search, respectively.

### C.2.2 Literature Screening

As described in Appendix B, a two-step process was used to screen the literature search to identify relevant studies examining the health effects of n-hexane.

Title and Abstract Screen. In the Title and Abstract Screen step, 101 documents (inclusive of all literature searches) were considered to meet the health effects inclusion criteria in Table C-1 and were moved to the next step in the process.

Full Text Screen. In the second step in the literature screening process for the systematic review, a full text review of 101 health effect documents (documents identified in the update literature search and documents cited in older versions of the profile) was performed. From those 101 documents (114 studies), 69 documents (75 studies) were included in the qualitative review.

## C.3 EXTRACT DATA FROM HEALTH EFFECTS STUDIES

Relevant data extracted from the individual studies selected for inclusion in the systematic review were collected in customized data forms. A summary of the type of data extracted from each study is presented in Table C-2. For references that included more than one experiment or species, data extraction records were created for each experiment or species.

Table C-2 Data Extracted from Individual Studies

Citation
Chemical form
Route of exposure (e.g., inhalation, oral, dermal)
Specific route (e.g., gavage in oil, drinking water)
Species
Strain
Exposure duration category (e.g., acute, intermediate, chronic)
Exposure duration
Frequency of exposure (e.g., 6 hours/day, 5 days/week)
Exposure length
Number of animals or subjects per sex per group
Dose/exposure levels
Parameters monitored
Description of the study design and method
Summary of calculations used to estimate doses (if applicable)
Summary of the study results
Reviewer’s comments on the study
Outcome summary (one entry for each examined outcome)
No-observed-adverse-effect level (NOAEL) value
Lowest-observed-adverse-effect level (LOAEL) value
Effect observed at the LOAEL value

A summary of the extracted data for each study is presented in the Supplemental Document for n-Hexane and overviews of the results of the inhalation, oral, and dermal exposure studies are presented in Sections 2.2–2.19 of the profile and in the Levels Significant Exposures tables in Section 2.1 of the profile (Tables 2-1, 2-2, and 2-3, respectively).

## C.4 IDENTIFY POTENTIAL HEALTH EFFECT OUTCOMES OF CONCERN

Overviews of the potential health effect outcomes for n-hexane identified in human and animal studies are presented in Tables C-3 and C-4, respectively. Both human and animal studies indicate that the nervous system is the primary target of n-hexane exposure. Additionally, the available animal studies suggest that the developmental and respiratory systems may also be sensitive targets of n-hexane exposure. Although numerous case reports evaluating n-hexane-induced neurotoxicity were available, these studies were not included in this review (discussed in Section 2.15). The remaining epidemiological and animal experimental studies examining these neurological, developmental, and respiratory outcomes were carried through to Steps 4–8 of the systematic review. There were 38 human and 52 animal studies (published in 70 documents) examining these outcomes carried through to Steps 4–8 of the systematic review.

Table C-3 Overview of the Health Outcomes for n-Hexane Evaluated In Human Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological | Neurological | Reproductive | Developmental | Other Noncancer | Caner
Inhalation studies
Cohort | | | | | | | | | | | | | | | 1
Cohort | | | | | | | | | | | | | | | | 1
Cross-sectional | 2 | 6 | | | 5 | 1 | 4 | 4 | | 1 | | 3 | 25 | 2 | | 1
Cross-sectional | 2 | 3 | | | 1 | 1 | 2 | 1 | | 1 | | 2 | 22 | 2 | | 0
Case-control | | | | | | | | | | | | | 5 | 3 | 1 | | 1
Case-control | | | | | | | | | | | | | 2 | 3 | 1 | | 1
Controlled | | 1 | | | | | | | | 1
Controlled | | 0 | | | | | | | | 0
Case series | | | | | | 2 | | | 1 | | 1 | | ≥10^a^ | | | 2
Case series | | | | | | 2 | | | 1 | | 0 | | ≥10^a^ | | | 0
Oral studies
Cohort
Case-control
Controlled
Case series
Dermal studies
Cohort
Case-control
Controlled | | | | | | | | | 1
Controlled | | | | | | | | | 1
Case series

Number of studies examining endpoint | 0 | 1 | 2 | 3 | 4 | 5-9 | ≥10
Number of studies reporting outcome | 0 | 1 | 2 | 3 | 4 | 5-9 | ≥10

a Due to the abundant database, case series examining neurological endpoints were not included in the systematic review

Table C-4 Overview of the Health Outcomes for n-Hexane Evaluated in Experimental Animal Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological^a^ | Neurological^a^ | Reproductive^a^ | Developmental | Other Noncancer | Caner
Inhalation studies
Acute-duration | 6 | | | | | | | | | | | | 6 | 5 | 6
Acute-duration | 2 | | | | | | | | | | | | 1 | 3 | 3
Intermediate-duration | 16 | 7 | 3 | 3 | 6 | 3 | 8 | 8 | 3 | 3 | 3 | 4 | 24 | 9 | 3 | 4 | 1
Intermediate-duration | 11 | 3 | 0 | 0 | 1 | 3 | 0 | 2 | 0 | 1 | 0 | 0 | 22 | 2 | 3 | 0 | 1
Chronic-duration | 1 | | | | | | | | | | | | | 1
Chronic-duration | 0 | | | | | | | | | | | | | 1
Oral studies
Acute-duration | 2 | | | | | | | | | | | | | 2 | 2
Acute-duration | 1 | | | | | | | | | | | | | 0 | 1
Intermediate-duration | 6 | | | | 1 | | | | | | | | 7 | 1
Intermediate-duration | 5 | | | | 1 | | | | | | | | 7 | 1
Chronic-duration
Dermal studies
Acute-duration | 1 | | | | | | | | 1
Acute-duration | 0 | | | | | | | | 1
Intermediate-duration
Chronic-duration

Number of studies examining endpoint | 0 | 1 | 2 | 3 | 4 | 5-9 | ≥10
Number of studies reporting outcome | 0 | 1 | 2 | 3 | 4 | 5-9 | ≥10

a Number of studies examining endpoint includes study evaluating histopathology, but not evaluating function.

## C.5 ASSESS THE RISK OF BIAS FOR INDIVIDUAL STUDIES

### C.5.1 Risk of Bias Assessment

The risk of bias of individual studies was assessed using OHAT’s Risk of Bias Tool (NTP 2015). The risk of bias questions for observational epidemiology studies, human-controlled exposure studies, and animal experimental studies are presented in Tables C-5, C-6, and C-7, respectively. Each risk of bias question was answered on a four-point scale:

- Definitely low risk of bias (++)
- Probably low risk of bias (+)
- Probably high risk of bias (-)
- Definitely high risk of bias (– –)

In general, “definitely low risk of bias” or “definitely high risk of bias” were used if the question could be answered with information explicitly stated in the study report. If the response to the question could be inferred, then “probably low risk of bias” or “probably high risk of bias” responses were typically used.

Table C-5 Risk of Bias Questionnaire for Observational Epidemiology Studies

Selection bias; Were the comparison groups appropriate?
Confounding bias; Did the study design or analysis account for important confounding and modifying variables?
Attrition/exclusion bias; Were outcome data complete without attrition or exclusion from analysis?
Detection bias; Is there confidence in the exposure characterization?; Is there confidence in outcome assessment?
Selective reporting bias; Were all measured outcomes reported?

Table C-6 Risk of Bias Questionnaire for Human-Controlled Exposure Studies

Selection bias; Was administered dose or exposure level adequately randomized?; Was the allocation to study groups adequately concealed?
Performance bias; Were the research personnel and human subjects blinded to the study group during the study?
Attrition/exclusion bias; Were outcome data complete without attrition or exclusion from analysis?
Detection bias; Is there confidence in the exposure characterization?; Is there confidence in outcome assessment?
Selective reporting bias; Were all measured outcomes reported?

Table C-7 Risk of Bias Questionnaire for Experimental Animal Studies

Selection bias; Was administered dose or exposure level adequately randomized?; Was the allocation to study groups adequately concealed?
Performance bias; Were experimental conditions identical across study groups?; Were the research personnel blinded to the study group during the study?
Attrition/exclusion bias; Were outcome data complete without attrition or exclusion from analysis?
Detection bias; Is there confidence in the exposure characterization?; Is there confidence in outcome assessment?
Selective reporting bias; Were all measured outcomes reported?

After the risk of bias questionnaires were completed for the health effects studies, the studies were assigned to one of three risk of bias tiers based on the responses to the key questions listed below and the responses to the remaining questions.

- Is there confidence in the exposure characterization? (only relevant for observational studies)
- Is there confidence in the outcome assessment?
- Does the study design or analysis account for important confounding and modifying variables? (only relevant for observational studies)

First Tier. Studies placed in the first tier received ratings of “definitely low” or “probably low” risk of bias on the key questions AND received a rating of “definitely low” or “probably low” risk of bias on the responses to at least 50% of the other applicable questions.

Second Tier. A study was placed in the second tier if it did not meet the criteria for the first or third tiers.

Third Tier. Studies placed in the third tier received ratings of “definitely high” or “probably high” risk of bias for the key questions AND received a rating of “definitely high” or “probably high” risk of bias on the response to at least 50% of the other applicable questions.

The results of the risk of bias assessment for the different types of n-hexane health effects studies (observational epidemiology, human-controlled exposure, and animal experimental studies) are presented in Tables C-8, C-9, and C-10, respectively.

Table C-8 Summary of Risk of Bias Assessment for n-Hexane—Observational Epidemiology Studies

Reference | Risk of bias criteria and ratings
Reference | Selection bias | Confounding bias | Attrition / exclusion bias | Detection bias | | Selective reporting bias
Reference | Were the comparison groups appropriate? | Did the study design or analysis account for important confounding and modifying variables?^*^ | Were outcome data complete without attrition or exclusion from analysis? | Is there confidence in the exposure characterization?^*^ | Is there confidence in the outcome assessment?^*^ | Were all measured outcomes reported? | Risk of bias tier
Outcome: Developmental
Cohort
Lehmann et al. 2002 | ++ | + | + | + | + | ++ | First
Case-control
Gong et al. 2018 | ++ | + | ++ | + | + | ++ | First
Outcome: Respiratory
Cross-sectional
Buchdahl et al. 2000 | + | + | + | + | + | ++ | First
Mustajbegovic et al. 2000 | + | + | ++ | + | + | ++ | First
Nijem et al. 2000 | – | – | ++ | – | – | + | Third
Nijem et al. 2001 | – | – | ++ | – | – | + | Third
Paciencia et al. 2020 | – | – | – | – | – | – | Third
Wichmann et al. 2009 | + | + | ++ | – | ++ | ++ | Second
Outcome: Neurological
Case-control
Boggess et al. 2016 | ++ | + | ++ | + | ++ | ++ | First
Goldman et al. 2012 | + | – | + | – | + | ++ | Second
Issever et al. 2002 | – | – | + | – | – | + | Third
Talbott et al. 2015 | ++ | ++ | ++ | + | + | ++ | First
Verberk et al. 2004 | – | – | + | – | + | + | Third
Cross-sectional
Bates et al. 2016, 2019 | + | – | – | – | + | ++ | Third
Beckman et al. 2016 | + | + | + | – | + | ++ | Second
Chang and Yip 1987 | – | – | + | – | – | + | Third
Chang 1987 | – | – | + | – | – | + | Third
Chang et al. 1993 | – | – | + | + | – | + | Third
Gong et al. 2003 | + | + | + | + | + | ++ | First
Governa et al. 1987 | – | – | – | + | – | – | Third
Huang et al. 1991 | – | – | – | + | – | – | Third
Ithnin et al. 2011 | – | – | – | – | – | – | Third
Juarez-Perez et al. 2014 | – | – | – | + | – | + | Third
Murata et al. 1994 | + | + | – | + | – | + | Second
Mutti et al. 1982a | + | – | – | + | + | + | Second
Mutti et al. 1982b | + | – | + | + | + | + | Second
Neghab et al. 2012 | + | + | + | ++ | + | ++ | First
Nijem et al. 2000 | – | – | + | – | + | + | Second
Nijem et al. 2001 | – | – | + | – | + | + | Third
Park et al. 2009 | + | – | + | + | – | + | Third
Pastore et al. 1994 | + | – | – | + | + | + | Second
Raitta et al. 1978; Seppalainen et al. 1979 | – | – | + | – | + | + | Third
Sanagi et al. 1980 | + | + | – | ++ | + | ++ | First
Sliwinska-Kowalska et al. 2005 | + | ++ | + | + | + | + | First
Tsai et al. 1997 | + | ++ | + | – | + | ++ | Second
Wang et al. 1986 | – | – | – | – | – | ++ | Third
Yokoyama et al. 1997 | + | – | + | – | + | + | Third

++ = definitely low risk of bias; + = probably low risk of bias; – = probably high risk of bias; – – = definitely high risk of bias

* Key questions used to assign risk of bias tier

Table C-9 Summary of Risk of Bias Assessment for n-Hexane – Human-Controlled Exposure Studies

Reference | Risk of bias criteria and ratings | | | | | | | Risk of bias tier
Reference | Selection bias | | Performance bias | Attrition / exclusion bias | Detection bias | | Selective reporting bias | Risk of bias tier
Reference | Was administered dose or exposure level adequately randomized? | Was the allocation to study groups adequately concealed? | Were the research personnel and human subjects blinded to the study group during the study? | Were outcome data complete without attrition or exclusion from analysis? | Is there confidence in the exposure characterization? | Is there confidence in the outcome assessment?^*^ | Were all measured outcomes reported? | Risk of bias tier
Outcome: Respiratory
Inhalation acute exposure
Nelson et al. 1943 | – | – | – | – | – – | – | – | Third

++ = definitely low risk of bias; + = probably low risk of bias; – = probably high risk of bias; – – = definitely high risk of bias

* Key question used to assign risk of bias tier

Table C-10 Summary of Risk of Bias Assessment for n-Hexane—Experimental Animal Studies

Reference | Risk of bias criteria and ratings
Reference | Selection bias | | Performance bias | | Attrition / exclusion bias | Detection bias | | Selective reporting bias
Reference | Was administered dose or exposure level adequately randomized? | Was the allocation to study groups adequately concealed? | Were experimental conditions identical across study groups? | Were the research personnel blinded to the study group during the study? | Were outcome data complete without attrition or exclusion from analysis? | Is there confidence in the exposure characterization? | Is there confidence in the outcome assessment?^*^ | Were all measured outcomes reported? | Risk of bias tier
Outcome: Developmental Effects
Inhalation acute exposure
API 1979 | – | – | + | + | + | – | + | ++ | First
Bus et al. 1979 (GDs 8–12) | – | – | + | + | + | + | + | ++ | First
Bus et al. 1979 (GDs 12–16) | – | – | + | + | + | + | + | ++ | First
Bus et al. 1979 (GDs 8–16) | – | – | + | + | + | + | + | ++ | First
NIEHS 1987 | + | – | ++ | + | + | ++ | + | ++ | First
NIEHS 1988c | + | – | ++ | + | + | ++ | + | ++ | First
Inhalation intermediate exposure
Li et al. 2014, 2015 | – | – | – | – | – | – | – | + | Third
Stoltenburg-Didinger et al. 1990 (21 days) | – | – | – – | – | – | – | + | – | Third
Stoltenburg-Didinger et al. 1990 (63 days) | – | – | – – | – | – | – | + | – | Third
Oral acute exposure
Marks et al. 1980 (1 dose/day) | + | – | + | + | + | + | + | + | Second
Marks et al. 1980 (3 doses/day) | + | – | + | + | + | + | + | + | Second
Outcome: Respiratory Effects
Inhalation intermediate exposure
API 1981 | ++ | – | ++ | + | + | ++ | ++ | ++ | First
Cavender et al. 1984 | + | – | + | + | ++ | ++ | ++ | ++ | First
Howd et al. 1983 (21 days old) | + | – | + | + | ++ | – | + | ++ | First
Howd et al. 1983 (80 days old) | + | – | + | + | ++ | – | + | ++ | First
Lungarella et al. 1984 | – | – | + | – | – – | + | + | + | Third
NTP 1991 (6 hours/day) | ++ | ++ | + | + | + | ++ | ++ | ++ | First
NTP 1991 (22 hours/day) | ++ | ++ | + | + | + | ++ | ++ | ++ | First
Outcome: Neurological Effects
Inhalation acute exposure
Chalansonnet et al. 2013 | – | – | ++ | + | – | ++ | – | ++ | Third
De Martino et al. 1987 (1–2 weeks) | + | – | – | + | – | + | – | ++ | Third
NIEHS 1987 | + | – | ++ | + | + | ++ | + | ++ | First
NIEHS 1988a | + | – | ++ | + | + | ++ | + | ++ | First
NIEHS 1988b | + | – | ++ | + | + | ++ | + | ++ | First
NIEHS 1988c | + | – | ++ | + | + | ++ | + | ++ | First
Inhalation intermediate exposure
Altenkirch et al. 1982 (9 weeks) | – | – | ++ | – | + | + | ++ | ++ | Second
Altenkirch et al. 1982 (40 weeks) | – | – | ++ | – | + | + | ++ | ++ | Second
API 1981 | ++ | – | ++ | – | + | ++ | ++ | ++ | First
Cavender et al. 1984 | + | – | + | – | ++ | ++ | ++ | ++ | First
API 1979 | – | – | + | + | + | – | + | ++ | First
De Martino et al. 1987 (3–6 weeks) | + | – | – | – | – | + | – | ++ | Third
Frontali et al. 1981 (9 hours/day, 5 days/week) | ++ | – | + | – | – | + | – | + | Third
Frontali et al. 1981 (10 hours/day, 6 days/week) | ++ | – | + | – | – | + | – | + | Third
Howd et al. 1983 (21 days old) | + | – | + | – | ++ | – | + | ++ | Second
Howd et al. 1983 (80 days old) | + | – | + | – | ++ | – | + | ++ | Second
Huang et al. 1989 | + | – | + | – | + | + | + | ++ | Second
Ichihara et al. 1998 | + | – | + | + | + | + | + | ++ | First
Li et al. 2014, 2015 | – | – | – | – | – | – | – | + | Third
Lungarella et al. 1984 | – | – | + | – | – – | + | + | + | Third
NTP 1991 (6 hours/day) | ++ | ++ | + | – | + | ++ | ++ | ++ | First
NTP 1991 (22 hours/day) | ++ | ++ | + | – | + | ++ | ++ | ++ | First
Pryor et al. 1983 | + | + | + | – | – | + | + | + | Second
Rebert and Sorenson 1983 | – | – | + | – | + | – | + | + | Third
Schaumburg and Spencer 1976 | – | – | – – | – | – | – – | – | – | Third
Stoltenburg-Didinger et al. 1990 (21 days) | – | – | – | – | – | – | + | + | Third
Takeuchi et al. 1980 | – | – | – | – | – | + | + | + | Third
Oral intermediate exposure
Gao et al. 2019 | + | – | + | – | + | – | + | + | First
Krasavage et al. 1980 | + | – | + | – | + | ++ | + | ++ | First
Li et al. 2018 | + | – | + | – | – | – | + | ++ | Second
Li et al. 2020a | + | – | + | ++ | – | – | + | ++ | Second
Li et al. 2020b | + | – | + | ++ | – | – | + | + | Second
Ono et al. 1981 | – | – | + | – | – | – – | + | – | Third
Wang et al. 2017 | + | – | + | – | + | – | + | + | Third

++ = definitely low risk of bias; + = probably low risk of bias; – = probably high risk of bias; – – = definitely high risk of bias

* Key question used to assign risk of bias tier

## C.6 RATE THE CONFIDENCE IN THE BODY OF EVIDENCE FOR EACH RELEVANT OUTCOME

Confidences in the bodies of human and animal evidence were evaluated independently for each potential outcome. ATSDR did not evaluate the confidence in the body of evidence for carcinogenicity; rather, the Agency defaulted to the cancer weight-of-evidence assessment of other agencies including HHS, EPA, and IARC. The confidence in the body of evidence for an association or no association between exposure to n-hexane and a particular outcome was based on the strengths and weaknesses of individual studies. Four descriptors were used to describe the confidence in the body of evidence for effects or when no effect was found:

- High confidence: the true effect is highly likely to be reflected in the apparent relationship
- Moderate confidence: the true effect may be reflected in the apparent relationship
- Low confidence: the true effect may be different from the apparent relationship
- Very low confidence: the true effect is highly likely to be different from the apparent relationship

Confidence in the body of evidence for a particular outcome was rated for each type of study: case-control, case series, cohort, population, human-controlled exposure, and experimental animal. In the absence of data to the contrary, data for a particular outcome were collapsed across animal species, routes of exposure, and exposure durations. If species (or strain), route, or exposure duration differences were noted, then the data were treated as separate outcomes.

### C.6.1 Initial Confidence Rating

In ATSDR’s modification to the OHAT approach, the body of evidence for an association (or no association) between exposure to n-hexane and a particular outcome was given an initial confidence rating based on the key features of the individual studies examining that outcome. The presence of these key features of study design was determined for individual studies using four “yes or no” questions, which were customized for epidemiology, human controlled exposure, or experimental animal study designs. Separate questionnaires were completed for each outcome assessed in a study. The key features for observational epidemiology (cohort, population, and case-control) studies, human controlled exposure, and experimental animal studies are presented in Tables C-11, C-12, and C-13, respectively. The initial confidence in the study was determined based on the number of key features present in the study design:

- High Initial Confidence: Studies in which the responses to the four questions were “yes”.
- Moderate Initial Confidence: Studies in which the responses to only three of the questions were “yes”.
- Low Initial Confidence: Studies in which the responses to only two of the questions were “yes”.
- Very Low Initial Confidence: Studies in which the response to one or none of the questions was “yes”.

Table C-11 Key Features of Study Design for Observational Epidemiology Studies

Exposure was experimentally controlled
Exposure occurred prior to the outcome
Outcome was assessed on individual level rather than at the population level
A comparison group was used

Table C-12 Key Features of Study Design for Human-Controlled Exposure Studies

A comparison group was used or the subjects served as their own control
A sufficient number of subjects were tested
Appropriate methods were used to measure outcomes (i.e., clinically-confirmed outcome versus selfreported)
Appropriate statistical analyses were performed and reported or the data were reported in such a way to allow independent statistical analysis

Table C-13 Key Features of Study Design for Experimental Animal Studies

A concurrent control group was used
A sufficient number of animals per group were tested
Appropriate parameters were used to assess a potential adverse effect
Appropriate statistical analyses were performed and reported or the data were reported in such a way to allow independent statistical analysis

The presence or absence of the key features and the initial confidence levels for studies examining developmental, respiratory, and neurological outcomes observed in the observational epidemiology, human-controlled exposure, and animal experimental studies are presented in Tables C-14, C-15, and C-16, respectively.

Table C-14 Presence of Key Features of Study Design for n-Hexane—Observational Epidemiology Studies

Reference | Key features | | | | Initial study confidence
Reference | Controlled exposure | Exposure prior to outcome | Outcomes assessed on an individual level | Comparison group | Initial study confidence
Outcome: Developmental
Cohort
Lehmann et al. 2002 | No | No | Yes | Yes | Low
Case-control
Gong et al. 2018 | No | No | Yes | Yes | Low
Outcome: Respiratory
Cross-sectional
Buchdahl et al. 2000 | No | No | Yes | Yes | Low
Mustajbegovic et al. 2000 | No | Yes | Yes | Yes | Moderate
Nijem et al. 2000 | No | Yes | Yes | No | Low
Nijem et al. 2001 | No | Yes | Yes | No | Low
Paciencia et al. 2020 | No | No | Yes | No | Very low
Wichmann et al. 2009 | No | No | Yes | Yes | Low
Outcome:
Case-control
Boggess et al. 2016 | No | No | Yes | Yes | Low
Goldman et al. 2012 | No | Yes | Yes | Yes | Moderate
Issever et al. 2002 | No | Yes | Yes | Yes | Moderate
Talbott et al. 2015 | No | No | Yes | Yes | Low
Verberk et al. 2004 | No | Yes | Yes | Yes | Moderate
Cross-sectional
Bates et al. 2016, 2019 | No | Yes | Yes | Yes | Moderate
Beckman et al. 2016 | No | Yes | Yes | Yes | Moderate
Chang and Yip 1987 | No | Yes | Yes | Yes | Moderate
Chang 1987 | No | Yes | Yes | Yes | Moderate
Chang et al. 1993 | No | Yes | Yes | Yes | Moderate
Gong et al. 2003 | No | Yes | Yes | Yes | Moderate
Governa et al. 1987 | No | Yes | Yes | No | Low
Huang et al. 1991 | No | Yes | Yes | Yes | Moderate
Ithnin et al. 2011 | No | Yes | Yes | No | Low
Juarez-Perez et al. 2014 | No | Yes | Yes | Yes | Moderate
Murata et al. 1994 | No | Yes | Yes | Yes | Moderate
Mutti et al. 1982a | No | Yes | Yes | Yes | Moderate
Mutti et al. 1982b | No | Yes | Yes | Yes | Moderate
Neghab et al. 2012 | No | Yes | Yes | Yes | Moderate
Nijem et al. 2000 | No | Yes | Yes | No | Low
Nijem et al. 2001 | No | Yes | Yes | No | Low
Park et al. 2009 | No | Yes | Yes | Yes | Moderate
Pastore et al. 1994 | No | Yes | Yes | Yes | Moderate
Raitta et al. 1978; Seppalainen et al. 1979 | No | Yes | Yes | Yes | Moderate
Sanagi et al. 1980 | No | Yes | Yes | Yes | Moderate
Sliwinska-Kowalska et al. 2005 | No | Yes | Yes | Yes | Moderate
Tsai et al. 1997 | No | Yes | Yes | Yes | Moderate
Wang et al. 1986 | No | Yes | Yes | No | Low
Yokoyama et al. 1997 | No | Yes | Yes | Yes | Moderate

Table C-15 Presence of Key Features of Study Design for n-Hexane—Human-Controlled Exposure

Reference | Key features | | | | Initial study confidence
Reference | Comparison group or served as own controls | Sufficient number of subjects tested | Appropriate outcome assessment | Appropriate statistical analysis | Initial study confidence
Outcome: Respiratory effects
Inhalation acute exposure
Nelson et al. 1943 | No | No | Yes | No | Very low

Table C-16 Presence of Key Features of Study Design for n-Hexane—Experimental Animal Studies

Reference | Key features | | | | Initial study confidence
Reference | Concurrent control group | Sufficient number of animals per group | Appropriate parameters to assess potential effect | Adequate data for statistical analysis | Initial study confidence
Outcome: Developmental Effects
Inhalation acute exposure
API 1979 | Yes | Yes | Yes | Yes | High
Bus et al. 1979 (GDs 8–12) | Yes | No | Yes | Yes | Moderate
Bus et al. 1979 (GDs 12–16) | Yes | No | Yes | Yes | Moderate
Bus et al. 1979 (GDs 8–16) | Yes | No | Yes | Yes | Moderate
NIEHS 1987 | Yes | Yes | Yes | Yes | High
NIEHS 1988c | Yes | Yes | Yes | Yes | High
Inhalation intermediate exposure
Li et al. 2014, 2015 | Yes | No | Yes | Yes | Moderate
Stoltenburg-Didinger et al. 1990 (21 days) | Yes | No | Yes | No | Low
Stoltenburg-Didinger et al. 1990 (63 days) | Yes | No | Yes | No | Low
Oral acute exposure
Marks et al. 1980 (1 dose/day) | Yes | No | Yes | Yes | Moderate
Marks et al. 1980 (3 doses/day) | Yes | No | Yes | Yes | Moderate
Outcome: Respiratory Effects
Inhalation intermediate exposure
API 1981 | Yes | Yes | Yes | Yes | High
Cavender et al. 1984 | Yes | Yes | Yes | Yes | High
Howd et al. 1983 (21 days old) | Yes | Yes | Yes | Yes | High
Howd et al. 1983 (80 days old) | Yes | Yes | Yes | Yes | High
Lungarella et al. 1984 | Yes | Yes | Yes | No | Moderate
NTP 1991 (6 hours/day) | Yes | Yes | Yes | Yes | High
NTP 1991 (22 hours/day) | Yes | Yes | Yes | Yes | High
Outcome: Neurological Effects
Inhalation acute exposure
Chalansonnet et al. 2013 | Yes | No | Yes | No | Low
De Martino et al. 1987 (1–2 weeks) | Yes | No | Yes | No | Low
NIEHS 1987 | Yes | Yes | Yes | No | Moderate
NIEHS 1988a | Yes | Yes | Yes | No | Moderate
NIEHS 1988b | Yes | Yes | Yes | No | Moderate
NIEHS 1988c | Yes | Yes | Yes | No | Moderate
Inhalation intermediate exposure
Altenkirch et al. 1982 (9 weeks) | Yes | No | Yes | No | Low
Altenkirch et al. 1982 (40 weeks) | Yes | No | Yes | No | Low
API 1981 | Yes | Yes | Yes | Yes | High
Cavender et al. 1984 | Yes | Yes | Yes | Yes | High
De Martino et al. 1987 (3–6 weeks) | Yes | No | Yes | No | Low
Frontali et al. 1981 (9 hours/day, 5 days/week) | Yes | No | Yes | No | Low
Frontali et al. 1981 (10 hours/day, 6 days/week) | Yes | No | Yes | No | Low
Howd et al. 1983 (21 days old) | Yes | Yes | Yes | Yes | High
Howd et al. 1983 (80 days old) | Yes | Yes | Yes | Yes | High
Huang et al. 1989 | Yes | No | Yes | Yes | Moderate
Ichihara et al. 1998 | Yes | No | Yes | Yes | Moderate
Li et al. 2014, 2015 | Yes | No | Yes | Yes | Moderate
Lungarella et al. 1984 | Yes | Yes | Yes | No | Moderate
NTP 1991 (6 hours/day) | Yes | Yes | Yes | Yes | High
NTP 1991 (22 hours/day) | Yes | Yes | Yes | Yes | High
Pryor et al. 1983 | Yes | Yes | Yes | Yes | High
Rebert and Sorenson 1983 | Yes | No | Yes | Yes | Moderate
Schaumburg and Spencer 1976 | No | No | Yes | No | Low
Stoltenburg-Didinger et al. 1990 (21 days) | Yes | No | Yes | No | Low
Stoltenburg-Didinger et al. 1990 (63 days) | Yes | No | Yes | No | Low
Takeuchi et al. 1980 | Yes | No | Yes | Yes | Moderate
Oral intermediate exposure
Gao et al. 2019 | Yes | Yes | Yes | Yes | High
Krasavage et al. 1980 | Yes | No | Yes | No | Low
Li et al. 2018 | Yes | Yes | Yes | Yes | High
Li et al. 2020a | Yes | Yes | Yes | Yes | High
Li et al. 2020b | Yes | No | Yes | Yes | Moderate
Ono et al. 1981 | Yes | No | Yes | Yes | Moderate
Wang et al. 2017 | Yes | Yes | Yes | Yes | High

A summary of the initial confidence ratings for each outcome is presented in Table C-17. If individual studies for a particular outcome and study type had different study quality ratings, then the highest confidence rating for the group of studies was used to determine the initial confidence rating for the body of evidence; any exceptions were noted in Table C-17.

Table C-17 Initial Confidence Rating for n-Hexane Health Effects Studies

| Initial study confidence | Initial confidence rating
Outcome: Developmental Effects
Inhalation acute exposure
Animal studies
Bus et al. 1979 (GDs 8–12) | Moderate | High
Bus et al. 1979 (GDs 12–16) | Moderate | High
Bus et al. 1979 (GDs 8–16) | Moderate | High
API 1979 | High | High
NIEHS 1987 | High | High
NIEHS 1988c | High | High
Inhalation intermediate exposure
Animal studies
Li et al. 2014, 2015 | Moderate | Moderate
Stoltenburg-Didinger et al. 1990 (21 days) | Low | Moderate
Stoltenburg-Didinger et al. 1990 (63 days) | Low | Moderate
Inhalation chronic exposure
Human studies
Lehmann et al. 2002 | Low | Low
Gong et al. 2018 | Low | Low
Oral acute exposure
Animal studies
Marks et al. 1980 (1 dose/day) | Moderate | Moderate
Marks et al. 1980 (3 doses/day) | Moderate | Moderate
Outcome: Respiratory Effects
Inhalation acute exposure
Human studies
Nelson et al. 1943 | Very Low | Very Low
Inhalation intermediate exposure
Animal studies
API 1981 | High | High
Cavender et al. 1984 | High | High
Howd et al. 1983 (21 days old) | High | High
Howd et al. 1983 (80 days old) | High | High
Lungarella et al. 1984 | Moderate | High
NTP 1991 (6 hours/day) | High | High
NTP 1991 (22 hours/day) | High | High
Inhalation chronic exposure
Human studies
Buchdahl et al. 2000 | Low | Low
Mustajbegovic et al. 2000 | Moderate | Low
Nijem et al. 2000 | Low | Low
Nijem et al. 2001 | Low | Low
Paciencia et al. 2020 | Very low | Low
Wichmann et al. 2009 | Low | Low
Nelson et al. 1943 | Very low | Low
Outcome: Neurological Effects
Inhalation acute exposure
Animal studies
Chalansonnet et al. 2013 | Low | Moderate
De Martino et al. 1987 (1–2 weeks) | Low | Moderate
NIEHS 1987 | Moderate | Moderate
NIEHS 1988a | Moderate | Moderate
NIEHS 1988b | Moderate | Moderate
NIEHS 1988c | Moderate | Moderate
Inhalation intermediate exposure
Animal studies
API 1981 | High | High
Altenkirch et al. 1982 (9 weeks) | Low | High
Altenkirch et al. 1982 (40 weeks) | Low | High
Cavender et al. 1984 | High | High
De Martino et al. 1987 (3–6 weeks) | Low | High
Frontali et al. 1981 (9 hours/day, 5 days/week) | Low | High
Frontali et al. 1981 (10 hours/day, 6 days/week) | Low | High
Howd et al. 1983 (21 days old) | High | High
Howd et al. 1983 (80 days old) | High | High
Huang et al. 1989 | Moderate | High
Ichihara et al. 1998 | Moderate | High
Li et al. 2014, 2015 | Moderate | High
Lungarella et al. 1984 | Moderate | High
NTP 1991 (6 hours/day) | High | High
NTP 1991 (22 hours/day) | High | High
Pryor et al. 1983 | High | High
Rebert and Sorenson 1983 | Moderate | High
Schaumburg and Spencer 1976 | Low | High
Stoltenburg-Didinger et al. 1990 (21 days) | Low | High
Takeuchi et al. 1980 | Moderate | High
Inhalation chronic exposure
Human studies
Boggess et al. 2016 | Low | Moderate
Goldman et al. 2012 | Moderate | Moderate
Issever et al. 2002 | Moderate | Moderate
Talbott et al. 2015 | Low | Moderate
Verberk et al. 2004 | Moderate | Moderate
Bates et al. 2016, 2019 | Moderate | Moderate
Beckman et al. 2016 | Moderate | Moderate
Chang and Yip 1987 | Moderate | Moderate
Chang 1987 | Moderate | Moderate
Chang et al. 1993 | Moderate | Moderate
Gong et al. 2003 | Moderate | Moderate
Governa et al. 1987 | Low | Moderate
Huang et al. 1991 | Moderate | Moderate
Ithnin et al. 2011 | Low | Moderate
Juarez-Perez et al. 2014 | Moderate | Moderate
Murata et al. 1994 | Moderate | Moderate
Mutti et al. 1982a | Moderate | Moderate
Mutti et al. 1982b | Moderate | Moderate
Neghab et al. 2012 | Moderate | Moderate
Nijem et al. 2000 | Low | Moderate
Nijem et al. 2001 | Low | Moderate
Park et al. 2009 | Moderate | Moderate
Pastore et al. 1994 | Moderate | Moderate
Raitta et al. 1978; Seppalainen et al. 1979 | Moderate | Moderate
Sanagi et al. 1980 | Moderate | Moderate
Sliwinska-Kowalska et al. 2005 | Moderate | Moderate
Tsai et al. 1997 | Moderate | Moderate
Wang et al. 1986 | Low | Moderate
Yokoyama et al. 1997 | Moderate | Moderate
Oral intermediate exposure
Animal studies
Gao et al. 2019 | High | High
Krasavage et al. 1980 | Low | High
Li et al. 2018 | High | High
Li et al. 2020a | High | High
Li et al. 2020b | Moderate | High
Ono et al. 1981 | Moderate | High
Wang et al. 2017 | High | High

### C.6.2 Adjustment of the Confidence Rating

The initial confidence rating was then downgraded or upgraded depending on whether there were substantial issues that would decrease or increase confidence in the body of evidence. The nine properties of the body of evidence that were considered are listed below. The summaries of the assessment of the confidence in the body of evidence for developmental, respiratory, and neurological effects are presented in Table C-18. If the confidence ratings for a particular outcome were based on more than one type of human study, then the highest confidence rating was used for subsequent analyses. An overview of the confidence in the body of evidence for all health effects associated with n-hexane exposure is presented in Table C-19.

Table C-18 Adjustments to the Initial Confidence in the Body of Evidence

| Initial confidence | Adjustments to the initial confidence rating | Final confidence
Outcome: Developmental Effects
Human studies | Low | -1 indirectness | Very low
Animal studies | High | +1 consistency | High
Outcome: Respiratory Effects
Human studies | Low | -1 risk of bias | Very low
Animal studies | High | | High
Outcome: Neurological Effects
Human studies | Moderate | -1 risk of bias; +1 consistency; +1 large magnitude of effect; +1 Residual bias | High
Animal studies | High | +1 consistency; +1 dose response; +1 large magnitude of effect | High

Table C-19 Confidence in the Body of Evidence for n-Hexane

Outcome | Confidence in body of evidence
Outcome | Human studies | Animal studies
Developmental | Very low | High
Respiratory | Very low | High
Neurological | High | High

Five properties of the body of evidence were considered to determine whether the confidence rating should be downgraded:

- Risk of bias. Evaluation of whether there is substantial risk of bias across most of the studies examining the outcome. This evaluation used the risk of bias tier groupings for individual studies examining a particular outcome (Tables C-8, C-9, and C-10). Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for risk of bias:
  ○ No downgrade if most studies are in the risk of bias first tier
  ○ Downgrade one confidence level if most studies are in the risk of bias second tier
  ○ Downgrade two confidence levels if most studies are in the risk of bias third tier
- Unexplained inconsistency. Evaluation of whether there is inconsistency or large variability in the magnitude or direction of estimates of effect across studies that cannot be explained. Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for unexplained inconsistency:
  ○ No downgrade if there is little inconsistency across studies or if only one study evaluated the outcome
  ○ Downgrade one confidence level if there is variability across studies in the magnitude or direction of the effect
  ○ Downgrade two confidence levels if there is substantial variability across studies in the magnitude or direct of the effect
- Indirectness. Evaluation of four factors that can affect the applicability, generalizability, and relevance of the studies:
  ○ Relevance of the animal model to human health—unless otherwise indicated, studies in rats, mice, and other mammalian species are considered relevant to humans
  ○ Directness of the endpoints to the primary health outcome—examples of secondary outcomes or nonspecific outcomes include organ weight in the absence of histopathology or clinical chemistry findings in the absence of target tissue effects
  ○ Nature of the exposure in human studies and route of administration in animal studies—inhalation, oral, and dermal exposure routes are considered relevant unless there are compelling data to the contrary
  ○ Duration of treatment in animal studies and length of time between exposure and outcome assessment in animal and prospective human studies—this should be considered on an outcome-specific basis
  Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for indirectness:
  ○ No downgrade if none of the factors are considered indirect
  ○ Downgrade one confidence level if one of the factors is considered indirect
  ○ Downgrade two confidence levels if two or more of the factors are considered indirect
- Imprecision. Evaluation of the narrowness of the effect size estimates and whether the studies have adequate statistical power. Data are considered imprecise when the ratio of the upper to lower 95% CIs for most studies is ≥10 for tests of ratio measures (e.g., odds ratios) and ≥100 for absolute measures (e.g., percent control response). Adequate statistical power is determined if the study can detect a potentially biologically meaningful difference between groups (20% change from control response for categorical data or risk ratio of 1.5 for continuous data). Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for imprecision:
  ○ No downgrade if there are no serious imprecisions
  ○ Downgrade one confidence level for serious imprecisions
  ○ Downgrade two confidence levels for very serious imprecisions
- Publication bias. Evaluation of the concern that studies with statistically significant results are more likely to be published than studies without statistically significant results.
  ○ Downgrade one level of confidence for cases where there is serious concern with publication bias

Four properties of the body of evidence were considered to determine whether the confidence rating should be upgraded:

- Large magnitude of effect. Evaluation of whether the magnitude of effect is sufficiently large so that it is unlikely to have occurred as a result of bias from potential confounding factors.
  ○ Upgrade one confidence level if there is evidence of a large magnitude of effect in a few studies, provided that the studies have an overall low risk of bias and there is no serious unexplained inconsistency among the studies of similar dose or exposure levels; confidence can also be upgraded if there is one study examining the outcome, provided that the study has an overall low risk of bias
- Dose response. Evaluation of the dose-response relationships measured within a study and across studies. Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level for evidence of a monotonic dose-response gradient
  ○ Upgrade one confidence level for evidence of a non-monotonic dose-response gradient where there is prior knowledge that supports a non-monotonic dose-response and a non-monotonic dose-response gradient is observed across studies
- Plausible confounding or other residual biases. This factor primarily applies to human studies and is an evaluation of unmeasured determinants of an outcome such as residual bias towards the null (e.g., “healthy worker” effect) or residual bias suggesting a spurious effect (e.g., recall bias). Below is the criterion used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level for evidence that residual confounding or bias would underestimate an apparent association or treatment effect (i.e., bias toward the null) or suggest a spurious effect when results suggest no effect
- Consistency in the body of evidence. Evaluation of consistency across animal models and species, consistency across independent studies of different human populations and exposure scenarios, and consistency across human study types. Below is the criterion used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level if there is a high degree of consistency in the database

## C.7 TRANSLATE CONFIDENCE RATING INTO LEVEL OF EVIDENCE OF HEALTH EFFECTS

In the seventh step of the systematic review of the health effects data for n-hexane, the confidence in the body of evidence for specific outcomes was translated to a level of evidence rating. The level of evidence rating reflected the confidence in the body of evidence and the direction of the effect (i.e., toxicity or no toxicity); route-specific differences were noted. The level of evidence for health effects was rated on a five-point scale:

- High level of evidence: High confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Moderate level of evidence: Moderate confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Low level of evidence: Low confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Evidence of no health effect: High confidence in the body of evidence that exposure to the substance is not associated with the health outcome
- Inadequate evidence: Low or moderate confidence in the body of evidence that exposure to the substance is not associated with the health outcome OR very low confidence in the body of evidence for an association between exposure to the substance and the health outcome

A summary of the level of evidence of health effects for n-hexane is presented in Table C-20.

Table C-20 Level of Evidence of Health Effects for n-Hexane

Outcome | Confidence in body of evidence | Direction of health effect | Level of evidence for health effect
Human studies
Developmental | Very low | Health effect | Inadequate
Respiratory | Very low | Health effect | Inadequate
Neurological | High | Health effect | High
Animal studies
Developmental | High | Health effect | High
Respiratory | High | Health effect | High
Neurological | High | Health effect | High

## C.8 INTEGRATE EVIDENCE TO DEVELOP HAZARD IDENTIFICATION CONCLUSIONS

The final step involved the integration of the evidence streams for the human studies and animal studies to allow for a determination of hazard identification conclusions. For health effects, there were four hazard identification conclusion categories:

- Known to be a hazard to humans
- Presumed to be a hazard to humans
- Suspected to be a hazard to humans
- Not classifiable as to the hazard to humans

The initial hazard identification was based on the highest level of evidence in the human studies and the level of evidence in the animal studies; if there were no data for one evidence stream (human or animal), then the hazard identification was based on the one data stream (equivalent to treating the missing evidence stream as having low level of evidence). The hazard identification scheme is presented in Figure C-1 and described below:

- Known: A health effect in this category would have:
  ○ High level of evidence for health effects in human studies AND a high, moderate, or low level of evidence in animal studies.
- Presumed: A health effect in this category would have:
  ○ Moderate level of evidence in human studies AND high or moderate level of evidence in animal studies OR
  ○ Low level of evidence in human studies AND high level of evidence in animal studies
- Suspected: A health effect in this category would have:
  ○ Moderate level of evidence in human studies AND low level of evidence in animal studies OR
  ○ Low level of evidence in human studies AND moderate level of evidence in animal studies
- Not classifiable: A health effect in this category would have:
  ○ Low level of evidence in human studies AND low level of evidence in animal studies

Figure C-1 Hazard Identification Scheme

Other relevant data such as mechanistic or mode-of-action data were considered to raise or lower the level of the hazard identification conclusion by providing information that supported or opposed biological plausibility.

Two hazard identification conclusion categories were used when the data indicated that there may be no health effect in humans:

- Not identified to be a hazard in humans
- Inadequate to determine hazard to humans

If the human level of evidence conclusion of no health effect was supported by the animal evidence of no health effect, then the hazard identification conclusion category of “not identified” was used. If the human or animal level of evidence was considered inadequate, then a hazard identification conclusion category of “inadequate” was used. As with the hazard identification for health effects, the impact of other relevant data was also considered for no health effect data.

The hazard identification conclusions for n-hexane are listed below and summarized in Table C-21.

Known Health Effects

- Neurological
  ○ High level of evidence from human studies: numerous human studies are available that establish the neurotoxicity of n-hexane (Chang et al. 1993; Gong et al. 2003; Huang et al. 1991; Murata et al. 1994; Mutti et al. 1982a, 1982b; Pastore et al. 1994; Raitta et al. 1978; Seppalainen et al. 1979; Sanagi et al. 1980; Wang et al. 1986; Yokoyama et al. 1997).
  ○ High level of evidence from animal studies: abundant data are available demonstrating the neurological effects of n-hexane inhalation (Altenkirch et al. 1982; API 1981; Cavender et al. 1984; De Martino et al. 1987; Frontali et al. 1981; Howd et al. 1983; Huang et al. 1989; Ichihara et al. 1998; NTP 1991; Schaumburg and Spencer 1976; Takeuchi et al. 1980) and oral exposure (Gao et al. 2019; Krasavage et al. 1980; Li et al. 2018, 2020a, 2020b; Ono et al. 1981; Wang et al. 2017) in rodents.

Suspected Health Effects

- Developmental
  ○ Inadequate evidence from human studies: A case-control study showed a positive association between ambient n-hexane exposure and low birth weight (Gong et al. 2018), while a cohort study reported an association between maternal n-hexane exposure and alterations of the neonatal immune system (Lehmann et al. 2002). No other developmental studies were available.
  ○ High level of evidence from animal studies: several rodent studies have reported decreased fetal/litter weights following inhalation (Bus et al. 1979; NIEHS 1987, 1988c; Stoltenburg-Didinger et al. 1990) or oral exposure (Marks et al. 1980) to n-hexane.
- Respiratory
  ○ Inadequate evidence from human studies: human survey studies have identified higher incidences of self-reported respiratory symptoms (i.e., cough, phlegm, bronchitis, chest tightness) in solvent-exposed workers (Mustajbegovic et al. 2000; Nijem et al. 2001). In a study evaluating the effects of ambient n-hexane exposure in children, reduced lung function was observed in children living near point sources (Wichmann et al. 2009); however, two additional studies found no associations between n-hexane exposure and hospital visits for breathing problems (Buchdahl et al. 2000) or the incidence of rhinitis (Paciencia et al. 2020) in children.
  ○ High level of evidence from animal studies: an inhalation study observed nasal lesions in mice following intermediate-duration exposure (NTP 1991); two similar studies did not find lesions in the nasal turbinates of rats (API 1981; Cavender et al. 1984). Additional studies have observed increased lung weights and lung lesions (Howd et al. 1983; Lungarella et al. 1984; NTP 1991).

Table C-21 Hazard Identification Conclusions for n-Hexane

Outcome | Hazard identification
Developmental | Suspected
Respiratory | Suspected
Neurological | Known