# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. LOAELs for serious health effects (such as irreparable damage to the liver or kidneys, or serious birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substances than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Office of Innovation and Analytics, Toxicology Section, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Office of Innovation and Analytics, Toxicology Section, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S106-5, Atlanta, Georgia 30329-4027.

## n-Hexane Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | n-Hexane
CAS Number: | 110-54-3
Date: | April 2025
Profile Status: | Final
Route: | Inhalation
Duration: | Acute
MRL: | 6 ppm (21 mg/m^3^)
Critical Effects: | Decreased fetal body weight
Reference: | NIEHS 1987
Point of Departure: | NOAEL of 200 ppm (NOAEL_HEC_ of 167 ppm)
Uncertainty Factor: | 30
LSE Graph Key: | 9
Species: | Rat

MRL Summary: An acute-duration inhalation MRL of 6 ppm was derived for n-hexane based on a NOAEL of 200 ppm and a LOAEL of 1,000 ppm for developmental effects (7.5% decrease in male fetal body weight) in rats exposed on GDs 6–19 (14 days) for 20 hours/day (NIEHS 1987). The NOAEL was adjusted to continuous duration exposure, converted to a human equivalent concentration (NOAEL_HEC_) of 167 ppm, and divided by a total uncertainty factor of 30 (3 for extrapolation from animals to humans with dosimetric adjustments and 10 for human variability).

Selection of the Critical Effect: Several studies examined the acute-duration inhalation toxicity of n-hexane. A summary of the identified LOAELs is presented in Table A-1. Exposure to 1,000 ppm resulted in developmental effects, while exposure to 5,000 ppm resulted in body weight, neurological, developmental, and reproductive effects. The lowest LOAELs were 1,000 ppm for decreased litter weight and fetal body weight (Bus et al. 1979; NIEHS 1987).

Selection of the Principal Study: Bus et al. (1979) and NIEHS (1987) both identified LOAELs of 1,000 ppm for decreased fetal/litter weights. In the Bus et al. (1979) study, a 13.9% decrease in mean litter weight at 3 weeks after birth was observed in the offspring of rats exposed to 1,000 ppm n-hexane 6 hours/day on GDs 8–16. No differences were observed in birth weight or pup body weight 7 weeks after birth. In the NIEHS (1987) study, a 7.5% decrease in male fetal body weight was observed in the offspring of rats exposed to 1,000 ppm 20 hours/day on GDs 6–19; a NOAEL of 200 ppm was also identified.

Adjusting the durations to continuous exposure results in a LOAEL_ADJ_ of 250 ppm for Bus et al. (1979) study and a NOAEL_ADJ_ of 167 ppm and LOAEL_ADJ_ of 833 ppm for NIEHS (1987) study. The NIEHS (1987) study was selected as the principal study because it identified a NOAEL for the most sensitive endpoint, used multiple doses, exposed animals for 20 hours/day (close to a continuous exposure), and examined a larger number of litters (23–28/group versus 8–14/group in the Bus et al. [1979] study).

Table A-1 Summary of NOAEL and LOAEL Values Following Acute-Duration Inhalation Exposure to n-Hexane

Species (strain, sex) | Duration | NOAEL (NOAEL_ADJ_) (ppm) | LOAEL (LOAEL_ADJ_) (ppm) | Effect | Reference
Developmental effects
Rats (Fischer-344, F) | 9 days (GDs 8–16); 6 hours/day | ND | 1,000; (250) | Decreased litter weight (13.9% at 3 weeks after birth) | Bus et al. 1979
Rats (Sprague-Dawley, F) | 14 days (GDs 6–19); 20 hours/day | 200; (167) | 1,000; (833) | Decreased fetal body weight (7.5% in male offspring) | NIEHS 1987
Mice (Swiss, F) | 12 days (GDs 6–17); 20 hours/day | ND | 5,000; (4,167) | Decreased number of live fetuses per litter, increased incidence of late resorptions | NIEHS 1988c
Reproductive effects
Rats (Sprague-Dawley, M) | 2 weeks; 6 days/week; 16 hours/day | ND | 5,000; (2,857) | Testicular lesions (spermatocyte necrosis, exfoliation of spermatids, and Sertoli cell vacuolization) | De Martino et al. 1987
Rats (Sprague-Dawley, M) | 8 days; 16 hours/day | ND | 5,000; (3,333) | Testicular lesions (degeneration of spermatocytes, exfoliation of elongated spermatids, and Sertoli cell vacuolization) | De Martino et al. 1987
Rats (Sprague-Dawley, M) | 24 hours; Continuous | ND | 5,000 | Testicular lesions (focal degeneration of spermatocytes and mild exfoliation of elongated spermatids) | De Martino et al. 1987
Neurological effects
Rats (Sprague-Dawley, M) | 2 weeks; 6 days/week; 16 hours/day | ND | 5,000; (2,857) | Decreased motor conduction velocity | De Martino et al. 1987
Body weight effects
Rats (Sprague-Dawley, M) | 2 weeks; 6 days/week; 16 hours/day | ND | 5,000; (2,857) | Decreased body weight (20–30%) (serious LOAEL) | De Martino et al. 1987
Rats (Sprague-Dawley, F) | 14 days (GDs 6–19); 20 hours/day | 1,000; (833) | 5,000; (4,167) | Decreased body weight (10% in pregnant dams, 12% in virgin females) | NIEHS 1987

ADJ = adjusted for continuous exposure; F = females; GD = gestation day; LOAEL = lowest-observed-adverse-effect level; M = males; ND = not determined; NOAEL = no-observed-adverse-effect level

Summary of the Principal Study:

NIEHS. 1987. Inhalation developmental toxicology studies: Teratology study of n-hexane in rats: Final report. Washington, DC: National Institute of Environmental Health Sciences. DE88006812. PNL-645. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/DE88006812.xhtml. October 20, 2022.

Timed-pregnant (30/group) and virgin (10/group) Sprague-Dawley rats were exposed to 0, 200, 1,000, or 5,000 ppm n-hexane vapor for 20 hours/day for 14 days (GDs 6–19 for pregnant females). All animals were observed daily for mortality, morbidity, and overt signs of toxicity. Adult body weights were monitored throughout the study and at sacrifice (GD 20 for pregnant rats). Uterine, placental, and fetal body weights were measured from pregnant females. Reproductive/developmental parameters evaluated included number of implants, early or late resorptions, number of live fetuses, number of dead fetuses, sex ratios, fetal weight, and malformations.

No maternal deaths or clinical signs of toxicity were observed. Statistically significantly decreased body weights were observed in pregnant and virgin females at 5,000 ppm. Extra-gestational body weight gain (weight gain minus the weight of the gravid uterus) was also statistically significantly decreased at 5,000 ppm. Exposure to n-hexane had no effect on the number of implantations, live pups per litter, resorptions per litter, fetal sex ratio, intrauterine death rate, or fetal or skeletal malformations. Fetal body weights were decreased at 1,000 ppm (7.5% for male offspring). At 5,000 ppm, decreased body weights were observed in males and females combined (15%), in males only (15%) and in females only (14%) (Table A-2).

Table A-2 Average Fetal Weights Following Maternal Inhalation Exposure to n-Hexane

Exposure concentration | 0 | 200 ppm | 1,000 ppm | 5,000 ppm
Fetuses examined | 339 | 350 | 392 | 408
Sex ratio (M/F) | 0.53±0.14^a^ | 0.48±0.11 | 0.46±0.17 | 0.54±0.14
Fetal body weight (g) | 3.48±0.37 | 3.54±0.36 | 3.27±0.32^b^ | 2.97±0.38^b^
Male fetal body weight (g) | 3.60±0.39 | 3.66±0.39 | 3.33±0.33^b^ | 3.05±0.41^b^
Female fetal body weight (g) | 3.33±0.37 | 3.43±0.37 | 3.23±0.32 | 2.86±0.36^b^

a Mean±standard deviation.

b Statistically significantly different from controls at p<0.05.

F = female; M = male

Source: NIEHS 1987

Selection of the Point of Departure for the MRL: Benchmark dose (BMD) modeling of the male fetal body weight data could not be attempted because the number of male fetuses was not reported. The NOAEL of 200 ppm for developmental effects (decreased male fetal body weights) in rats exposed for 20 hours/day on GDs 6–19 (NIEHS 1987) was selected as the point of departure (POD) for the MRL.

Adjustment for Intermittent Exposure: The intermittent 20 hours/day NOAEL of 200 ppm was adjusted to a 24-hour continuous exposure using the following equation:

N O A E L_A D J_ = N O A E L × (20 h o u r s)/(24 h o u r s) = 200 p p m × (20 h o u r s)/(24 h o u r s) = 167 p p m

Human Equivalent Concentration: The human equivalent concentration (HEC) was calculated by multiplying the NOAEL_ADJ_ by the ratio of the n-hexane air:blood partition coefficient for humans and rats. The reported blood:gas (air) partition coefficient (H_b/g_) values for n-hexane are 2.29 for rats (Gargas et al. 1989) and 0.8 for humans (Perbellini et al. 1985). Since the ratio of the rat to human blood:gas (air) partition coefficients is >1, a default value of 1 was used.

N O A E L_H E C_ = N O A E L_A D J_ × ((H_b / g_)_A_)/((H_b / g_)_H_) = 167 p p m × 1 = 167 p p m

Uncertainty Factor: The NOAEL_HEC_ was divided by a total uncertainty factor of 30:

- 3 for extrapolation from animals to humans with dosimetric adjustments
- 10 for human variability

M R L = N O A E L_H E C_ ÷ U F s 167 p p m ÷ 30 = 5.56 p p m ≈ 6 p p m

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Selection of decreased fetal weight in rats as the critical effect is supported by several other studies using similar or higher concentrations or longer durations that also observed effects on fetal weight (Bus et al. 1979; Stoltenburg-Didinger et al. 1990). Additionally, a positive association was observed between ambient n-hexane exposure (represented as a unitless exposure intensity) and low birth weight (OR 1.06) in a case-control study in Texas (Gong et al. 2018).

Agency Contacts (Chemical Managers): Obaid Faroon

## n-Hexane Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | n-Hexane
CAS Number: | 110-54-3
Date: | April 2025
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate
MRL: | 0.4 ppm (1.4 mg/m^3^)
Critical Effects: | Lesions in the nasal cavity (multifocal regeneration and metaplasia in olfactory epithelium)
Reference: | NTP 1991
Point of Departure: | LOAEL of 1,099 ppm (LOAEL_HEC_ of 111 ppm)
Uncertainty Factor: | 300
LSE Graph Key: | 43
Species: | Mouse

MRL Summary: An intermediate-duration inhalation MRL of 0.4 ppm was derived for n-hexane based on a LOAEL of 1,099 ppm for respiratory effects (nasal cavity lesions) in mice exposed for 22 hours/day, 5 days/week for 13 weeks (NTP 1991). The LOAEL was duration adjusted to continuous duration exposure, converted to a human equivalent concentration (LOAEL_HEC_) of 111 ppm, and divided by a total uncertainty factor of 300 (10 for use of a LOAEL, 3 for extrapolation from animals to humans with dosimetric adjustments, and 10 for human variability).

Selection of the Critical Effect: Several studies have evaluated the intermediate-duration toxicity of inhaled n-hexane. A summary of the identified LOAELs is presented in Table A-3. The lowest LOAELs were identified for renal, neurological, musculoskeletal, body weight, and developmental effects with respiratory and reproductive effects observed at higher concentrations. One of the lowest LOAELs identified was 500 ppm for increased relative kidney weights and chronic nephritis in male rats exposed for 22 hours/day, 7 days/week for 6 months (API 1981). The study authors were unable to determine whether exposure to n-hexane exacerbated the normal age-related process observed in controls or caused a unique injury. High background rates of chronic nephropathy are commonly observed in male Sprague-Dawley rats and complicate its use as the critical effect. Additionally, the renal system is not a known target of n-hexane exposure, and several other rat and mouse studies have failed to identify a similar response (API 1978; Cavender et al. 1984; NTP 1991). Therefore, the renal effects were not selected as the critical effect for derivation of an intermediate-duration inhalation MRL.

The next lowest LOAELs identified were for neurological endpoints, which are a common outcome following inhalation exposure to n-hexane. Rats (sex not specified) exposed to 400–600 ppm n-hexane continuously for 42–162 days developed central and peripheral neuropathy, footdrop, waddling gait, and limb weakness, while histopathology revealed swollen axons and axonal degeneration (Schaumburg and Spencer 1976). Male rats exposed to 500 ppm for 22 hours/day, 7 days/week for 9 weeks presented with clinical signs of neurotoxicity (narcosis, paralysis) and histopathology (axonal swellings, myelin degradation), while rats exposed to 700 ppm for 8 hours/day, 7 days/week for 40 weeks only had axonal swelling (Altenkirch et al. 1982). Other studies have also shown neurological effects at 500 ppm, with abnormal gait and peripheral neuropathy in male rats exposed for 22 hours/day, 7 days/week for 6 months (API 1981), and decreased grip strength in male rats exposed for 24 hours/day, 5 days/week for 10 weeks (Rebert and Sorenson 1983). While there is consistent evidence of neurological effects, the calculated HECs for these effects were higher than those for respiratory nasal effects; thus, neurological effects were not selected as the critical effect for MRL derivation.

Table A-3 Selected NOAEL and LOAEL Values Following Intermediate-Duration Inhalation Exposure to n-Hexane

Species (strain, sex) | Duration | NOAEL (NOAEL_ADJ_) (ppm) | LOAEL (LOAEL_ADJ_) (ppm) | Effect | Reference
Renal effects
Rats (Sprague-Dawley, M) | 6 months; 7 days/week; 22 hours/day | ND | 500; (458) | Increased kidney weight, chronic nephropathy | API 1981
Respiratory effects
Mice (B6C3F1, B) | 13 weeks; 5 days/week; 22 hours/day | ND | 1,099; (719) | Lesions in the nasal cavity (multifocal regeneration and metaplasia in olfactory epithelium) | NTP 1991
Rabbit (New Zealand) | 24 weeks; 5 days/week; 8 hours/day | ND | 3,000; (714) | Upper respiratory tract irritation (nasal discharge and salivation), respiratory difficulties (gasping, lung rales, mouth breathing), histopathology (centrilobular emphysema, pulmonary fibrosis, goblet cell metaplasia, epithelial desquamation) | Lungarella et al. 1984
Mice (B6C3F1, B) | 13 weeks; 5 days/week; 6 hours/day | 1,109 F; (198); 4,421 M; (789) | 4,421 F; (789); 10,000 M; (1,786) | Lesions in the nasal cavity (multifocal regeneration and metaplasia in the olfactory epithelium) | NTP 1991
Neurological effects
Rats (Wistar, M) | 40 weeks; 7 days/week; 8 hours/day | ND | 700; (233) | Axonal swelling in the spinal cord | Altenkirch et al. 1982
Rats (Fischer-344, M) | 11 weeks; 5 days/week; 24 hours/day | ND | 500; (357) | Decreased grip strength | Rebert and Sorenson 1983
Rats (Sprague-Dawley, NS) | 45 days; continuously | ND | 400–600 | Central and peripheral neuropathy, footdrop, waddling gait, limb weakness, swollen axons, axonal degeneration | Schaumburg and Spencer 1976
Rats (Wistar, M) | 9 weeks; 7 days/week; 22 hours/day | ND | 500; (458) | SLOAEL: Clinical signs (narcosis, paralysis), multifocal giant axonal swellings, primarily in the calf muscles, breakdown of axons, and myelin degradation | Altenkirch et al. 1982
Rats (Sprague-Dawley, M) | 6 months; 7 days/week; 22 hours/day | ND | 500; (458) | Abnormal gait, peripheral nerve atrophy | API 1981
Rats (Wistar, M) | 16 weeks; 7 days/week; 12 hours/day | 500; (250) | 1,200; (600) | Decreased grip strength and motor nerve conduction velocity, paranodal swelling, demyelination, and remyelination of the peripheral nerve | Huang et al. 1989
Mice (B6C3F1, B) | 13 weeks; 5 days/week; 22 hours/day | ND | 1,099; (719) | Decreased locomotor activity (females), paranodal swellings in tibial nerve | NTP 1991
Rats (Wistar, F) | 63 days (GD 1–PND 42); 7 days/week; 23 hours/day | ND | 800; (767) | Hindlimb weakness | Stoltenburg-Didinger et al. 1990
Rats (Wistar, M) | 20 weeks; 6 days/week; 12 hours/day | ND | 2,000; (857) | Decreased motor conduction velocity | Ichihara et al. 1998
Rats (Sprague-Dawley, M) | 30 weeks; 6 days/week; 10 hours/day | 500; (179) | 2,500; (892) | Tibial nerve axonal degeneration | Frontali et al. 1981
Rats (Fischer-344, M) | 11 weeks; 7 days/week (4 weeks); 6 days/week (7 weeks); 24 hours/day | ND | 1,000; (914) | Decreased hindlimb and forelimb strength, and ataxia, increased action potential latency, and increased brainstem auditory-evoked response | Howd et al. 1983
Rats (Fischer-344, M) | 13 weeks; 5 days/week; 6 hours/day | 3,000; (536) | 6,500; (1,160) | Axonopathy in the sciatic nerve | Cavender et al. 1984
Rats (Fischer-344, M) | 14 weeks; 7 days/week; 14 hours/day | ND | 2,000; (1,167) | Decreased limb grip strength, startle response, and motor activity; increased evoked potential latencies | Pryor et al. 1983
Rats (Sprague-Dawley, M) | 14 weeks; 5 days/week; 9 hours/day | 1,500; (402) | 5,000; (1,339) | Tibial nerve axonal degeneration | Frontali et al. 1981
Rats (Wistar, M) | 16 weeks; 7 days/week; 12 hours/day | ND | 3,040; (1,520) | Gait disturbances, decreased motor and mixed nerve conduction velocity, axonal swelling, neurofilament accumulation, denervated neuromuscular junctions | Takeuchi et al. 1980
Mice (B6C3F1, B) | 13 weeks; 5 days/week; 6 hours/day | 4,421; (789) | 10,000; (1,785) | Decreased locomotor activity (females), paranodal swellings in tibial nerve | NTP 1991
Rats (Wistar, F) | 20 days (GD 1-20); 4 hours/day | 2,500; (417) | 12,500; (2,083) | Irritability, aggression | Li et al. 2014
Rats (Sprague-Dawley, M) | 6 weeks; 6 days/week; 16 hours/day | ND | 5,000; (2,857) | SLOAEL: Decreased motor conduction velocity, peripheral neuropathy, and paralysis | De Martino et al. 1987
Musculoskeletal effects
Rats (Sprague-Dawley, M) | 6 months; 7 days/week; 22 hours/day | ND | 500; (458) | Skeletal muscle atrophy | API 1981
Rats (Sprague-Dawley, M) | 61 days; 7 days/week; 18 hours/day | ND | 1,000; (750) | Hindlimb muscular atrophy | Nylen et al. 1989
Rats (Sprague-Dawley, M) | 28 days; 7 days/week; 21 hours/day | ND | 1,000; (875) | Hindlimb muscular atrophy | Nylen et al. 1989
Rats (Wistar, M) | 16 weeks; 7 days/week; 12 hours/day | ND | 3,040; (1,520) | Muscular atrophy, denervation, irregular fibers, and disordered myofilaments | Takeuchi et al. 1980
Reproductive effects
Rats (Sprague-Dawley, M) | 61 days; 7 days/week; 18 hours/day | ND | 1,000; (750) | Testicular atrophy | Nylen et al. 1989
Rats (Sprague-Dawley, M) | 28 days; 7 days/week; 21 hours/day | ND | 1,000; (875) | Testicular atrophy | Nylen et al. 1989
Rats (Sprague-Dawley, M) | 6 weeks; 6 days/week; 16 hours/day | ND | 5,000; (2,857) | Testicular lesions (spermatocyte necrosis, exfoliation of spermatids, and Sertoli cell vacuolization) | De Martino et al. 1987
Developmental effects
Rats (Wistar, F) | 21 days (GDs 1–21); 7 days/week; 23 hours/day | ND | 500; (479) | Decreased fetal body weight (22% at 9 days after birth), delayed histogenesis of the cerebellar cortex | Stoltenburg-Didinger et al. 1990
Rats (Wistar, F) | 20 days (GDs 1–20); 7 days/week; 4 hours/day | 2,500; (417) | 12,500; (2,083) | SLOAEL: Decreased live pups/litter, decreased percentage of secondary follicles, increased atretic follicles, and alterations in oestrus cycle in female offspring | Li et al. 2014, 2015

ADJ = adjusted for continuous exposure; B = both sexes; F = females; GD = gestation day; LOAEL = lowest-observed-adverse-effect level; M = males; ND = not determined; NOAEL = no-observed-adverse-effect level; NS = not specified; PND = postnatal day; SLOAEL = serious LOAEL

Decreased fetal body weights were observed following maternal exposure to 500 ppm (Stoltenburg-Didinger et al. 1990). Body weight and musculoskeletal effects were also observed at exposures between 500 and 1,000 ppm, but these effects were not considered critical effects for MRL derivation because they are thought to be secondary outcomes following injury to the primary neurological targets of n-hexane. Muscular atrophy and limb weakness have been shown to result from denervation in the extremities (Nylen et al. 1989; Takeuchi et al. 1980), and loss of body weight is often observed along with decreased food intake, possibly due to an underlying effect resulting in the animal’s refusal or inability to eat normally. At concentrations of 1,000 ppm, respiratory effects have been observed. In male and female mice, exposure to 1,099 ppm n-hexane for 22 hours/day, 5 days/week for 13 weeks resulted in nasal cavity lesions, including multifocal regeneration, and metaplasia in olfactory epithelium (NTP 1991). Similar results were not observed in two rat studies, suggesting that mice may be more susceptible than rats to point-of-entry effects from n-hexane inhalation.

Taken together, the data suggest that respiratory, developmental, and neurological effects are the most sensitive targets following intermediate-duration inhalation exposure to n-hexane. A comparison of the HECs of the LOAELs (LOAEL_HEC_) for these endpoints is presented in Table A-4. The lowest LOAEL_HEC_ value is 111 ppm for nasal lesions in mice exposed for 22 hours/day (NTP 1991). Thus, nasal lesions were selected as the critical effect.

Table A-4 Potential PODs Following Intermediate-Duration Inhalation Exposure to n-Hexane

Species | Exposure | LOAEL (ppm) | LOAEL_ADJ_ (ppm) | LOAEL_HEC_ (ppm) | Effect (Reference)
Respiratory effects
Mice | 22 hours/day; 5 days/week | 1,099 | 719 | 111 | Nasal cavity lesions (NTP 1991)
Mice | 6 hours/day; 5 days/week | 4,421 | 789 | 122 | Nasal cavity lesions (females only) (NTP 1991)
Neurological effects
Rats | 8 hours/day; 7 days/week | 700 | 233 | 233 | Axonal swelling in the spinal cord (Altenkirch et al. 1982)
Rats | 24 hours/day; 5 days/week | 500 | 357 | 357 | Decreased grip strength (Rebert and Sorenson 1983)
Developmental effects
Rats | 23 hours/day; 7 days/week | 500 | 479 | 479 | Decreased pup body weight (Stoltenburg-Didinger et al. 1990)

ADJ = adjusted; HEC = human equivalent concentration; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; POD = point of departure

Selection of the Principal Study: Few studies have evaluated respiratory effects following intermediate-duration inhalation exposure to n-hexane. Although rats appear to be more sensitive to n-hexane-induced neurotoxicity than mice, inhalation exposure studies in rats have failed to produce respiratory effects, suggesting that mice may be more sensitive to respiratory effects than rats. Male and female mice exposed to 1,099 ppm n-hexane for 22 hours/day, 5 days/week for 13 weeks presented with nasal cavity lesions (NTP 1991). In contrast, no histopathology was observed in the nasal cavity of male and female rats exposed up to 10,000 ppm for 6 hours/day, 5 days/week for 13 weeks (Cavender et al. 1984), or in male rats exposed to 500 ppm for 22 hours/day, 7 days/week for 6 months (API 1981).

Summary of the Principal Study:

NTP. 1991. Toxicity studies of n-hexane in B6C3F1 (inhalation studies). Research Triangle Park, NC: National Toxicology Program. PB91185322. NIH Publication No. 91-3121 https://ntp.niehs.nih.gov/ntp/htdocs/st_rpts/tox002.pdf. July 25, 2022.

Dunnick JK, Graham DG, Yang RS, . 1989. Thirteen-week toxicity study of n-hexane in B6C3F1 mice after inhalation exposure. Toxicology 57(2):163–172. 10.1016/0300483x(89)90162-5.2749745

Male and female B6C3F_1_ mice (18/sex/group) were exposed to n-hexane for 6 hours/day, 5 days/week for 13 weeks at concentrations of 0, 500, 1,000, 4,000, or 10,000 ppm (mean analytical concentrations of 0, 580, 1,109, and 4,421 ppm; analytical concentration not reported for the 10,000-ppm exposure level). An additional group of mice (18/sex/group) was exposed to 1,000 ppm n-hexane for 22 hours/day, 5 days/week for 13 weeks (mean analytical concentration of 1,099 ppm). The core set of animals (10/sex/group) were evaluated for body weights, clinical signs of toxicity, and a complete histopathological assessment. The remaining animals (8/sex/group) were evaluated in a series of neurobehavior and neuropathology studies, including undifferentiated motor activity, forelimb and hindlimb grip strengths, thermal sensitivity, startle response, and foot splay. Four males and four females were randomly selected from the 0, 1,099 (22 hours/day), and 10,000 ppm groups for evaluation of spinal cord and tibial nerve.

Core group: Exposure up to 10,000 ppm for 6 hours/day or 1,099 ppm for 22 hour/day had no effect on survival or clinical signs of toxicity. Body weights were decreased in male mice exposed to either 10,000 ppm n-hexane for 6 hours/day (17% decrease) or to 1,099 ppm for 22 hours/day (10% decrease), but not in female mice comparably exposed. Sneezing was seen in males and females exposed to 10,000 ppm beginning at week 4 and continuing until the end of the study. Histopathologic evaluations revealed exposure-related lesions in the nasal cavities of male and female mice at 1,099 ppm (22 hours/day) and in female mice at 4,421 ppm. Multifocal regeneration and metaplasia of the olfactory epithelium were the most common lesions observed in both male and female mice. Higher concentrations resulted in more significant damage, including epithelial erosion, subacute inflammation, and focal fibrosis of the submucosa. No other histopathological effects outside of the nasal cavity were observed.

Neurological group: The only neurobehavioral finding observed was a decrease in locomotor activity in female mice at 1,099 (22 hours/day) and 10,000 ppm. Paranodal swellings in the tibial nerve were observed in 6/8 mice exposed to 1,099 (22 hours/day) and 10,000 ppm. Nerve damage at 1,099 ppm for 22 hours/day was similar to that observed at 10,000 ppm for 6 hours/day, suggesting that continuous exposure to n-hexane is more toxic than intermittent exposure.

Selection of the Point of Departure for the MRL: Lesions in the nasal cavity were observed in male and female mice at 1,099 ppm (22 hours/day) and in female mice at 4,421 ppm (6 hours/day), with continuous-adjusted LOAEL_ADJ_ values of 719 and 789 ppm, respectively. The LOAEL value was selected as the POD. BMD modeling was not conducted because only one concentration was evaluated at this exposure duration.

Adjustment for Intermittent Exposure: The intermittent 22-hours/day, 5 days/week LOAEL of 1,000 ppm was adjusted to a 24-hour, 7 day/week continuous exposure using the following equation:

L O A E L_A D J_ = L O A E L × (22 h o u r s)/(24 h o u r s) × (5 d a y s)/(7 d a y s) 1,099 p p m × (22 h o u r s)/(24 h o u r s) × (5 d a y s)/(7 d a y s) = 719 p p m

Human Equivalent Concentration: The HEC was calculated by multiplying the LOAEL_ADJ_ by the regional gas dose ratio (RGDR). The RGDR for extrathoracic respiratory tract effects was calculated using the following equation:

R G D R_E T_ = (((V_E_)/(S A_E T_))_A_)/(((V_E_)/(S A_E T_))_H_)

Where:

- RGDR_ET_ = extrathoracic regional gas dose ratio (animal: human)
- V_E_ = minute volume (based on body weight)
- SA_ET_ = surface area of the extrathoracic region
- A = animal
- H = human

The human minute volume (13,800 mL/minute) and extrathoracic surface area (200 cm^2^) are provided in EPA (1994b) along with the extrathoracic surface area in mice (3 cm^2^). The mouse minute volume (32 mL/minute) was calculated based on the body weights reported in the study (males 30 g, females 25.4 g, average 27.7 g) (NTP 1991).

L O A E L_H E C_ = L O A E L_A D J_ × R G D R_E T_ L O A E L_H E C_ = 719 p p m × (((32 m l / m i n)/(3 c m^2^)))/(((13,800 m l / m i n)/(200 c m^2^))) = 719 p p m × 0.1546 = 111 p p m

Uncertainty Factor: The LOAEL_HEC_ was divided by a total uncertainty factor of 300:

- 10 for extrapolation from a LOAEL
- 3 for extrapolation from animals to humans with dosimetric adjustments
- 10 for human variability

M R L = L O A E L_H E C_ ÷ U F s 111 p p m ÷ 300 = 0.37 p p m ≈ 0.4 p p m

Other Additional Studies or Pertinent Information that Lend Support to this MRL: The principal study (NTP 1991) was the only study located that examined respiratory histopathology in mice following n-hexane exposure. No histopathological effects have been observed in the nasal cavities of rats exposed to n-hexane at concentrations up to 10,000 ppm for 6 hours/day or 500 ppm for 22 hours/day (API 1981; Cavender et al. 1984), although the exposure duration or concentration may not have been high enough to elicit a response. Pulmonary effects have also been observed. Relative lung weights were increased in male rats exposed to 1,000 ppm for 24 hours/day, 6–7 days/week for 11 weeks. However, histology was not performed on the lungs nor the nasal cavity (Howd et al. 1983). Male rabbits exposed to 3,000 ppm for 8 hours/day, 5 days/week for 24 weeks showed signs of respiratory irritation, breathing difficulties, and respiratory track histopathology (centrilobular emphysema, pulmonary fibrosis, goblet cell metaplasia, epithelial desquamation) (Lungarella et al. 1984). Since the NTP (1991) mouse study had the lowest LOAEL_HEC_ for respiratory effects, it was chosen as the principal study.

Neurological effects are the most sensitive outcome evaluated and identified following inhalation exposure to n-hexane; however, the MRL based on neurological effects would be higher due to the dosimetric adjustment for systemic effects. Therefore, the MRL based on nasal effects is protective of neurological effects.

Agency Contacts (Chemical Managers): Obaid Faroon

## n-Hexane Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | n-Hexane
CAS Numbers: | 110-54-3
Date: | April 2025
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: The database was not considered adequate for derivation of a chronic-duration inhalation MRL for n-hexane. Although there is a large database describing neurological effects in occupational workers resulting from inhalation exposure to n-hexane, these studies lack exposure information, or the exposure is confounded by additional compounds that exacerbate n-hexane-induced neurological effects. Only a single chronic-duration animal study was located that examined the reproductive toxicity of inhaled n-hexane (Leydig cell hyperplasia), but the study did not evaluate other potential sensitive targets such as neurological or respiratory outcomes, so it was not considered sufficient for deriving a chronic-duration MRL.

Rationale for Not Deriving an MRL: The neurotoxicity of n-hexane was first observed in the shoe industries of Japan and Italy in the 1960s and early 1970s. A number of epidemiological studies were initiated in response to outbreaks of apparent peripheral neuropathy in shoe workers. While the clinical course of the disease was well described, elucidation of a dose-response relationship has been difficult. In most cases, concentrations of n-hexane in the workplace air were not measured until after disease developed. Also, in almost all cases, workers were concurrently exposed to other chemicals which may have affected their response to n-hexane.

Few human studies are available that have the exposure and duration information needed to identify a point of departure. Sanagi et al. (1980) evaluated motor nerve conduction velocity in 14 occupationally exposed workers employed in a factory producing tungsten carbide alloys. Personal monitors reported mean 8-hour time weighted concentrations of n-hexane (58 ppm) and acetone (39 ppm); no other “solvent vapors” were detected. Chang et al. (1993) reported alterations in motor and sensory nerve amplitudes and latencies in printing press workers diagnosed with peripheral neuropathy. Mean concentrations of n-hexane were 63 ppm (background, 30–110 ppm) and 132 ppm (personal samplers, 80–210 ppm), although toluene and isopropyl alcohol were also measured, and additional exposures to lead, toluene, mercury, and diesel were also possible from the solvents used. Mutti et al. (1982a, 1982b) also identified electroneurographic abnormalities in shoe factory workers exposed to n-hexane near the recommended threshold limit value, but additional contaminants measured in the breathing zone included cyclohexane, MEK, and ethyl acetate. A study of oil spill workers found an association between cumulative n-hexane exposure and vibrotactile threshold (Chen et al. 2023a, 2023b); as with the other studies, the workers were exposed to other contaminants including benzene, toluene, ethylbenzene, and xylenes.

Several studies suggest that co-exposures to chemicals including acetone, toluene, and MEK may enhance n-hexane metabolism and neurotoxicity (Altenkirch et al. 1977, 1982; Ladefoged et al. 1989, 1994; Ladefoged and Perbellini 1986; Nylen et al. 1994; Nylen and Hagman 1994; Patten et al. 1986; Robertson et al. 1989; Zhao et al. 1998). Due to the known co-exposure to and potential interactions with acetone, the available human studies were not considered adequate for the development of a chronic-duration inhalation MRL. A single chronic-duration animal study examined the male reproductive toxicity of inhaled n-hexane (Imai and Omoto 1999). Leydig cell hyperplasia and benign Leydig cell tumors were observed in male rats exposed to 1,000 ppm n-hexane for 60 weeks, but this study was not considered adequate due to poor reporting and the lack of supporting studies suggesting that Leydig cells are a target of n-hexane exposure. Additionally, this study did not evaluate any other potential targets of n-hexane exposure such as neurotoxicity or respiratory effects. Therefore, a chronic-duration inhalation MRL was not derived.

Agency Contacts (Chemical Managers): Obaid Faroon

## n-Hexane Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | n-Hexane
CAS Numbers: | 110-54-3
Date: | April 2025
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: The database was not considered adequate for derivation of an acute-duration oral MRL for n-hexane. There is limited information on the toxicity of n-hexane following acute oral exposure. The only nonlethal effect is developmental toxicity (decreased fetal weight); however, increased maternal mortality has been observed at lower doses.

Rationale for Not Deriving an MRL: Three studies have evaluated the acute oral toxicity of n-hexane (Kimura et al. 1971; Linder et al. 1992; Marks et al. 1980). A LOAEL of 7,920 mg/kg/day was identified in mice for decreased fetal weight following oral exposure 3 times/day on GDs 6–15 (10 days) (Marks et al. 1980). In this same dosing regime, a non-statistically significant increase in dam mortality (9%) was observed at 2,830 mg/kg/day. The remaining two studies evaluated the potential reproductive toxicity of oral n-hexane exposure but did not identify an effect for any outcome. None of the acute-duration oral studies examined non-reproductive or developmental endpoints, particularly potential neurotoxicity, which is a known sensitive target of n-hexane.

Agency Contacts (Chemical Managers): Obaid Faroon

## n-Hexane Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | n-Hexane
CAS Number: | 110-54-3
Date: | April 2025
Profile Status: | Final
Route: | Oral
Duration: | Intermediate
MRL: | 0.1 mg/kg/day
Critical Effects: | Neurological effects (impaired performance on a test of memory)
Reference: | Gao et al. 2019
Point of Departure: | LOAEL of 43.5 mg/kg/day
Uncertainty Factor: | 300
LSE Graph Key: | 12
Species: | Mouse

MRL Summary: An intermediate-duration oral MRL of 0.1 mg/kg/day was derived for n-hexane based on neurobehavioral effects (impaired performance on a test of memory) in mice administered via gavage 43.5 mg/kg/day for 20 consecutive days (Gao et al. 2019). The minimal LOAEL of 43.5 mg/kg/day was divided by a total uncertainty factor of 300 (3 for the use of a minimal LOAEL, 10 for extrapolation from animals to humans, and 10 for human variability).

Selection of the Critical Effect: Several intermediate-duration studies examining the oral toxicity of n-hexane are available. A summary of the identified LOAELs is presented in Table A-5. Exposure to 43.5 mg/kg/day resulted in neurobehavioral effects and neuromuscular effects were observed at ≥1,000 mg/kg/day. Other observed adverse effects include decreased body weight gain at ≥570 mg/kg/day and reproductive effects at 4,000 mg/kg/day. Neurological effects were chosen as the critical effect because they occurred at the lowest adverse effect level and the endpoint is well supported by epidemiological and animal studies involving inhalation exposure.

Selection of the Principal Study: Several studies are available that evaluated neurological effects following intermediate-duration oral exposure to n-hexane. The lowest adverse effect level of 43.5 mg/kg/day was identified in the Gao et al. (2019) mouse study. At higher doses, signs of clinical neurotoxicity (transient paralysis, abnormal gait, decreased rotarod latency) and decreased motor nerve conduction velocity were observed (Krasavage et al. 1980; Li et al. 2018, 2020a, 2020b; Ono et al. 1981; Wang et al. 2017). The Gao et al. (2019) study was selected as the principal study because it identified the lowest LOAEL for neurological effects.

Table A-5 Available NOAEL and LOAEL Values Following Intermediate-Duration Oral Exposure to n-Hexane

Species (strain, sex) | Duration | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Body weight effects
Rats (COBS, M) | 90 days; 5 times/week | ND | 570 | Decreased body weight (15%) | Krasavage et al. 1980
Rats (Wistar, M) | 24 weeks; 7 times/week | 500 | 1,000 | Decreased body weight (19%) | Li et al. 2020b
Rats (Wistar, M) | 10 weeks; 6 times/week | 1,000 | 2,000 | Decreased body weight (19%) | Li et al. 2018
Rats (Wistar, M) | 7 weeks; 7 times/week | ND | 3,000 | SLOAEL: Decreased body weight (23%) | Li et al. 2020a
Neurological effects
Mice (Kunming, M, F) | 20 days; 7 times/week | ND | 43.5 | Impaired response on test of learning and memory (Y-maze) | Gao et al. 2019
Rats (Wistar, M) | 24 weeks; 7 times/week | 500 | 1,000 | Transient paralysis, abnormal gait, decreased ability to stay on a rotating rod and motor nerve conduction velocity | Li et al. 2020b
Rats (Wistar, M) | 8 weeks; 7 times/week | ND | 1,000 | Decreased motor and mixed nerve conduction velocity | Ono et al. 1981
Rats (Wistar, M) | 10 weeks; 6 times/week | 1,000 | 2,000 | Abnormal gait, decreased ability to stay on rotating rod | Li et al. 2018
Rats (Wistar, M) | 7 weeks; 7 times/week | ND | 3,000 | SLOAEL: Paralysis | Li et al. 2020a
Rats (Wistar, M) | 8 weeks; 7 times/week | ND | 3,000 | Decreased grip strength, abnormal gait | Wang et al. 2017
Rats (COBS, M) | 90 days; 5 times/week | 1,140 | 4,000 | SLOAEL: Hindlimb paralysis, axonal swelling, myelin retraction | Krasavage et al. 1980
Reproductive effects
Rats (COBS, M) | 90 days; 5 times/week | 1,140 | 4,000 | SLOAEL: Testicular atrophy of the germinal epithelium | Krasavage et al. 1980

F = females; LOAEL = lowest-observed-adverse-effect level; M = males; ND = not determined; NOAEL = no-observed-adverse-effect level; SLOAEL = serious LOAEL

Summary of the Principal Study:

Gao J, Zhang X, Lin Q, . 2019. Changes to learning and memory ability and the expression of NGF/NGF-R mRNA in the brain tissue of mice exposed to n-hexane. Chin J Ind Hyg Occup Dis. 37:217–221.

Groups of 10 Kunming mice (presumably 5 males and 5 females) were administered n-hexane via gavage at 0, 43.5, 86.5, or 173.0 mg/kg/day for 20 days. Learning and memory were evaluated using a Y-maze test. The test was conducted on 2 consecutive days (the day after exposure completion and 24-hours later), the first day to assess learning and the second day to assess memory recall ability.

The investigators noted that decreased activity and reduced food intake were observed in the exposed groups beginning after exposure day 4; more pronounced symptoms were observed in the 173.0 mg/kg/day group. However, no incidence or frequency data were provided. The investigators also noted that the mean body weight, presumably in the 173.0 mg/kg/day group, was decreased by 2.1 g; no additional information was provided. On the first test (learning), significant decreases in the correct response rate were observed in the 86.5 and 173.0 mg/kg/day groups; no statistically significant alterations in total electric shock time or total training sessions were observed. In the second test (memory), significant increases in total electric shock time and decreases in correct response rate were observed in all three groups. Significant decreases in nerve growth factor (NGF) and nerve growth factor receptor (NGF-R) concentrations were observed at 173.0 and 86.5 mg/kg/day, respectively. Decreased levels of NGF messenger ribonucleic acid (mRNA) and NGF-R mRNA levels were also observed at 43.5 and 86.5 mg/kg/day, respectively.

Selection of the Point of Departure for the MRL: The minimal LOAEL of 43.5 mg/kg/day for impaired performance on a test of memory in mice administered n-hexane for 20 days was selected as the POD for the MRL. BMD modeling was not conducted because it is unclear whether values presented in Table 2 of the paper are the mean±standard deviation or mean±standard error of the mean. Therefore, the NOAEL/LOAEL approach was used.

Uncertainty Factor: The NOAEL is divided by a total uncertainty factor of 300:

- 3 for the use of a minimal LOAEL
- 10 for extrapolation from animals to humans
- 10 for human variability

M R L = L O A E L ÷ U F s 43.5 m g / k g / d a y ÷ 300 = 0.1 m g / k g / d a y

The 43.5 mg/kg/day dose was considered a minimal LOAEL because overt signs of neurotoxicity were not observed at this dose level.

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Several studies are available with similar LOAELs and critical effects (Li et al. 2018; Ono et al. 1981), while more serious neurological signs including lasting paralysis have been observed at higher concentrations (Krasavage et al. 1980; Li et al. 2020a). Additionally, body weight changes occurred at the same dose as the selected LOAEL, so this MRL is protective against decreased body weight as well.

Agency Contacts (Chemical Managers): Obaid Faroon

## n-Hexane Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | n-Hexane
CAS Numbers: | 110-54-3
Date: | April 2025
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: The database was not considered adequate for derivation of a chronic-duration oral MRL for n-hexane.

Rationale for Not Deriving an MRL: No studies were located that describe the effects of chronic-duration oral exposure to n-hexane in humans or animals.

Agency Contacts (Chemical Managers): Obaid Faroon