# CHAPTER 8 REFERENCES

Abdo KM, Grumbein S, Chou BJ, . 2001. Toxicity and carcinogenicity study in F344 rats following 2 years of whole-body exposure to naphthalene vapors. Inhal Toxicol 13(10):931–950. 10.1080/089583701752378179.11696867
Adkins B, Van Stee EW, Simmons JE, . 1986. Oncogenic response of strain A/J mice to inhaled chemicals. J Toxicol Environ Health 17(2–3):311–322. 10.1080/15287398609530825.3083111
Agarry SE, Oghenejoboh KM. 2015. Enhanced aerobic biodegradation of naphthalene in soil: kinetic modelling and half-life study. Int J Environ Bioremediat Biodegrad 3(2):48–53. 10.12691/ijebb-3-2-2.
Agarwal P, Anand M, Chakraborty P, . 2022. Placental levels of polycyclic aromatic hydrocarbons (PAHs) and their association with birth weight of infants. Drug Chem Toxicol 45(2):868–877. 10.1080/01480545.2020.1783285.32597233
Ahmad R, Amir SH, Khan SA. 2019. Naphthalene mothballs poisoning leading to intravascular hemolysis: A case report. J Emerg Med 58(1):e1–e3. 10.1016/j.jemermed.2019.09.047.31744706
Akash S, Sivaprakash B, Rajamohan N, . 2023. Biotransformation as a tool for remediation of polycyclic aromatic hydrocarbons from polluted environment - review on toxicity and treatment technologies. Environ Pollut 318:120923. 10.1016/j.envpol.2022.120923.36566676
Aktay G, Cengiz G, Söylemezoğlu T. 2000. Protective effect of nitrendipine on naphthalene-induced oxidative stress. J Fac Pharm Gazi 17(1):19–24. 10.1023/A:1010946517651.
Alalaiwe A, Lin YK, Lin CH, . 2020. The absorption of polycyclic aromatic hydrocarbons into the skin to elicit cutaneous inflammation: The establishment of structure-permeation and in silico-in vitro-in vivo relationships. Chemosphere 255:126955. 10.1016/j.chemosphere.2020.126955.32416390
Ambre J, Ruo TI, Smith-Coggins R. 1986. Mothball composition: Three simple tests for distinguishing paradichlorobenzene from naphthalene. Ann Emerg Med 15:724–726. 10.1016/S0196-0644(86)80434-6.3706864
Amoore JE, Hautala E. 1983. Odor as an aid to chemical safety: Odor thresholds compared with threshold limit values and volatilities for 214 industrial chemicals in air and water dilution. J Appl Toxicol 3(6):272–290. 10.1002/jat.2550030603.6376602
Anand V, Venkatesan DK, Pugazhentham T, . 2023. Methemoglobinemia secondary to a traditional healing practice using mothballs: A need of pediatric vigilance. Cureus 15(6):e41192. 10.7759/cureus.41192.37525810
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York, NY: Marcel Dekker, Inc., 9–25.
Angu Bala Ganesh KSV, Soman S, Reginald SR, . 2024. Ultrastructural changes of synapses in the hippocampus of Sprague Dawley rat brain following exposure to naphthalene balls. J Pharm Bioallied Sci 16(Suppl 2):S1522–s1525. 10.4103/jpbs.jpbs_1184_23.38882886
Anziulewicz JA, Dick HJ, Chiarulli EE. 1959. Transplacental naphthalene poisoning. Am J Obstet Gynecol 78:519–521. 10.1016/0002-9378(59)90522-8.13793923
Aoshiba K, Tsuji T, Itoh M, . 2014. A murine model of airway fibrosis induced by repeated naphthalene exposure. Exp Toxicol Pathol 66(4):169–177. 10.1016/j.etp.2014.01.001.24480153
Arfaeinia H, Dobaradaran S, Mahmoodi M, . 2022. Urinary profile of PAHs and related compounds in women working in beauty salons. Sci Total Environ 851(Pt 2):158281. 10.1016/j.scitotenv.2022.158281.36029813
Arfsten DP, Davenport R, Schaeffer DJ. 1994. Reversion of bioluminescent bacteria (Mutatox) to their luminescent state upon exposure to organic compounds, munitions, and metal salts. Biomed Environ Sci 7:144–149.7946010
Arı A. 2020. A comprehensive study on gas and particle emissions from laser printers: Chemical composition and health risk assessment. Atmos Pollut Res 11(2):269–282. 10.1016/j.apr.2019.10.013.
Asada S, Sasaki K, Tanaka N, . 2005. Detection of initiating as well as promoting activity of chemicals by a novel cell transformation assay using v-Ha-ras-transfected BALB/c 3T3 cells (Bhas 42 cells). Mutat Res 588(1):7–21. 10.1016/j.mrgentox.2005.07.011.16260176
Aslam R, Sharif F, Baqar M, . 2023. Association of human cohorts exposed to blood and urinary biomarkers of PAHs with adult asthma in a South Asian metropolitan city. Environ Sci Pollut Res Int 30(13):35945–35957. 10.1007/s11356-022-24445-z.36538227
Atkinson R, Aschmann SM, Pitts JN. 1984. Kinetics of the reactions of naphthalene and biphenyl with OH radicals and with O_3_ at 294 ± 1 K. Environ Sci Technol 18:110–113. 10.1021/es00120a012.22292686
Atkinson R, Arey J, Zielinska B, . 1987. Kinetics and products of the gas-phase reactions of OH radicals and N_2_O_5_ with naphthalene and biphenyl. Environ Sci Technol 21:1014–1022. 10.1021/es50001a017.19995002
Atkinson JJ, Toennies HM, Holmbeck K, . 2007. Membrane type 1 matrix metalloproteinase is necessary for distal airway epithelial repair and keratinocyte growth factor receptor expression after acute injury. Am J Physiol Lung Cell Mol Physiol 293(3):L600–L610. 10.1152/ajplung.00028.2007.17557804
ATSDR. 1989. Decision guide for identifying substance- specific data needs related to toxicological profiles; Notice. Fed Reg 54(174):37617–37634. https://www.loc.gov/item/fr054174/. October 10, 2024.
ATSDR. 2006. Health consultation: Brewer Brothers Petroleum Bulk Plant Cardwell, Dunklin County, Missouri. Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/HAC/pha/BrewerBrothersPetroleumBulkPlant/BrewerBrothersHC093006.pdf. September 7, 2023.
ATSDR. 2007a. Health consultation: Laugh and Learn Daycare Ashville, Pickaway County, Ohio. Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/HAC/pha/LaughandLearnDaycare/LaughAndLearnDaycareHC061807.pdf. September 7, 2023.
ATSDR. 2007b. Health consultation follow-up on J.H. Baxter health assessment based on new air monitoring data Eugene, Oregon EPA facility ID: ORD009032400. Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.oregon.gov/oha/PH/HEALTHYENVIRONMENTS/TRACKINGASSESSMENT/ENVIRONMENTALHEALTHASSESSMENT/Documents/nweugene_finalhc_july2008.pdf. December 30, 2022.
ATSDR. 2008. Health consultation: Schuylkill Haven MGP Site, Schuylkill Haven, Schuylkill County, Pennsylvania, EPA Facility ID: PAD981104870. Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/HAC/pha/SchuylkillHavenMGPSite/Schuylkill_Haven_MGP_Site%20HC%209-30-2008.pdf. September 7, 2023.
ATSDR. 2022a. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/SPL/resources. June 8, 2023.
ATSDR. 2022b. Sanders2015 HLCs used in SHOWER Model v3 and PHAST. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
ATSDR. 2024. Toxicological profile for creosote. Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://wwwn.cdc.gov/TSP/ToxProfiles/ToxProfiles.aspx?id=66&tid=18. February 12, 2025.
Ayala DC, Morin D, Buckpitt AR. 2015. Simultaneous quantification of multiple urinary naphthalene metabolites by liquid chromatography tandem mass spectrometry. PLoS One 10(4):e0121937. 10.1371/journal.pone.0121937.25853821
Azzolina NA, Kreitinger JP, Skorobogatov Y, . 2016. Background concentrations of PAHs and metals in surface and subsurface soils collected throughout Manhattan, New York. Environ Forensics 17(4):294–310. 10.1080/15275922.2016.1230905.
Back S, Masser AE, Rutqvist LE, . 2023. Harmful and potentially harmful constituents (HPHCs) in two novel nicotine pouch products in comparison with regular smokeless tobacco products and pharmaceutical nicotine replacement therapy products (NRTs). BMC Chem 17(1):9. 10.1186/s13065-023-00918-1.36869349
Baek K, Kim M, Kwak K. 2021. Exposure to diesel engine exhausts and increase of urinary 8-hydroxy-2’-deoxyguanosine among male tank maintenance workers in the Republic of Korea Army. Ind Health 59(6):403–414. 10.2486/indhealth.2021-0022.34588383
Bagchi D, Bagchi M, Balmoori J, . 1998. Induction of oxidative stress and DNA damage by chronic administration of naphthalene to rats. Res Commun Mol Pathol Pharmacol 101(3):249–257.9874283
Bagchi D, Balmoori J, Bagchi M, . 2000. Role of p53 tumor suppressor gene in the toxicity of TCDD, endrin, naphthalene, and chromium (VI) in liver and brain tissues of mice. Free Radic Biol Med 28(6):895–903. 10.1016/S0891-5849(00)00173-8.10802220
Bagchi D, Balmoori J, Bagchi M, . 2002. Comparative effect of TCDD, endrin, naphthalene and chromium (VI) on oxidative stress and tissue damage in the liver and brain tissues of mice. Toxicology 175:73–82. 10.1016/S0300-483X(02)00062-8.12049837
Bakali U, Baum JLR, Louzado-Feliciano P, . 2024. Characterization of fire investigators’ polyaromatic hydrocarbon exposures using silicone wristbands. Ecotoxicol Environ Saf 278:116349. 10.1016/j.ecoenv.2024.116349.38714081
Bakke J, Struble C, Gustafsson JA, . 1985. Catabolism of premercapturic acid pathway metabolites of naphthalene to naphthols and methylthio-containing metabolites in rats. Proc Natl Acad Sci USA 82:668–671. 10.1073/pnas.82.3.668.3856220
Baldwin AK, Corsi SR, Stefaniak OM, . 2022. Risk-based prioritization of organic chemicals and locations of ecological concern in sediment from Great Lakes tributaries. Environ Toxicol Chem 41(4):1016–1041. 10.1002/etc.5286.35170813
Banerjee S, Baughman GL. 1991. Bioconcentration factors and lipid solubility. Environ Sci Technol 25:536–539. 10.1021/es00015a024.
Bao ZZ, Lu SQ, Wang G, . 2023a. Adsorption of 2-hydroxynaphthalene, naphthalene, phenanthrene, and pyrene by polyvinyl chloride microplastics in water and their bioaccessibility under in vitro human gastrointestinal system. Sci Total Environ 871:162157. 10.1016/j.scitotenv.2023.162157.36775174
Bao ZZ, Lu SQ, Wang G, . 2023b. Supplemental material: Adsorption of 2-hydroxynaphthalene, naphthalene, phenanthrene, and pyrene by polyvinyl chloride microplastics in water and their bioaccessibility under in vitro human gastrointestinal system. Sci Total Environ 871 10.1016/j.scitotenv.2023.162157.
Barbee GC. 1994. Fate of chlorinated aliphatic hydrocarbons in the vadose zone and ground water. Ground Water Monit Remed 14:129–140. 10.1111/j.1745-6592.1994.tb00098.x.
Barfknecht TR, Naismith RW, Matthews RJ. 1985. Rat hepatocyte primary culture/DNA repair test: naphthalene. Texaco, Inc. Submitted to U.S. Environmental Protection Agency under section 8D. OTS0513638. 86-870000560. PH 311-TX-008-85. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0513638.xhtml. April 19, 2023.
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486. 10.1016/0273-2300(88)90047-5.3222488
Barnes NM, Damare SR, Bhatawadekar VC, . 2023. Degradation of crude oil-associated polycyclic aromatic hydrocarbons by marine-derived fungi. 3 Biotech 13(10):335. 10.1007/s13205-023-03753-2.
Baxter CS, Hoffman JD, Knipp MJ, . 2014. Exposure of firefighters to particulates and polycyclic aromatic hydrocarbons. J Occup Environ Hyg 11(7):D85–91. 10.1080/15459624.2014.890286.24512044
Bender ME, Huggett RJ. 1989. Polynuclear aromatic hydrocarbon residues in shellfish: Species variations and apparent intraspecific differences. In: Kaiser HE, ed. Comparative aspects of tumor development. Doredrecht, Netherlands: Kluwer Academic Publishers, 226–234.
Benson WH, Dorough HW. 1984. Comparative ester hydrolysis of carbaryl and ethiofencarb in four mammalian species. Pestic Biochem Physiol 21:199–206. 10.1016/0048-3575(84)90055-5.
Berry MR, Johnson LS, Jones JW, . 1997. Dietary characterizations in a study of human exposure in the lower Rio Grande valley: I. Foods and beverages. Environ Int 23(5):675–692. 10.1016/S0160-4120(97)00069-X.
Bieniek G. 1994. The presence of 1-naphthol in the urine of industrial workers exposed to naphthalene. Occup Environ Med 51(5):357–359. 10.1136/oem.51.5.357.8199689
Bieniek G, Łusiak A. 2012. Occupational exposure to aromatic hydrocarbons and polycyclic aromatic hydrocarbons at a coke plant. Ann Occup Hyg 56(7):796–807. 10.1093/annhyg/mes016.22539560
Birman I, Alexander M. 1996. Effect of viscosity of nonaqueous-phase liquids (NAPLs) on biodegradation of NAPL constituents. Environ Toxicol Chem 15(10):1683–1686. 10.1002/etc.5620151005.
Bock KW, Van Ackeren G, Lorch F, . 1976. Metabolism of naphthalene to naphthalene dihydrodiol glucuronide in isolated hepatocytes and in liver microsomes. Biochem Pharmacol 25(21):2351–2356. 10.1016/0006-2952(76)90027-7.826255
Bock KW, von Clausbruch UC, Winne D. 1979. Absorption and metabolism of naphthalene and benzo[a]pyrene in the rat jejunum in situ. Med Biol 57:262–264.522514
Bogdanffy MS, Sarangapani R, Plowchalk DR, . 1999. A biologically based risk assessment for vinyl acetate-induced cancer and noncancer inhalation toxicity. Toxicol Sci 51(1):19–35. 10.1093/toxsci/51.1.19.10496674
Borujeni ET, Yaghmaian K, Naddafi K, . 2022. Identification and determination of the volatile organics of third-hand smoke from different cigarettes and clothing fabrics. J Environ Health Sci Eng 20(1):53–63. 10.1007/s40201-021-00755-1.35669833
Bos RP, Theuws JL, Jongeneelen FJ, . 1988. Mutagenicity of bi-, tri- and tetra-cyclic aromatic hydrocarbons in the “taped-plate assay” and in the conventional Salmonella mutagenicity assay. Mutat Res 204:203–206. 10.1016/0165-1218(88)90090-0.3278211
Breger RK, Franklin RB, Lech JJ. 1981. Metabolism of 2-methylnaphthalene to isomeric dihydrodiols by hepatic microsomes of rat and rainbow trout. Drug Metab Dispos 9(2):88–93.6113123
Breger RK, Novak RF, Franklin RB, . 1983. Further structural analysis of rat liver microsomal metabolites of 2-methylnaphthalene. Drug Metab Dispos 11(4):319–323.6137337
Bregman R. 1954. Mothball poisoning. A case presentation. Clin Proc Child Hosp Dist Columbia 9:1–5.
Brown KW, Donnelly KC. 1988. An estimation of risk associated with the organic constituents of hazardous and municipal waste landfill leachates. Haz Waste Haz Mater 5(1):1–30. 10.1089/hwm.1988.5.1.
Brown RP, Delp MD, Lindstedt SL, . 1997. Physiological parameter values for physiologically based pharmacokinetic models. Toxicol Ind Health 13(4):407–484. 10.1177/074823379701300401.9249929
Brusseau ML. 1991. Cooperative sorption of organic chemicals in systems composed of low organic carbon aquifer materials. Environ Sci Technol 25:1747–1752. 10.1021/es00022a011.
Buchholz BA, Haack KW, Sporty JL, . 2010. Free flow electrophoresis separation and AMS quantitation of C-naphthalene-protein adducts. Nucl Instrum Methods Phys Res B 268(7–8):1324–1327. 10.1016/j.nimb.2009.10.164.20454606
Buchholz BA, Carratt SA, Kuhn EA, . 2019. Naphthalene DNA adduct formation and tolerance in the lung. Nucl Instrum Methods Phys Res B 438:119–123. 10.1016/j.nimb.2018.07.004.30631217
Buckpitt AR, Bahnson LS. 1986. Naphthalene metabolism by human lung microsomal enzymes. Toxicology 41:333–341. 10.1016/0300-483X(86)90186-1.3775781
Buckpitt AR, Franklin RB. 1989. Relationship of naphthalene and 2-methylnaphthalene metabolism to pulmonary bronchiolar epithelial cell necrosis. Pharmacol Ther 41:393–410. 10.1016/0163-7258(89)90116-2.2652157
Buckpitt AR, Buonarati M, Avey LB, . 1992. Relationship of cytochrome P450 activity to cell cytotoxicity. II. Comparison of stereo-selectivity of naphthalene epoxidation in lung and nasal mucosa of mouse, hamster, rat and Rhesus monkey. J Pharmacol Exp Ther 261(1):364–372.1560380
Buckpitt A, Chang A, Weir A, . 1995. Relationship of cytochrome P450 activity to cell cytotoxicity. IV. Metabolism of naphthalene and naphthalene oxide in microdissected airways from mice, rats, and hamsters. Molecular Pharmacol 47:74–81.
Buckpitt A, Boland B, Isbell M, . 2002. Naphthalene-induced respiratory tract toxicity: Metabolic mechanisms of toxicity. Drug Metab Rev 34(4):791–820. 10.1081/DMR-120015694.12487150
Buckpitt A, Morin D, Murphy S, . 2013. Kinetics of naphthalene metabolism in target and non-target tissues of rodents and in nasal and airway microsomes from the Rhesus monkey. Toxicol Appl Pharmacol 270(2):97–105. 10.1016/j.taap.2013.04.006.23602890
Buratti M, Campo L, Fustinoni S, . 2007. Application of ultraviolet spectrophotometry to estimate occupational exposure to airborne polyaromatic compounds in asphalt pavers. J Occup Environ Hyg 4(6):412–419. 10.1080/15459620701337817.17474031
Bush A, Pabary R. 2020. Pulmonary alveolarproteinosis in children. Breathe 16(2):200001. 10.1183/20734735.0001-2020.32684993
Bushnik T, Wong SL, Holloway AC, . 2020. Association of urinary polycyclic aromatic hydrocarbons and obesity in children aged 3-18: Canadian Health Measures Survey 2009-2015. J Dev Orig Health Dis 11(6):623–631. 10.1017/s2040174419000825.31806062
Bysshe SE. 1982. Bioconcentration factor in aquatic organisms. In: Lyman WJ, ed. Handbook of chemical property estimation methods. New York, NY: McGraw Hill, 5.1–5.30.
Cakmak S, Dales RE, Liu L, . 2014. Residential exposure to volatile organic compounds and lung function: results from a population-based cross-sectional survey. Environ Pollut 194:145–151. 10.1016/j.envpol.2014.07.020.25108490
Calabrese EJ. 1986. Ecogenetics: Historical foundation and current status. J Occup Med 28:1096–1102.3772543
Campbell JL, Andersen ME, Clewell HJ. 2014. A hybrid CFD-PBPK model for naphthalene in rat and human with IVIVE for nasal tissue metabolism and cross-species dosimetry. Inhal Toxicol 26(6):333–344. 10.3109/08958378.2014.896059.24666369
Caron-Beaudoin E, Whyte KP, Bouchard MF, . 2022. Volatile organic compounds (VOCs) in indoor air and tap water samples in residences of pregnant women living in an area of unconventional natural gas operations: Findings from the EXPERIVA study. Sci Total Environ 805:150242. 10.1016/j.scitotenv.2021.150242.34818775
Carratt SA, Morin D, Buckpitt AR, . 2016. Naphthalene cytotoxicity in microsomal epoxide hydrolase deficient mice. Toxicol Lett 246:35–41. 10.1016/j.toxlet.2016.01.019.26840748
Carratt SA, Hartog M, Buchholz BA, . 2019a. Naphthalene genotoxicity: DNA adducts in primate and mouse airway explants. Toxicol Lett 305:103–109. 10.1016/j.toxlet.2019.01.009.30684585
Carratt SA, Kovalchuk N, Ding X, . 2019b. Metabolism and lung toxicity of inhaled naphthalene: Effects of postnatal age and sex. Toxicol Sci 170(2):536–548. 10.1093/toxsci/kfz100.31020322
CDC. 2017. Biomonitoring summary: polycyclic aromatic hydrocarbons overview. Centers for Disease Control and Prevention. https://www.cdc.gov/biomonitoring/Naphthalene_BiomonitoringSummary.html. January 20, 2023.
CDC. 2023. Biomonitoring data tables for environmental chemicals: [1- and 2-hydroxynaphthalene]. Centers for Disease Control and Prevention. https://www.cdc.gov/exposurereport/data_tables.html. January 20, 2023.
Chao YC, Gibson RL, Nylander-French LA. 2005. Dermal exposure to jet fuel (JP-8) in US Air Force personnel. Ann Occup Hyg 49(7):639–645. 10.1093/annhyg/mei021.16006502
Chao YC, Kupper LL, Serdar B, . 2006. Dermal exposure to jet fuel JP-8 significantly contributes to the production of urinary naphthols in fuel-cell maintenance workers. Environ Health Perspect 114(2):182–185. 10.1289/ehp.8288.16451852
Charles SM, Batterman SA, Jia C. 2007. Composition and emissions of VOCs in main- and side-stream smoke of research cigarettes. Atmos Environ 41(26):5371–5384. 10.1016/j.atmosenv.2007.02.020.
Chen Y, Yi L, Yan G, . 2010a. α-Lipoic acid alters post-translational modifications and protects the chaperone activity of lens α-crystallin in naphthalene-induced cataract. Curr Eye Res 35(7):620–630. 10.3109/02713681003768211.20597648
Chen Y, Yi L, Yan GQ, . 2010b. Decreased chaperone activity of α-crystallins in naphthalene-induced cataract possibly results from C-terminal truncation. J Int Med Res 38(3):1016–1028. 10.1177/147323001003800328.20819438
Chen Y, Jiang YX, Yi L, . 2012. Excessive milk intake as a risk factor, probably associated with oxidative stress, in experimental naphthalene-initiated cataract in rats. Ophthalmic Res 47(2):87–97. 10.1159/000330504.21865765
Chen YY, Kao TW, Wang CC, . 2019. Exposure to polycyclic aromatic hydrocarbons and risk of disability among an elderly population. Environ Sci Pollut Res Int 26(11):10719–10726. 10.1007/s11356-019-04498-3.30778934
Chen Q, Wang F, Yang H, . 2021. Exposure to fine particulate matter-bound polycyclic aromatic hydrocarbons, male semen quality, and reproductive hormones: The MARCHS study. Environ Pollut 280:116883. 10.1016/j.envpol.2021.116883.33794416
Cherry N, Galarneau JM, Kinniburgh D, . 2021. Exposure and absorption of PAHs in wildland firefighters: A field study with pilot interventions. Ann Work Expo Health 65(2):148–161. 10.1093/annweh/wxaa064.32572446
Childers JW, Witherspoon CL, Smith LB, . 2000. Real-time and integrated measurement of potential human exposure to particle-bound polycyclic aromatic hydrocarbons (PAHs) from aircraft exhaust. Environ Health Perspect 108(9):853–862. 10.1289/ehp.00108853.11017890
Cho TM, Rose RL, Hodgson E. 2006. In vitro metabolism of naphthalene by human liver microsomal cytochrome P450 enzymes. Drug Metab Dispos 34(1):176–183. 10.1124/dmd.105.005785.16243959
Cho M, Chichester C, Morin D, . 1994a. Covalent interactions of reactive naphthalene metabolites with proteins. J Pharmacol Exp Ther 269(2):881–889.8182557
Cho M, Jedrychowski R, Hammock B, . 1994b. Reactive metabolite binding to hemoglobin and albumin. Fundam Appl Toxicol 22:26–33. 10.1093/toxsci/22.1.26.8125210
Choi JW, Kim M, Song G, . 2023. Toxicokinetic analyses of naphthalene, fluorene, phenanthrene, and pyrene in humans after single oral administration. Sci Total Environ 870:161899. 10.1016/j.scitotenv.2023.161899.36716884
Chopra S, Ridley L, Murphy WR, . 2019. Quantitative analysis of polycyclic aromatic hydrocarbons at part per billion levels in fish oil by headspace solid-phase microextraction and gas chromatography-mass spectrometry (HS-SPME-GC-MS). J Chromatogr Sci 57(1):87–92. 10.1093/chromsci/bmy086.30215681
Chuang JC, Mack GA, Kuhlman MR, . 1991. Polycyclic aromatic hydrocarbons and their derivatives in indoor and outdoor air in an eight-home study. Atmos Environ 25B(3):369–380. 10.1016/0957-1272(91)90008-3.
Chuang JC, Callahan PJ, Menton RG, . 1995. Monitoring methods for polycyclic aromatic hydrocarbons and their distribution in house dust and track-in soil. Environ Sci Technol 29:494–500. 10.1021/es00002a027.22201397
Chuang JC, Callahan PJ, Lyu CW, . 1999. Polycyclic aromatic hydrocarbon exposures of children in low-income families. J Exp Anal Environ Epidem 9(2):85–98. 10.1038/sj.jea.7500003.
Chusid E, Fried CT. 1955. Acute hemolytic anemia due to naphthalene ingestion. AMA Am J Dis Child 89:612–614. 10.1001/archpedi.1955.02050110726019.14360746
Cichocki JA, Smith GJ, Mendoza R, . 2014. Sex differences in the acute nasal antioxidant/antielectrophilic response of the rat to inhaled naphthalene. Toxicol Sci 139(1):234–244. 10.1093/toxsci/kfu031.24563378
Cilluffo G, Ferrante G, Murgia N, . 2022. Effects of polycyclic aromatic hydrocarbons on lung function in children with asthma: A mediation analysis. Int J Environ Res Public Health 19(3):1826. 10.3390/ijerph19031826.35162850
Clark JD, Serdar B, Lee DJ, . 2012. Exposure to polycyclic aromatic hydrocarbons and serum inflammatory markers of cardiovascular disease. Environ Res 117:132–137. 10.1016/j.envres.2012.04.012.22626472
Clewell HJ. 1995. The application of physiologically based pharmacokinetic modeling in human health risk assessment of hazardous substances. Toxicol Lett 79(1–3):207–217. 10.1016/0378-4274(95)03372-r.7570658
Clewell HJ, Efremenko A, Campbell JL, . 2014. Transcriptional responses in the rat nasal epithelium following subchronic inhalation of naphthalene vapor. Toxicol Appl Pharmacol 280(1):78–85. 10.1016/j.taap.2014.06.015.24976557
Collin G, Hoke H, Greim H. 2012. Naphthalene and hydronaphthalenes. In: Ullmann’s encyclopedia of industrial chemistry. Vol. 23. Weinheim: Wiley-VCH Verlag GmbH & Co. KGaA, 661–670. 10.1002/14356007.a17_001.pub2.
Connor TH, Thiess JC, Hanna HA, . 1985. Genotoxicity of organic chemicals frequently found in the air of mobile homes. Toxicol Lett 25:33–40. 10.1016/0378-4274(85)90097-9.3887653
Cripps GC. 1992. Baseline levels of hydrocarbons in seawater of the Southern Ocean: Natural variability and regional patterns. Mar Pollut Bull 24(2):109–114. 10.1016/0025-326X(92)90739-S.
Danish EPA. 2015. Survey of naphthalene (CAS 91-20-3). Danish Environmental Protection Agency. Environmental project no. 1721. https://www2.mst.dk/Udgiv/publications/2015/06/978-87-93352-34-6.pdf. January 12, 2023.
Darious M, Daoud A, Dawara A. 2020. Study the effect of alcoholic flaxseed extract on naphthalene-induced hemolytic anemia in Syrian hamster. Chem Res J 5(1):47–55.
Davey NG, Fitzpatrick CT, Etzkorn JM, . 2014. Measurement of spatial and temporal variation in volatile hazardous air pollutants in Tacoma, Washington, using a mobile membrane introduction mass spectrometry (MIMS) system. J Environ Sci Health A Tox Hazard Subst Environ Eng 49(11):1199–1208. 10.1080/10934529.2014.910014.24967552
Dawson JP, Thayer WW, Desforges JF. 1958. Acute hemolytic anemia in the newborn infant due to naphthalene poisoning: Report of two cases, with investigations into the mechanism of the disease. Blood 13(12):1113–1125. 10.1182/blood.V13.12.1113.1113.13596416
de Pinho JV, Lopes AP, de Almeida Rodrigues P, . 2023. Food safety concerns on polycyclic aromatic hydrocarbon contamination in fish products from estuarine bays throughout the American continent. Sci Total Environ 858(Pt 2):159930. 10.1016/j.scitotenv.2022.159930.36356770
Dean BS, Lopez G, Krenzelok EP. 1992. Environmentally-induced methemoglobinemia in an infant. Clin Toxicol 30(1):127–133. 10.3109/15563659208994453.
Dehghani S, Fararouei M, Rafiee A, . 2022. Prenatal exposure to polycyclic aromatic hydrocarbons and effects on neonatal anthropometric indices and thyroid-stimulating hormone in a Middle Eastern population. Chemosphere 286(Pt 1):131605. 10.1016/j.chemosphere.2021.131605.34298295
Dela Cruz M, Khalid MM, Mostafa A, . 2019. Hemolytic crisis following naphthalene mothball ingestion in a 21-month-old patient with glucose-6-phosphate dehydrogenase (G6PD) deficiency. Case Rep Pediatr 2019:1092575. 10.1155/2019/1092575.31321110
Delgado-Rodriquez A, Ortiz-Marttelo R, Graf U, . 1995. Genotoxic activity of environmentally important polycyclic aromatic hydrocarbons and their nitro derivatives in the wing spot test of Drosophila melanogaster. Mutat Res 341:235–247. 10.1016/0165-1218(95)90095-0.7531283
DeStefano-Shields C, Morin D, Buckpitt A. 2010. Formation of covalently bound protein adducts from the cytotoxicant naphthalene in nasal epithelium: species comparisons. Environ Health Perspect 118(5):647–652. 10.1289/ehp.0901333.20435546
Dhar K, Panneerselvan L, Subashchandrabose SR, . 2023. Anaerobic degradation of naphthalene and pyrene by sulfate-reducing cultures enriched from former manufactured gas plant soil. Microb Ecol 86(1):271–281. 10.1007/s00248-022-02042-4.35610382
Djomo JE, Ferrier V, Gauthier L, . 1995. Amphibian micronucleus test in vivo: Evaluation of the genotoxicity of some major polycyclic aromatic hydrocarbons found in a crude oil. Mutagenesis 10(3):223–226. 10.1093/mutage/10.3.223.7666774
Dobaradaran S, Schmidt TC, Lorenzo-Parodi N, . 2019. Cigarette butts: An overlooked source of PAHs in the environment? Environ Pollut 249:932–939. 10.1016/j.envpol.2019.03.097.30965545
Dodd DE, Gross EA, Miller RA, . 2010. Nasal olfactory epithelial lesions in F344 and SD rats following 1- and 5-day inhalation exposure to naphthalene vapor. Int J Toxicol 29(2):175–184. 10.1177/1091581809357955.20086191
Dodd DE, Wong BA, Gross EA, . 2012. Nasal epithelial lesions in F344 rats following a 90-day inhalation exposure to naphthalene. Inhal Toxicol 24(1):70–79. 10.3109/08958378.2011.636086.22182220
DOE. 2024a. Protective action criteria (PAC) based on AEGLs, ERPGs, or TEELs. U.S. Department of Energy. https://edms3.energy.gov/pac/TeelDocs. September 13, 2024.
DOE. 2024b. Definition of PACs (AEGLs, ERPGs or TEELs). U.S. Department of Energy. https://edms3.energy.gov/pac/TeelDef. September 13, 2024.
Doherty MD, Cohen GM, Smith MT. 1984. Mechanisms of toxic injury to isolated hepatocytes by 1-naphthol. Biochem Pharmacol 33(4):543–549. 10.1016/0006-2952(84)90305-8.6200119
Durant ND, Wilson LP, Bouwer EJ. 1994. Screening for natural subsurface biotransformation of polycyclic aromatic hydrocarbons at a former manufactured gas plant. In: Hinchee RE, Leeson A, Semprini L, ., eds. Bioremediation of chlorinated and polycyclic aromatic hydrocarbon compounds. Boca Raton: CRC Press, Inc., 457–461.
Dusautoir R, Zarcone G, Verriele M, . 2021. Comparison of the chemical composition of aerosols from heated tobacco products, electronic cigarettes and tobacco cigarettes and their toxic impacts on the human bronchial epithelial BEAS-2B cells. J Hazard Mater 401:123417. 10.1016/j.jhazmat.2020.123417.32763707
Eastmond DA, Booth GM, Lee ML. 1984. Toxicity, accumulation, and elimination of polycyclic aromatic sulfur heterocycles in Daphnia magna. Arch Environ Contam 13:105–111. 10.1007/BF01055652.
Easton MDL, Luszniak D, Von der Geest E. 2002. Preliminary examination of contaminant loadings in farmed salmon, wild salmon and commercial salmon feed. Chemosphere 46(7):1053–1074. 10.1016/S0045-6535(01)00136-9.11999769
Egeghy PP, Hauf-Cabalo L, Gibson R, . 2003. Benzene and naphthalene in air and breath as indicators of exposure to jet fuel. Occup Environ Med 60(12):969–976. 10.1136/oem.60.12.969.14634191
Ehrlich GG, Goerlitz DF, Godsy EM, . 1982. Degradation of phenolic contaminants in ground water by anaerobic bacteria: St. Louis Park, Minnesota. Ground Water 20(6):703–710. 10.1111/j.1745-6584.1982.tb01390.x.
Eisele GR. 1985. Naphthalene distribution in tissues of laying pullets, swine, and dairy cattle. Bull Environ Contam Toxicol 34:549–556.3838688
Ekambaram S, Chandan Kumar KM, Mahalingam V. 2017. Acute kidney injury: A rare complication of mothball (Naphthalene) poisoning. Saudi J Kidney Dis Transpl 28(6):1412–1415. 10.4103/1319-2442.220858.29265056
Ellickson KM, McMahon CM, Herbrandson C, . 2017. Analysis of polycyclic aromatic hydrocarbons (PAHs) in air using passive sampling calibrated with active measurements. Environ Pollut 231(Pt 1):487–496. 10.1016/j.envpol.2017.08.049.28841501
El-Masri HA, Mumtaz MM, Yushak ML. 2004. Application of physiologically-based pharmacokinetic modeling to investigate the toxicological interaction between chlorpyrifos and parathion in the rat. Environ Toxicol Pharmacol 16(1–2):57–71. 10.1016/j.etap.2003.10.002.21782694
Emi Y, Konishi Y. 1985. Endogenous lipid pneumonia in female B6C3F1 mice. In: Jones TC, Mohr U, Hunt RD, eds. Respiratory system. Berlin, Germany: Springer, 166–168. 10.1007/978-3-642-96846-4_25.
EPA. 1982. Exposure and risk assessment for benzo(a)pyrene and other polycyclic aromatic hydrocarbons. Volume 2: Naphthalene. Washington, DC: U.S. Environmental Protection Agency. PB85222560. EPA440485020V2. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB85222560.xhtml. April 18, 2023.
EPA. 1986a. Guidelines for the health risk assessment of chemical mixtures. U.S. Environmental Protection Agency. Fed Reg 51(185):34014–34025. https://www.loc.gov/item/fr051185/. October 10, 2024.
EPA. 1986b. Broad scan analysis of the FY82 national human adipose tissue survey specimens. Volume I: Executive summary. Washington, DC: U.S. Environmental Protection Agency. EPA560586035. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=2000HPAT.txt. February 9, 2023.
EPA. 1987. Summary review of health effects associated with naphthalene: Health issue assessment. Research Triangle Park, NC: U.S. Environmental Protection Agency. PB88172374. EPA600887055F. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=30001GTV.txt. April 19, 2023.
EPA. 1988. Health effects assessment for naphthalene. Cincinnati, OH: U.S. Environmental Protection Agency. PB90142464. EPA600889094. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB90142464.xhtml. April 19, 2023.
EPA. 1989a. Land disposal restrictions for second third scheduled wastes; proposed rule. U.S. Environmental Protection Agency. Fed Reg 54(7):1056–1119.
EPA. 1989b. Characteristics of pilot and full-scale hazardous waste incinerator ash. Cincinnati, OH: U.S. Environmental Protection Agency. PB90134396. EPA600D89232. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB90134396.xhtml. April 19, 2023.
EPA. 1991. Indoor air-assessment; indoor air concentrations of environmental carcinogens. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA600890042. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=30001J0D.txt. April 19, 2023.
EPA. 1994. Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry. U.S. Environmental Protection Agency. EPA600890066F. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=30001K4C.txt. April 19, 2023.
EPA. 1996. Exposure factors handbook. Washington, DC: U.S. Environmental Protection Agency. EPA600889043. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=30001I91.txt. April 19, 2023.
EPA. 1998. Toxicological review of naphthalene (CAS No. 91-20-3). In support of summary information on the Integrated Risk Information System (IRIS). U.S. Environmental Protection Agency. PB99137358. EPA635R98010. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB99137358.xhtml. April 19, 2023.
EPA. 2002. Health effects support document for naphthalene: External review draft. Alexandria, VA: U.S. Environmental Protection Agency. EPA822R02031. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=20003JAW.txt. April 19, 2023.
EPA. 2003. Toxicological review of 2-methylnaphthalene (CAS No. 91-57-6) U.S. Environmental Protection Agency. EPA635R03010. http://www.epa.gov/iris. May 9, 2022.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. EPA260B05001. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P100EI4V.txt. December 4, 2024.
EPA. 2007a. Method 8272: Parent and alkyl polycyclic aromatics in sediment pore water by solid-phase microextraction and gas chromatography/mass spectrometry in selected ion monitoring mode. U.S. Environmental Protection Agency. https://www.epa.gov/sites/default/files/2015-12/documents/8272.pdf. May 9, 2022.
EPA. 2007b. Provisional peer-reviewed toxicity values for 2-methylnaphthalene. Cincinnati, OH: U.S. Environmental Protection Agency. EPA690R07022F. https://cfpub.epa.gov/ncea/pprtv/recordisplay.cfm?deid=338998. May 9, 2022.
EPA. 2008. Provisional peer-reviewed toxicity values for 1-methylnaphthalene. Cincinnati, OH: U.S. Environmental Protection Agency. EPA690R08017F. https://cfpub.epa.gov/ncea/pprtv/recordisplay.cfm?deid=338997. May 9, 2022.
EPA. 2009. Method 524.3, V.1: Measurement of purgeable organic compounds in water by capillary column gas chromatography/mass spectrometry. Cincinnati, OH: U.S. Environmental Protection Agency. EPA815B09009. https://www.nemi.gov/methods/method_summary/10417/. November 21, 2023.
EPA. 2012. Data evaluation record: Naphthalene, immunotoxicity study in mice [MRID 48792701]. U.S. Environmental Protection Agency. https://www.regulations.gov/document/EPA-HQ-OPP-2016-0113-0025. January 20, 2023.
EPA. 2016. Vapor intrusion screening level calculator. U.S. Environmental Protection Agency. https://www.epa.gov/vaporintrusion. October 9, 2024.
EPA. 2017a. Hazardous air pollutants. U.S. Environmental Protection Agency. 42 U.S.C. 7412. https://www.govinfo.gov/app/details/USCODE-2011-title42/USCODE-2011-title42-chap85-subchapI-partA-sec7412. December 15, 2022.
EPA. 2017b. National emission inventory (NEI) data. U.S. Environmental Protection Agency. https://www.epa.gov/air-emissions-inventories/2017-national-emissions-inventory-nei-data. October 20, 2022.
EPA. 2018a. 2018 Edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency. EPA822S12001. https://www.epa.gov/sites/production/files/2018-03/documents/dwtable2018.pdf. July 25, 2018.
EPA. 2018b. Naphthalene. Human health risk assessment in support of registration review. Washington, DC: U.S. Environmental Protection Agency. D440842. https://www.regulations.gov/document/EPA-HQ-OPP-2016-0113-0018. May 11, 2022.
EPA. 2018c. Compiled AEGL values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2018-08/documents/compiled_aegls_update_27jul2018.pdf. April 12, 2020.
EPA. 2020. 2017 NEI data. U.S. Environmental Protection Agency. https://www.epa.gov/air-emissions-inventories/2017-national-emissions-inventory-nei-data. January 15, 2023.
EPA. 2022a. 2020 CDR data. U.S. Environmental Protection Agency. https://www.epa.gov/chemical-data-reporting/access-cdr-data#2020. October 26, 2022.
EPA. 2022b. Annual summary data: Naphthalene, 1-methylnaphthalene, and 2-methylnaphthalene. Air data: Air quality data collected at outdoor monitors across the US. U.S. Environmental Protection Agency. https://www.epa.gov/outdoor-air-quality-data. April 19, 2023.
EPA. 2022c. Derivation of an acute reference concentration for inhalation exposure to naphthalene. Washington, DC: U.S. Environmental Protection Agency. EPA600R21292. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P1015I0I.txt. April 19, 2023.
EPA. 2022d. Toxic chemical release inventory reporting forms and instructions: Revised 2021 version. U.S. Environmental Protection Agency. EPA740B22002. https://ordspub.epa.gov/ords/guideme_ext/guideme_ext/guideme/file/ry_2021_rfi.pdf. August 22, 2023.
EPA. 2023a. Chemical name: naphthalene. U.S. Environmental Protection Agency. https://ordspub.epa.gov/ords/pesticides/f?p=113:6:::::P6_XCHEMICAL_ID:3014. January 1, 2023.
EPA. 2023b. Air monitoring and sampling data: East Palestine, Ohio Train Derailment. U.S. Environmental Protection Agency. https://www.epa.gov/east-palestine-oh-train-derailment/air-monitoring-and-sampling-data. September 5, 2023.
EPA. 2023c. National primary drinking water regulations. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141. https://www.govinfo.gov/content/pkg/CFR-2023-title40-vol25/pdf/CFR-2023-title40-vol25-part141.pdf. May 3, 2024.
EPA. 2024. Provisional peer-reviewed toxicity values for 1-methylnaphthalene (CASRN 90-12-0). Cincinnati, OH: U.S. Environmental Protection Agency. EPA690R24001F. https://cfpub.epa.gov/ncea/pprtv/documents/methylnaphthalene1.pdf. October 1, 2024.
Eskandarani RM, Alghamdi FS. 2020. Naphthalene toxicity in a three-year-old child complicated by severe hemolytic anemia and mild methemoglobinemia: A case report. J Emerg Med 59(4):e113–e117. 10.1016/j.jemermed.2020.06.009.32682642
EU. 2003. European Union risk assessment report: Naphthalene. European Chemicals Bureau. European Union. EUR 20763 EN. https://echa.europa.eu/documents/10162/4c955673-9744-4d1c-a812-2bf97863906a. February 9, 2023.
Fait DW, Nachreiner RW. 1985. Naphthalene acute inhalation toxicity study. Submitted to the U.S. Environmental Protection Agency under TSCA section 8D. OTS0513636. 86-870000558. Project Report 48-511. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0513636.xhtml. April 19, 2023.
Fanucchi MV, Buckpitt AR, Murphy ME, . 1997. Naphthalene cytotoxicity of differentiating cells in neonatal mice. Toxicol Appl Pharmacol 144:96–104. 10.1006/taap.1997.8119.9169074
FDA. 2022. FDA total diet study (TDS): 1991-2017. U.S. Food and Drug Administration. https://www.fda.gov/food/fda-total-diet-study-tds/fda-total-diet-study-tds-1991-2017. December 15, 2022.
FDA. 2024. 1-Methylnaphthalene. Substances added to food. U.S. Food and Drug Administration. https://www.cfsanappsexternal.fda.gov/scripts/fdcc/index.cfm?set=FoodSubstances&id=METHYLNAPHTHALENE. October 8, 2024.
Florin I, Rutberg L, Curvall M, . 1980. Screening of tobacco smoke constituents for mutagenicity using the Ames test. Toxicology 18:219–232. 10.1016/0300-483X(80)90055-4.
Flowers L, Ohnishi T, Penning TM, . 1997. DNA strand scission by polycyclic aromatic hydrocarbon o-quinones: role of reactive oxygen species, Cu(II)/Cu(I) redox cycling and o-semiquinone anion radicals. Biochemistry 36:8640–8648. 10.1021/bi970367p.9214311
Flowers-Geary L, Bleczinski W, Harvey RG, . 1996. Cytotoxicity and mutagenicity of polycyclic aromatic hydrocarbon o-quinones produced by dihydrodiol dehydrogenase. Chem Bio Int 99:55–72. 10.1016/0009-2797(95)03660-1.
Foster GD, Roberts EC, Gruessner B, . 2000. Hydrogeochemistry and transport of organic contaminants in an urban watershed of Chesapeake Bay (USA). Appl Geochem 15:901–915. 10.1016/S0883-2927(99)00107-9.
Frantz SW, Van Miller JP, Hengler WC. 1986. Ninety-day (sub-chronic) dermal toxicity study with naphthalene in albino rats. Texaco, Inc. Submitted to the U.S. Environmental Protection Agency under TSCA section 8D. OTS0513643. 86-8700000565. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0513643.xhtml. April 19, 2023.
Frederick CB, Bush ML, Lomax LG, . 1998. Application of a hybrid computational fluid dynamics and physiologically based inhalation model for interspecies dosimetry extrapolation of acidic vapors in the upper airways. Toxicol Appl Pharmacol 152(1):211–231. 10.1006/taap.1998.8492.9772217
Freeman AE, Weisburger EK, Weisburger JH, . 1973. Transformation of cell cultures as an indication of the carcinogenic potential of chemicals. J Natl Cancer Inst 51:799–808. 10.1093/jnci/51.3.799.4200596
Fulekar MH. 2017. Microbial degradation of petrochemical waste-polycyclic aromatic hydrocarbons. Bioresour Bioprocess 4(1):28. 10.1186/s40643-017-0158-4.28725525
Gaines TB. 1969. Acute toxicity of pesticides. Toxicol Appl Pharmacol 14(3):515–534. 10.1016/0041-008x(69)90013-1.5787520
Gao P, Xu M, Liu Y, . 2019. Emerging and legacy PAHs in urban soils of four small cities: Concentrations, distribution, and sources. Sci Total Environ 685:463–470. 10.1016/j.scitotenv.2019.05.403.31176231
Gao B, Wang X, Ford RM. 2023. Chemotaxis along local chemical gradients enhanced bacteria dispersion and PAH bioavailability in a heterogenous porous medium. Sci Total Environ 859(Pt 1):160004. 10.1016/j.scitotenv.2022.160004.36368405
García-Pérez J, Fernández de Larrea-Baz N, Lope V, . 2020. Residential proximity to industrial pollution sources and colorectal cancer risk: A multicase-control study (MCC-Spain). Environ Int 144:106055. 10.1016/j.envint.2020.106055.32827807
Gatehouse D. 1980. Mutagenicity of 1,2 ring-fused acenaphthenes against S. typhimurium TA1537 and TA1538: structure-activity relationships. Mutat Res 78:121–135. 10.1016/0165-1218(80)90091-9.6993940
GDCH. 1992. Methylnaphthalenes. GDCH-Advisory Committee on existing chemicals of environmental relevance (BUA). Gesellschaft Deutscher Chemiker. BUA Report 47.
Germansky M, Jamall IS. 1988. Organ-specific effects of naphthalene on tissue peroxidation, glutathione peroxidases and superoxide dismutase in the rat. Arch Toxicol 61(6):480–483. 10.1007/BF00293694.3190445
Germin-Aizac J, Maitre A, Balducci F, . 2023. Bitumen fumes and PAHs in asphalt road paving: Emission characteristics, determinants of exposure and environmental impact. Environ Res 228:115824. 10.1016/j.envres.2023.115824.37030408
Geyer H, Sheehan P, Kotzias D, . 1982. Prediction of ecotoxicological behaviour of chemicals: Relationship between physico-chemical properties and bioaccumulation of organic chemicals in the mussel Mytilus edulis. Chemosphere 11(11):1121–1134. 10.1016/0045-6535(82)90122-9.
Ghetti G, Mariani L. 1956. [Eye changes due to naphthalene]. Med Lav 47(10):533–538. (Italian)13386681
Ghoshal S, Luthy RG. 1996. Bioavailability of hydrophobic organic compounds from nonaqueous-phase liquids: The biodegradation of naphthalene from coal tar. Environ Toxicol Chem 15(11):1894–1900. 10.1002/etc.5620151106.
Gidron E, Leurer J. 1956. Naphthalene poisoning. Lancet 270(6910):228–231. 10.1016/s0140-6736(56)91152-7.13287114
Godek EG, Naismith RW, Matthews RJ. 1985. Ames Salmonella/microsome plate test (EPA/OECD) (unpublished material). Texaco, Inc. Submitted to the U.S. Environmental Protection Agency under TSCA section 8D. OTS0513637. 86-870000559. PH 301-TX-020-85. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0513637.xhtml. April 19, 2023.
Gold KW, Naugle DF, Berry MA. 1993. Indoor concentrations of environmental carcinogens. In: Seifert B, van de Wiel HJ, Dodet B, ., eds. IARC scientific publication on indoor concentrations of environmental carcinogens. Vol. 12: Indoor air. Lyon, France: International Agency for Research on Cancer, 41–71.
Gollahon LS. 1990. Dissertation: Chromosomal damage to preimplantation embryos in vitro by naphthalene. Texas A&M University ProQuest Dissertations Publishing.
Gomez E, Ledbetter CA, Hartsell PL. 1993. Volatile compounds in apricot, plum, and their interspecific hybrids. J Agric Food Chem 41:1669–1676. 10.1021/jf00034a029.
Greeley MA, Van Winkle LS, Edwards PC, . 2010. Airway trefoil factor expression during naphthalene injury and repair. Toxicol Sci 113(2):453–467. 10.1093/toxsci/kfp268.19880587
Greene JF, Zheng J, Grant DF, . 2000. Cytotoxicity of 1,2-epoxynaphthalene is correlated with protein binding and in situ glutathione depletion in cytochrome P4501A1 expressing Sf-21 cells. Toxicol Sci 53:352–360. 10.1093/toxsci/53.2.352.10696783
Griffin KA, Johnson CB, Breger RK, . 1982. Effects of inducers and inhibitors of cytochrome P-450-linked monooxygenases on the toxicity, in vitro metabolism and in vivo irreversible binding of 2-methylnaphthalene in mice. J Pharmacol Exp Ther 221:517–524.7086669
Griffin KA, Johnson CB, Breger RK, . 1983. Pulmonary toxicity of 2-methylnaphthalene: Lack of a relationship between toxicity, dihydrodiol formation and irreversible binding to cellular macromolecules in DBA/2J mice. Toxicology 26:213–230. 10.1016/0300-483X(83)90083-5.6857696
Grimes AJ, Young L. 1956. The metabolism of 2-methylnaphthalene. Biochem J 62:11.
Guerrero PA, Corsi RL. 2012. Emissions of p-dichlorobenzene and naphthalene from consumer products. J Air Waste Manag Assoc 62(9):1075–1084. 10.1080/10962247.2012.694399.23019821
Gummin DD, Mowry JB, Beuhler MC, . 2021. 2020 Annual report of the American Association of Poison Control Centers’ National Poison Data System (NPDS): 38^th^ annual report. Clin Toxicol 59(12):1282–1501. 10.1080/15563650.2021.1989785.
Guo J, Huang Y, Bian S, . 2018. Associations of urinary polycyclic aromatic hydrocarbons with bone mass density and osteoporosis in U.S. adults, NHANES 2005-2010. Environ Pollut 240:209–218. 10.1016/j.envpol.2018.04.108.29738949
Gupta R, Singhal PC, Muthusethupathy MA, . 1979. Cerebral oedema and renal failure following naphthalene poisoning. J Assoc Physicians India 27:347–348.528485
Haggerty RJ. 1956. Toxic hazards: Naphthalene poisoning. N Engl J Med 255(19):919–920. 10.1056/NEJM195611082551917.
Han B, Wang L, Wang X, . 2024. Association between multipollutant exposure and thyroid hormones in elderly people: A cross-sectional study in China. Environ Res 252(Pt 1):118781. 10.1016/j.envres.2024.118781.38552824
Hanchi M, Campo L, Polledri E, . 2017. Urinary 8-oxo-7,8-dihydro-2’-deoxyguanosine in Tunisian electric steel foundry workers exposed to polycyclic aromatic hydrocarbons. Ann Work Expo Health 61(3):333–343. 10.1093/annweh/wxw030.28355448
Hao W, Kingston HM, Dillard A, . 2020. Quantification of persistent organic pollutants in human whole blood samples using stir bar sorptive extraction coupled with GC/MS/MS and isotope dilution mass spectrometry. Microchem J 153:104279. 10.1016/j.microc.2019.104279.
Haque SE, Gilani KM. 2005. Effect of ambroxol, spirulina and vitamin-E in naphthalene induced cataract in female rats. Indian J Physiol Pharmacol 49(1):57–64.15881859
Harden RA, Baetjer AM. 1978. Aplastic anemia following exposure to paradichlorobenzene and naphthalene. J Occup Med 20:820–822.731345
Harper BL, Ramanujam VMS, Gad-El-Karim MM, . 1984. The influence of simple aromatics on benzene clastogenicity. Mutat Res 128:105–114. 10.1016/0027-5107(84)90097-6.6472309
Hawthorne SB, Poppendieck DG, Grabanski CB, . 2001. PAH release during water desorption, supercritical carbon dioxide extraction, and field bioremediation. Environ Sci Technol 35(22):4577–4583. 10.1021/es010771i.11757619
Heaton KJ, Maule AL, Smith KW, . 2017. JP8 exposure and neurocognitive performance among US Air Force personnel. Neurotoxicology 62:170–180. 10.1016/j.neuro.2017.07.001.28687449
Heck JE, He D, Wing SE, . 2024. Exposure to outdoor ambient air toxics and risk of breast cancer: The multiethnic cohort. Int J Hyg Environ Health 259:114362. 10.1016/j.ijheh.2024.114362.38574449
Heitzer A, Webb OF, Thonnard JE, . 1992. Specific and quantitative assessment of naphthalene and salicylate bioavailability by using a bioluminescent catabolic reporter bacterium. Appl Environ Microbiol 58(6):1839–1846. 10.1128/aem.58.6.1839-1846.1992.16348717
Herbes SE. 1981. Rates of microbial transformation of polycylic aromatic hydrocarbons in water and sediments in the vicinity of a coal-coking wastewater discharge. Appl Environ Microbiol 41(1):20–28. 10.1128/aem.41.1.20-28.1981.16345686
Herbes SE, Schwall LR. 1978. Microbial transformation of polycyclic aromatic hydrocarbons in pristine and petroleum-contaminated sediments. Appl Environ Microbiol 35(2):306–316. 10.1128/aem.35.2.306-316.1978.16345270
Herbes SE, Southworth GR, Shaeffer DL, . 1980. Critical pathways of polycyclic aromatic hydrocarbons in aquatic environments. In: Witschi H, ed. The scientific basis of toxicity assessment. Amsterdam: Elsevier/North Holland Biomedical Press, 113–128.
Hoffmann K, Krause C, Seifert B, . 2000. The German Environmental Survey 1990/92 (GERES II) Sources of personal exposure to volatile organic compounds. J Expo Anal Environ Epidemiol 10:115–125. 10.1038/sj.jea.7500084.10791593
Holmberg K, Bake B, Pipkorn U. 1989. Mucosal blood flow in the human nose following local challenge with histamine. Allergy 44(1):45–51. 10.1111/j.1398-9995.1989.tb00445.x.2719176
Holmén JB, Ekesten B, Lundgren B. 1999. Naphthalene-induced cataract model in rats: A comparative study between slit and retroillumination images, biochemical changes and naphthalene dose and duration. Curr Eye Res 19(5):418–425. 10.1076/ceyr.19.5.418.5296.10520218
Honda T, Kiyozumi M, Kojima S. 1990. Alkylnaphthalene. XI. Pulmonary toxicity of naphthalene, 2-methylnaphthalene, and isopropylnaphthalenes in mice. Chem Pharm Bull 38(11):3130–3135. 10.1248/cpb.38.3130.
Horn GP, Madrzykowski D, Neumann DL, . 2022. Airborne contamination during post-fire investigations: Hot, warm and cold scenes. J Occup Environ Hyg 19(1):35–49. 10.1080/15459624.2021.2002343.34762010
Horney JA, Casillas GA, Baker E, . 2018. Comparing residential contamination in a Houston environmental justice neighborhood before and after Hurricane Harvey. PLoS One 13(2):e0192660. 10.1371/journal.pone.0192660.29420658
Horning MG, Stillwell WG, Griffin GW, . 1980. Epoxide intermediates in the metabolism of naphthalene by the rat. Drug Metab Dispos 8(6):404–414.6109608
Howard PH. 1989. Naphthalene. In: Handbook of environmental fate and exposure data for organic chemicals. Vol. 1. Lewis Publishers, 408–421.
Hu J, Sheng L, Li L, . 2014. Essential role of the cytochrome P450 enzyme CYP2A5 in olfactory mucosal toxicity of naphthalene. Drug Metab Dispos 42(1):23–27. 10.1124/dmd.113.054429.24104196
Huang S, Nian M, Ma S, . 2023. Associations between urinary monohydroxylated polycyclic aromatic hydrocarbons and unexplained recurrent spontaneous abortion and health risk assessment in a large case-control study in China. Environ Res 218:115039. 10.1016/j.envres.2022.115039.36513126
Hughes CS, Bakker J, Kamatari O. 1985. CEH product review: Naphthalene. In: Chemical economics handbook. Menlo Park, CA: SRI International, 300.7600 C-Z.
IARC. 2002. Volume 82: Some traditional herbal medicines, some mycotoxins, naphthalene and styrene. IARC Monographs on the evaluation of carcinogenic risks to humans. Lyon, France: International Agency for Research on Cancer. https://monographs.iarc.who.int/wp-content/uploads/2018/06/mono82.pdf. April 19, 2023.
IRIS. 1998. Naphthalene. CASRN 91-20-3. Integrated Risk Information System. Chemical assessment summary. U.S. Environmental Protection Agency. https://iris.epa.gov/static/pdfs/0436_summary.pdf. May 9, 2022.
IRIS. 2003. 2-Methylnaphthalene. CASRN 91-57-6. Integrated Risk Information System. Chemical assessment summary. U.S. Environmental Protection Agency. https://iris.epa.gov/static/pdfs/0436_summary.pdf. May 9, 2022.
Jia C, Batterman S. 2011. A critical review of naphthalene sources and exposures relevant to indoor and outdoor air. Int J Environ Res Public Health 7(7):2903–2939. 10.3390/ijerph7072903.
Jia C, Xue Z, Fu X, . 2020. Impacts of Independence Day fireworks on pollution levels of atmospheric polycyclic aromatic hydrocarbons (PAHs) in the U.S. Sci Total Environ 743:140774. 10.1016/j.scitotenv.2020.140774.32659565
Jimenez A, Adisa A, Woodham C, . 2014. Determination of polycyclic aromatic hydrocarbons in roasted coffee. J Environ Sci Health B 49(11):828–835. 10.1080/03601234.2014.938552.25190557
Jin M, Kijima A, Suzuki Y, . 2012. In vivo genotoxicity of 1-methylnaphthalene from comprehensive toxicity studies with B6C3F1 gpt delta mice. J Toxicol Sci 37(4):711–721. 10.2131/jts.37.711.22863852
Jin H, Zhao C, Chen Y, . 2024. Environmental exposure to polycyclic aromatic hydrocarbons: An underestimated risk factor for systemic lupus erythematosus onset and progression. Sci Total Environ 926:171841. 10.1016/j.scitotenv.2024.171841.38513863
Jing L, Chen B, Zhang B, . 2014. Naphthalene degradation in seawater by UV irradiation: the effects of fluence rate, salinity, temperature and initial concentration. Mar Pollut Bull 81(1):149–156. 10.1016/j.marpolbul.2014.02.003.24576392
John EM, Keegan TH, Terry MB, . 2022a. Urinary biomarkers of polycyclic aromatic hydrocarbons and timing of pubertal development: The California PAH study. Epidemiology 33(6):777–787. 10.1097/ede.0000000000001535.35895514
John EM, Koo J, Ingles SA, . 2022b. Predictors of urinary polycyclic aromatic hydrocarbon metabolites in girls from the San Francisco Bay Area. Environ Res 205:112534. 10.1016/j.envres.2021.112534.34896321
Jonsson G, Bechmann RK, Bamber SD, . 2004. Bioconcentration, biotransformation, and elimination of polycyclic aromatic hydrocarbons in sheepshead minnows (Cyprinodon variegatus) exposed to contaminated seawater. Environ Toxicol Chem 23(6):1538–1548. 10.1897/03-173.15376540
Juchau MR, Boutelet-Bochan H, Huang Y. 1998. Cytochrome-P450-dependent biotransformation of xenobiotics in human and rodent embryonic tissues. Drug Metab Rev 30(3):541–568. 10.3109/03602539808996324.9710705
Kaden DA, Hites RA, Thilly WG. 1979. Mutagenicity of soot and associated polycyclic aromatic hydrocarbons to Salmonella typhimurium. Cancer Res 39(10):4152–4159.383281
Kaikiti C, Stylianou M, Agapiou A. 2022. TD-GC/MS analysis of indoor air pollutants (VOCs, PM) in hair salons. Chemosphere 294:133691. 10.1016/j.chemosphere.2022.133691.35065178
Kalmykova Y, Björklund K, Strömvall AM, . 2013. Partitioning of polycyclic aromatic hydrocarbons, alkylphenols, bisphenol A and phthalates in landfill leachates and stormwater. Water Res 47(3):1317–1328. 10.1016/j.watres.2012.11.054.23295068
Kamal A, Malik RN, Martellini T, . 2014. PAH exposure biomarkers are associated with clinico-chemical changes in the brick kiln workers in Pakistan. Sci Total Environ 490:521–527. 10.1016/j.scitotenv.2014.05.033.24878696
Kanekal S, Plopper C, Morin D, . 1990. Metabolic activation and bronchiolar cell necrosis from naphthalene in the isolated perfused mouse lung. J Pharmacol Exp Ther 252(1):428–437.2299600
Kanekal S, Plopper C, Morin D, . 1991. Metabolism and cytotoxicity of naphthalene oxide in the isolated perfused mouse lung. J Pharmacol Exp Ther 256(1):391–401.1988668
Kappeler T, Wuhrmann K. 1978. Microbial degradation of the water-soluble fraction of gas oil - I. Water Res 12:327–333. 10.1016/0043-1354(78)90120-3.
Kapraun DF, Schlosser PM, Nylander-French LA, . 2020. A physiologically based pharmacokinetic model for naphthalene with inhalation and skin routes of exposure. Toxicol Sci 177(2):377–391. 10.1093/toxsci/kfaa117.32687177
Kapuci M, Ulker Z, Gurkan S, . 2014. Determination of cytotoxic and genotoxic effects of naphthalene, 1-naphthol and 2-naphthol on human lymphocyte culture. Toxicol Ind Health 30(1):82–89. 10.1177/0748233712451772.22740618
Karagiannis TC, Li X, Tang MM, . 2012. Molecular model of naphthalene-induced DNA damage in the murine lung. Hum Exp Toxicol 31(1):42–50. 10.1177/0960327111407228.21508073
Karickhoff SW. 1981. Semi-empirical estimation of sorption of hydrophobic pollutants on natural sediments and soils. Chemosphere 10(8):833–846. 10.1016/0045-6535(81)90083-7.
Katsnelson BA, Minigaliyeva IA, Degtyareva TD, . 2014. Does a concomitant exposure to lead influence unfavorably the naphthalene subchronic toxicity and toxicokinetics? Environ Toxicol Chem 33(1):152–157. 10.1002/etc.2405.24114755
Kedderis GL, Shepard KG, Recio L. 2014. Cytotoxicity of naphthalene toward cells from target and non-target organs in vitro. Chem Biol Interact 209:85–95. 10.1016/j.cbi.2013.12.003.24361489
Keimig SD, Morgan DP. 1986. Urinary 1-naphthol as a biological indicator of naphthalene exposure. Appl Ind Hyg 2:61–65. 10.1080/08828032.1986.10390469.
Kelsey JW, Alexander M. 1997. Declining bioavailability and inappropriate estimation of risk of persistent compounds. Environ Toxicol Chem 16(3):582–585. 10.1002/etc.5620160327.
Kelty JS, Keum C, Brown VJ, . 2020. Comparison of acute respiratory epithelial toxicity for 4-Methylimidazole and naphthalene administered by oral gavage in B6C3F1 mice. Regul Toxicol Pharmacol 116:104761. 10.1016/j.yrtph.2020.104761.32768664
Kenaga EE. 1980. Predicted bioconcentration factors and soil sorption coefficients of pesticides and other chemicals. Ecotoxicol Environ Safety 4:26–38. 10.1016/0147-6513(80)90005-6.7379718
Khalili Doroodzani A, Dobaradaran S, Akhbarizadeh R, . 2021. Diet, exposure to polycyclic aromatic hydrocarbons during pregnancy, and fetal growth: A comparative study of mothers and their fetuses in industrial and urban areas in Southwest Iran. Environ Pollut 276:116668. 10.1016/j.envpol.2021.116668.33611204
Khosravipour M, Khosravipour H. 2020. The association between urinary metabolites of polycyclic aromatic hydrocarbons and diabetes: A systematic review and meta-analysis study. Chemosphere 247:125680. 10.1016/j.chemosphere.2019.125680.32069705
Kim YM, Harrad S, Harrison RM. 2001. Concentrations and sources of VOCs in urban domestic and public microenvironments. Environ Sci Technol 35:997–1004. 10.1021/es000192y.11347947
Kim D, Andersen ME, Nylander-French LA. 2006. A dermatotoxicokinetic model of human exposures to jet fuel. Toxicol Sci 93(1):22–33. 10.1093/toxsci/kfl048.16801332
Kim YS, Lee MJ, Seo DS, . 2020. Thirteen-week inhalation toxicity study of 1-methylnaphthalene in F344 rats. Toxicol Res 36(1):13–20. 10.1007/s43188-019-00009-1.32042710
Kinman RN, Nutini DL, Carson D. 1995. Evaluation of leachate and gas from sanitary landfills with and without HHW components. In: 19^th^ Purdue industrial waste conference proceedings. Chelsea, MI: Lewis Publishers, 263–269.
Kipopoulou AM, Manoli E, Samara C. 1999. Bioconcentration of polycyclic aromatic hydrocarbons in vegetables grown in an industrial area. Environ Pollut 106:369–380. 10.1016/S0269-7491(99)00107-4.15093033
Kitchin KT, Brown JL, Kulkarni AP. 1992. Predictive assay for rodent carcinogenicity using in vivo biochemical parameters: Operational characteristics and complementarity. Mutat Res 266:253–272. 10.1016/0027-5107(92)90193-6.1373835
Kitchin KT, Brown JL, Kulkarni AP. 1994. Predicting rodent carcinogenicity by in vivo biochemical parameters. Environ Carcinog Ecotoxicol C12(1):63–88. 10.1080/10590509409373430.
Klecka GM, Davis JW, Gray DR, . 1990. Natural bioremediation of organic contaminants in ground water: Cliff-Dow Superfund site. Ground Water 28(4):534–543. 10.1111/j.1745-6584.1990.tb01709.x.
Kojima M. 1992. Enzymatic distribution patterns of rat lenses and the changes that occur during naphthalene cataract development. Ophthalmic Res 24:73–82. 10.1159/000267150.1608600
Korsak Z, Majcherek W, Rydzynski K. 1998. Toxic effects of acute inhalation exposure to 1-methylnaphthalene and 2-methylnaphthalene in experimental animals. Int J Occup Med Environ Health 11(4):335–342.10028200
Kostianen R. 1995. Volatile organic compounds in the indoor air of normal and sick houses. Atmos Environ 29(6):693–702. 10.1016/1352-2310(94)00309-9.
Kovalchuk N, Kelty J, Li L, . 2017. Impact of hepatic P450-mediated biotransformation on the disposition and respiratory tract toxicity of inhaled naphthalene. Toxicol Appl Pharmacol 329:1–8. 10.1016/j.taap.2017.05.015.28527914
Kovalchuk N, Zhang QY, Van Winkle L, . 2020. Contribution of pulmonary CYP-mediated bioactivation of naphthalene to airway epithelial injury in the lung. Toxicol Sci 177(2):334–346. 10.1093/toxsci/kfaa114.32974682
Krieg EF, Mathias PI, Toennis CA, . 2012. Detection of DNA damage in workers exposed to JP-8 jet fuel. Mutat Res 747(2):218–227. 10.1016/j.mrgentox.2012.05.005.22617435
Kulka U, Schmid E, Huber R, . 1988. Analysis of the cytogenetic effect in human lymphocytes induced by metabolically activated 1- and 2-methylnaphthalene. Mutat Res 208:155–158. 10.1016/0165-7992(88)90052-8.3398867
Kurz JM. 1987. Naphthalene poisoning: Critical care nursing techniques. Dimens Crit Care Nurs 6(5):264–270.3650149
Kuwada G, Murakami A, Glaser DW, . 2022. Mothball ingestion in the setting of G6PD deficiency causing severe hemolytic anemia, methemoglobinemia, and multiple organ failure in a toddler. Hawaii J Health Soc Welf 81(1):3–5.35028588
Lakritz J, Chang A, Weir A, . 1996. Cellular and metabolic basis of cell tolerance to multiple doses of cytochrome P450-activated cytotoxicants. I: Bronchiolar epithelial reorganization and expression of cytochrome P450 monooxygenases in mice exposed to multiple doses of naphthalene. J Pharmacol Exp Ther 278(3):1408–1418.8819528
Lan J, Wu S. 2023. Occurrence, concentration and toxicity of 54 polycyclic aromatic hydrocarbons in butter during storage. Foods 12(24):4393. 10.3390/foods12244393.38137197
Lanza DL, Code E, Crespi CL, . 1999. Specific dehydrogenation of 3-methylindole and epoxidation of naphthalene by recombinant human CYP2F1 expressed in lymphoblastoid cells. Drug Metab Dispos 27(7):798–803.10383923
Lau OW, Wong SK, Leung KS. 1994. Naphthalene contamination of sterilized milk drinks contained in low-density polyethylene bottles. Part 1. Analyst 119(5):1037–1042. 10.1039/AN9941901037.8067533
Lau OW, Wong SK, Leung KS. 1995. Naphthalene contamination of sterilized milk drinks contained in low-density polyethylene bottles. Part 2. Effect of naphthalene vapour in air. Analyst 120(4):1125–1128. 10.1039/AN9952001125.7771676
Lee K, Levin DL, Webb R, . 1997. Pulmonary alveolar proteinosis: High-resolution CT, chest radiographic, and functional correlations. Chest 111(4):989–995. 10.1378/chest.111.4.989.9106579
Lee MG, Phimister A, Morin D, . 2005. In situ naphthalene bioactivation and nasal airflow cause region-specific injury patterns in the nasal mucosa of rats exposed to naphthalene by inhalation. J Pharmacol Exp Ther 314(1):103–110. 10.1124/jpet.105.084517.15833892
Lehmann I, Rehwagen M, Diez U, . 2001. Enhanced in vivo IgE production and T cell polarization toward the type 2 phenotype in association with indoor exposure to VOC: Results of the LARS study. Int J Hyg Environ Health 204(4):211–221. 10.1078/1438-4639-00100.11833293
Lehmann I, Thoelke A, Rehwagen M, . 2002. The influence of maternal exposure to volatile organic compounds on the cytokine secretion profile of neonatal T cells. Environ Toxicol 17(3):203–210. 10.1002/tox.10055.12112628
Lezenius A. 1902. [A fall from naphthalene-induced cataracts in masons]. Klin Monatsbl Augenheilkd 40:129. (German)
Li HY, Gao PP, Ni HG. 2019a. Emission characteristics of parent and halogenated PAHs in simulated municipal solid waste incineration. Sci Total Environ 665:11–17. 10.1016/j.scitotenv.2019.02.002.30772539
Li Y, Cakmak S, Zhu J. 2019b. Profiles and monthly variations of selected volatile organic compounds in indoor air in Canadian homes: Results of Canadian national indoor air survey 2012-2013. Environ Int 126:134–144. 10.1016/j.envint.2019.02.035.30798194
Li L, Wei Y, Van Winkle L, . 2011. Generation and characterization of a CYP2F2-null mouse and studies on the role of CYP2F2 in naphthalene-induced toxicity in the lung and nasal olfactory mucosa. J Pharmacol Exp Ther 339(1):62–71. 10.1124/jpet.111.184671.21730012
Li L, Carratt S, Hartog M, . 2017. Human CYP2A13 and CYP2F1 mediate naphthalene toxicity in the lung and nasal mucosa of CYP2A13/2F1-humanized mice. Environ Health Perspect 125(6):067004. 10.1289/ehp844.28599267
Li K, Zou Y, Wang Y, . 2022. 2-Naphthalenemethanol participates in metabolic activation of 2-methylnaphthalene. Xenobiotica 52(4):360–369. 10.1080/00498254.2022.2079022.35575452
Liao W, Smith WD, Chiang TC. 1988. Rapid, low-cost cleanup procedure for determination of semivolatile organic compounds in human and bovine adipose tissues. J Assoc Off Anal Chem 71(4):742–747. 10.1093/jaoac/71.4.742.3417593
Lin CY, Isbell MA, Morin D, . 2005. Characterization of a structurally intact in situ lung model and comparison of naphthalene protein adducts generated in this model vs lung microsomes. Chem Res Toxicol 18(5):802–813. 10.1021/tx049746r.15892573
Lin TJ, Guo YL, Hsu JC, . 2018. 2-Naphthol levels and allergic disorders in children. Int J Environ Res Public Health 15(7):1449. 10.3390/ijerph15071449.29987264
Lin XY, Liu YX, Zhang YJ, . 2022. Polycyclic aromatic hydrocarbon exposure and DNA oxidative damage of workers in workshops of a petrochemical group. Chemosphere 303(Pt 2):135076. 10.1016/j.chemosphere.2022.135076.35649444
Lin N, Ding N, Meza-Wilson E, . 2023. Volatile organic compounds in disposable diapers and baby wipes in the US: A survey of products and health risks. Environ Sci Technol 57(37):13732–13743. 10.1021/acs.est.3c02862.37683294
Linick M. 1983. Illness associated with exposure to naphthalene in mothballs - Indiana. MMWR 32:34–35.6402657
Liu B, Jia C. 2015. Effects of exposure to mixed volatile organic compounds on the neurobehavioral test performance in a cross-sectional study of US adults. Int J Environ Health Res 25(4):349–363. 10.1080/09603123.2014.945514.25130197
Liu B, Xue Z, Zhu X, . 2017. Long-term trends (1990-2014), health risks, and sources of atmospheric polycyclic aromatic hydrocarbons (PAHs) in the U.S. Environ Pollut 220(Pt B):1171–1179. 10.1016/j.envpol.2016.11.018.27847130
Liu B, Huang F, Yu Y, . 2021. Polycyclic aromatic hydrocarbons (PAHs) in indoor dust across China: Occurrence, sources and cancer risk assessment. Arch Environ Contam Toxicol 81(3):482–491. 10.1007/s00244-021-00881-9.34427723
Liu C, Liu Q, Song S, . 2023. The association between internal polycyclic aromatic hydrocarbons exposure and risk of Obesity-A systematic review with meta-analysis. Chemosphere 329:138669. 10.1016/j.chemosphere.2023.138669.37059208
Liu J, Song R, Li X, . 2024. Effects of PM2.5 and its components on disease severity in patients with schizophrenia and the mediating role of thyroid hormones. Environ Health 2(5):290–300. 10.1021/envhealth.3c00194.
Long PH, Herbert RA, Peckham JC, . 2003. Morphology of nasal lesions in F344/N rats following chronic inhalation exposure to naphthalene vapors. Toxicol Pathol 31(6):655–664. 10.1080/01926230390242016.14585734
Lopes TJ, Furlong ET. 2001. Occurrence and potential adverse effects of semivolatile organic compounds in streambed sediment, United States 1992-1995. Environ Sci Technol 20(4):727–737. 10.1002/etc.5620200406.
Lorber M. 1972. Hematoxicity of synergized pyrethrin insecticides and related chemicals in intact, totally and subtotally splenectomized dogs. Acta Hepato-Gastroenterol 19:66–78.
Lu R, Wu J, Turco RP, . 2005. Naphthalene distributions and human exposure in Southern California. Atmos Environ 39(3):489–507. 10.1016/j.atmosenv.2004.09.045.
Luo K, Zeng Y, Li M, . 2021. Inhalation bioacessibility and absorption of polycyclic aromatic hydrocarbons (PAHs) in indoor PM(2.5) and its implication in risk assessment. Sci Total Environ 774:145770. 10.1016/j.scitotenv.2021.145770.33610976
Luthy RG, Dzombak DA, Peters CA, . 1994. Remediating tar-contaminated soils at manufactured gas plant sites. Environ Sci Technol 28(6):266A–276A. 10.1021/es00055a002.
MacGregor RR. 1954. Naphthalene poisoning from the ingestion of moth balls. Can Med Assoc J 70:313–314.13141205
Mackell JV, Rieders F, Brieger H, . 1951. Acute hemolytic anemia due to ingestion of naphthalene moth balls. I. Clinical aspects. Pediatrics 71:722–727.
Mamber SW, Bryson V, Katz SE. 1983. The Escherichia coli WP2/WP100 rec assay for detection of potential chemical carcinogens. Mutat Res 119:135–144. 10.1016/0165-7992(83)90121-5.6338367
Mamber SW, Bryson V, Katz SE. 1984. Evaluation of the Escherichia coli K12 inductest for detection of potential chemical carcinogens. Mutat Res 130:141–151. 10.1016/0165-1161(84)90116-X.6374442
Marco MP, Nasiri M, Kurth MJ, . 1993. Enzyme-linked immunosorbent assay for the specific detection of the mercapturic acid metabolites of naphthalene. Chem Res Toxicol 6:284–293. 10.1021/tx00033a006.8318650
Marczynski B, Preuss R, Mensing T, . 2005. Genotoxic risk assessment in white blood cells of occupationally exposed workers before and after alteration of the polycyclic aromatic hydrocarbon (PAH) profile in the production material: comparison with PAH air and urinary metabolite levels. Int Arch Occup Environ Health 78(2):97–108. 10.1007/s00420-004-0567-5.15726396
Marczynski B, Raulf-Heimsoth M, Spickenheuer A, . 2011. DNA adducts and strand breaks in workers exposed to vapours and aerosols of bitumen: associations between exposure and effect. Arch Toxicol 85(Suppl 1):S53–S64. 10.1007/s00204-011-0682-5.21380739
Mason RT. 2002. Naphthalene. In: Ley C, ed. Kirk-Othmer encyclopedia of chemical technology. Vol. 17. John Wiley & Sons, Inc., 1–25. 10.1002/0471238961.1401160813011915.a01.pub2.
Masoner JR, Kolpin DW, Furlong ET, . 2014. Contaminants of emerging concern in fresh leachate from landfills in the conterminous United States. Environ Sci Process Impacts 16(10):2335–2354. 10.1039/c4em00124a.25111596
Mathur P, Garg S. 2023. Acute kidney injury following naphthalene (mothball) poisoning. Saudi J Kidney Dis Transpl 34(3):259–264. 10.4103/1319-2442.394000.38231722
Mayer AC, Fent KW, Wilkinson A, . 2022. Characterizing exposure to benzene, toluene, and naphthalene in firefighters wearing different types of new or laundered PPE. Int J Hyg Environ Health 240:113900. 10.1016/j.ijheh.2021.113900.34902715
Mazzone P, Thomassen MJ, Kavuru M. 2001. Our new understanding of pulmonary alveolar proteinosis: What an internist needs to know. Cleve Clin J Med 68:977–985.11765122
McAdam KG, Faizi A, Kimpton H, . 2013. Polycyclic aromatic hydrocarbons in US and Swedish smokeless tobacco products. Chem Cent J 7(1):151. 10.1186/1752-153x-7-151.24011230
McCann J, Choi E, Yamasaki E, . 1975. Detection of carcinogens as mutagens in the Salmonella/microsome test: Assay of 300 chemicals. Proc Natl Acad Sci USA 72(12):5135–5139. 10.1073/pnas.72.12.5135.1061098
McCarley KD, Bunge AL. 2001. Pharmacokinetic models of dermal absorption. J Pharm Sci 90(11):1699–1719. 10.1002/jps.1120.11745728
McCormick S, Snawder JE, Chen IC, . 2022. Exposure assessment of polycyclic aromatic hydrocarbons in refined coal tar sealant applications. Int J Hyg Environ Health 242:113971. 10.1016/j.ijheh.2022.113971.35472749
McCoull KD, Rindgen D, Blair IA, . 1999. Synthesis and characterization of polycyclic aromatic hydrocarbon o-quinone depurinating N7-guanine adducts. Chem Res Toxicol 12:237–246. 10.1021/tx980182z.10077486
McDonald JD, Zielinska B, Jujita EM, . 2000. Fine particle and gaseous emission rates from residential wood combustion. Environ Sci Technol 34:2080–2091. 10.1021/es9909632.
McMurray WC. 1977. Nitrogen metabolism. In: Essentials of human metabolism. 2^nd^ ed. Philadelphia, PA: Harper & Row, 252–254.
Meeker JD, Ryan L, Barr DB, . 2004a. The relationship of urinary metabolites of carbaryl/naphthalene and chlorpyrifos with human semen quality. Environ Health Perspect 112(17):1665–1670. 10.1289/ehp.7234.15579410
Meeker JD, Singh NP, Ryan L, . 2004b. Urinary levels of insecticide metabolites and DNA damage in human sperm. Hum Reprod 19(11):2573–2580. 10.1093/humrep/deh444.15333606
Meeker JD, Ryan L, Barr DB, . 2006. Exposure to nonpersistent insecticides and male reproductive hormones. Epidemiology 17(1):61–68. 10.1097/01.ede.0000190602.14691.70.16357596
Meeker JD, Ravi SR, Barr DB, . 2008. Circulating estradiol in men is inversely related to urinary metabolites of nonpersistent insecticides. Reprod Toxicol 25(2):184–191. 10.1016/j.reprotox.2007.12.005.18249523
Mehdi Z, Gupta M, Kaur J, . 2023. Severe hemolytic anemia after mothball ingestion complicated by an undiagnosed enzyme deficiency: A case report. Cureus 15(11):e48733. 10.7759/cureus.48733.38094525
Melancon MJ, Rickert DE, Lech JJ. 1982. Metabolism of 2-methylnaphthalene in the rat in vivo: I. Identification of 2-naphthoylglycine. Drug Metab Dispos 10(2):128–133.6124397
Melancon MJ, Williams DE, Buhler DR, . 1985. Metabolism of 2-methylnaphthalene by rat and rainbow trout hepatic microsomes and purified cytochromes P-450. Drug Metab Dispos 13(5):542–547.2865100
Melzer-Lange M, Walsh-Kelly C. 1989. Naphthalene-induced hemolysis in a black female toddler deficient in glucose-6-phosphate dehydrogenase. Pediatr Emerg Care 5(1):24–26.2710663
Mendoza-Sanchez I, Uwak I, Myatt L, . 2022. Maternal exposure to polycyclic aromatic hydrocarbons in South Texas, evaluation of silicone wristbands as personal passive samplers. J Expo Sci Environ Epidemiol 32(2):280–288. 10.1038/s41370-021-00348-y.34131287
Meng F, Wang Y, Myers MB, . 2011. p53 codon 271 CGT to CAT mutant fraction does not increase in nasal respiratory and olfactory epithelia of rats exposed to inhaled naphthalene. Mutat Res 721(2):199–205. 10.1016/j.mrgentox.2011.02.004.21324376
Mersch-Sundermann V, Mochayedi S, Kevekordes S, . 1993. The genotoxicity of unsubstituted and nitrated polycyclic aromatic hydrocarbons. Anticancer Res 13(6A):2037–2043.8297112
Messier KP, Tidwell LG, Ghetu CC, . 2019. Indoor versus outdoor air quality during wildfires. Environ Sci Technol Lett 6(12):696–701. 10.1021/acs.estlett.9b00599.32095488
Miles AK, Roster N. 1999. Enhancement of polycyclic aromatic hydrocarbons in estuarine invertebrates by surface runoff at a decommissioned military fuel depot. Mar Environ Res 47(1):49–60. 10.1016/S0141-1136(98)00104-4.
Miles CJ, Delfino JJ. 1999. Priority pollutant polycyclic aromatic hydrocarbons in Florida sediments. Bull Environ Contam Toxicol 63:226–234. 10.1007/s001289900970.10441640
Minyard JP, Roberts WE. 1991. Chemical contaminants monitoring. State findings on pesticide residues in foods-1988 and 1989. J Assoc Off Anal Chem 74(3):438–452. 10.1093/jaoac/74.3.438.1874687
Mlyczyńska E, Bongrani A, Rame C, . 2023. Concentration of polycyclic aromatic hydrocarbons (PAHs) in human serum and adipose tissues and stimulatory effect of naphthalene in adipogenesis in 3T3-L1 cells. Int J Mol Sci 24(2):1455. 10.3390/ijms24021455.36674971
Mohapatra B, Phale PS. 2021. Microbial degradation of naphthalene and substituted naphthalenes: Metabolic diversity and genomic insight for bioremediation. Front Bioeng Biotechnol 9:602445. 10.3389/fbioe.2021.602445.33791281
Morgan B, Hansgen R, Hawthorne W, . 2015. Industrial odor sources and air pollutant concentrations in Globeville, a Denver, Colorado neighborhood. J Air Waste Manag Assoc 65(9):1127–1140. 10.1080/10962247.2015.1064833.26110447
Morris JB. 1999. A method for measuring upper respiratory tract vapor uptake and its applicability to quantitative inhalation risk assessment. Inhal Toxicol 11(10):943–965. 10.1080/089583799196727.10509028
Morris JB. 2013. Nasal dosimetry of inspired naphthalene vapor in the male and female B6C3F1 mouse. Toxicology 309:66–72. 10.1016/j.tox.2013.04.009.23619605
Morris JB, Buckpitt AR. 2009. Upper respiratory tract uptake of naphthalene. Toxicol Sci 111(2):383–391. 10.1093/toxsci/kfp138.19648534
Mortelmans K, Haworth S, Lawlor T, . 1986. Salmonella mutagenicity tests: II. Results from the testing of 270 chemicals. Environ Mutagen 8(Supplement 7):1–119. 10.1002/em.2860080703.
Mu G, Fan L, Zhou Y, . 2019. Personal exposure to PM_2.5_-bound polycyclic aromatic hydrocarbons and lung function alteration: Results of a panel study in China. Sci Total Environ 684:458–465. 10.1016/j.scitotenv.2019.05.328.31154218
Muhammad F, Monteiro-Riviere NA, Riviere JE. 2005. Comparative in vivo toxicity of topical JP-8 jet fuel and its individual hydrocarbon components: identification of tridecane and tetradecane as key constituents responsible for dermal irritation. Toxicol Pathol 33(2):258–266. 10.1080/01926230590908222.15902969
Mumtaz MM, Ray M, Crowell SR, . 2012a. Translational research to develop a human PBPK models tool kit-volatile organic compounds (VOCs). J Toxicol Environ Health A 75(1):6–24. 10.1080/15287394.2012.625546.22047160
Mumtaz M, Fisher J, Blount B, . 2012b. Application of physiologically based pharmacokinetic models in chemical risk assessment. J Toxicol 2012:904603. 10.1155/2012/904603.22523493
Murano H, Kojima M, Sasaki K. 1993. Differences in naphthalene cataract formation between albino and pigmented rat eyes. Ophthalmic Res 25:16–22. 10.1159/000267216.8446364
Murata Y, Emi Y, Denda A, . 1992. Ultrastructural analysis of pulmonary alveolar proteinosis induced by methylnaphthalene in mice. Exp Toxicol Pathol 44(1):47–54. 10.1016/S0940-2993(11)80137-5.1392517
Murata Y, Denda A, Maruyama H, . 1993. Chronic toxicity and carcinogenicity studies of 1-methylnaphthalene in B6C3F1 mice. Fundam Appl Toxicol 21(1):44–51. 10.1006/faat.1993.1070.8365584
Murata Y, Denda A, Maruyama H, . 1997. Chronic toxicity and carcinogenicity studies of 2-methylnaphthalene in B6C3F1 mice. Fundam Appl Toxicol 36(1):90–93. 10.1006/faat.1996.2283.9073471
Mwachiro MM, Pritchett N, Calafat AM, . 2021. Indoor wood combustion, carcinogenic exposure and esophageal cancer in southwest Kenya. Environ Int 152:106485. 10.1016/j.envint.2021.106485.33689906
Nakamura S, Oda Y, Shimada T, . 1987. SOS-inducing activity of chemical carcinogens and mutagens in Salmonella typhimurium TA1535/pSK1002: Examination with 151 chemicals. Mutat Res 192:239–246. 10.1016/0165-7992(87)90063-7.3317033
Narbonne JF, Cassand P, Alzieu P, . 1987. Structure-activity relationships of the N--methylcarbamate series in Salmonella typhimurium. Mutat Res 191:21–27. 10.1016/0165-7992(87)90165-5.3553926
NAS/NRC. 2006. Human biomonitoring for environmental chemicals. Washington, DC: The National Academies Press, National Research Council. 10.17226/11700.
Navarro KM, Cisneros R, Noth EM, . 2017. Occupational exposure to polycyclic aromatic hydrocarbon of wildland firefighters at prescribed and wildland fires. Environ Sci Technol 51(11):6461–6469. 10.1021/acs.est.7b00950.28498656
Nayak J, Jena SR, Kumar S, . 2023. Human sperm proteome reveals the effect of environmental borne seminal polyaromatic hydrocarbons exposome in etiology of idiopathic male factor infertility. Front Cell Dev Biol 11:1117155. 10.3389/fcell.2023.1117155.37261076
Neff JM, Burns WA. 1996. Estimation of polycyclic aromatic hydrocarbon concentrations in the water column based on tissue residues in mussels and salmon: An equilibrium partitioning approach. Environ Toxicol Chem 15(12):2240–2253. 10.1002/etc.5620151218.
Nie J, Li J, Cheng L, . 2018. Maternal urinary 2-hydroxynaphthalene and birth outcomes in Taiyuan, China. Environ Health 17(1):91. 10.1186/s12940-018-0436-4.30572877
NIOSH. 1980. Worker exposure to polyaromatic hydrocarbons at selected petroleum refinery process units of Sun Oil Refinery, Tulsa, Oklahoma. Cincinnati, OH: National Institute for Occupational Safety and Health. PB81236846. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB81236846.xhtml. April 19, 2023.
NIOSH. 1994. Naphthalene. Immediately dangerous to life or health concentrations (IDLH). National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/idlh/91203.html. May 10, 2022.
NIOSH. 2009. Environmental and biological assessment of environmental tobacco smoke exposure among casino dealers. Health Hazard Evaluation Report. National Institute for Occupational Safety and Health. HETA 2005-0076; 2005-0201-3080. https://www.cdc.gov/niosh/hhe/reports/pdfs/2005-0201-3080.pdf. April 5, 2024.
NIOSH. 2019. Naphthalene. NIOSH pocket guide to chemical hazards. National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgd0439.html. May 10, 2022.
NITE. 2009. 1-Methylnapthalene summary: [Combined repeat dose and reproductive/developmental toxicity screening test of 1-methylnaphthalene by oral administration in rats]. Japanese National Institute of Technology and Evaluation. https://www.nite.go.jp/chem/jcheck/tempfile_list.action?tpk=23402&ppk=7239&kinou=100&type=ja. November 30, 2022. (Japanese)
NITE. 2010a. Naphthalene - Bioaccumulation: aquatic/sediment. Japanese Chemicals and Collaborative Knowledge Database. Japanese National Institute of Technology and Evaluation. https://www.nite.go.jp/chem/jcheck/template.action?ano=27773&mno=4-0311&cno=91-20-3&request_locale=en. December 15, 2022.
NITE. 2010b. Naphthalene - Biodegradation in water: screening tests. Japanese Chemicals and Collaborative Knowledge Database. Japanese National Institute of Technology and Evaluation. https://www.nite.go.jp/chem/jcheck/template.action?ano=1428&mno=4-0311&cno=91-20-3&request_locale=en. December 15, 2022.
NLM. 2023a. Naphthalene. PubChem database. U.S. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/931. January 4, 2023.
NLM. 2023b. 1-Methylnaphthalene. PubChem database. U.S. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/7002. January 4, 2023.
NLM. 2023c. 2-Methylnaphthalene. PubChem database. U.S. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/7055. January 4, 2023.
NTP. 1980a. Subchronic toxicity study: Naphthalene (C52904), B6C3F1 mice. Research Triangle Park, NC: National Toxicology Program.
NTP. 1980b. Subchronic toxicity study: Naphthalene (C52904), Fischer 344 rats. Research Triangle Park, NC: National Toxicology Program.
NTP. 1991. Developmental toxicity of naphthalene in Sprague-Dawley (CD) rats. Research Triangle Park, NC: National Toxicology Program. TER91006. https://ntp.niehs.nih.gov/publications/abstracts/dev/ter91006/ter91006.html. April 21, 2022.
NTP. 1992a. Toxicology and carcinogenesis studies of naphthalene (CAS No. 91-20-3) in B6C3F1 mice (inhalation studies). Research Triangle Park, NC: National Toxicology Program. TR-410. NIH Publication No. 92-3141. https://ntp.niehs.nih.gov/publications/reports/tr/400s/tr410/index.html. April 19, 2023.
NTP. 1992b. Developmental toxicity of naphthalene in New Zealand white rabbits. Research Triangle Park, NC: National Toxicology Program. TER91021. https://ntp.niehs.nih.gov/publications/abstracts/dev/ter91021/ter91021.html. April 21, 2022.
NTP. 2000. Toxicology and carcinogenesis studies of naphthalene (CAS No. 91-20-3) in F344/N rats (inhalation studies). National Toxicology Program. TR-500. NIH Publication No. 01-4434. https://ntp.niehs.nih.gov/publications/reports/tr/500s/tr500/index.html. April 19, 2023.
NTP. 2013. Draft OHAT approach for systematic review and evidence integration for literature-based health assessments - February 2013. National Toxicology Program, Office of Health Assessment and Translation. https://ntp.niehs.nih.gov/ntp/ohat/evaluationprocess/draftohatapproach_february2013.pdf. May 9, 2022.
NTP. 2015. OHAT risk of bias rating tool for human and animal studies. National Toxicology Program, Office of Health Assessment and Translation. https://ntp.niehs.nih.gov/ntp/ohat/pubs/riskofbiastool_508.pdf. March 19, 2019.
NTP. 2021. Naphthalene. In: Report on carcinogens. 15^th^ ed. National Toxicology Program, https://ntp.niehs.nih.gov/ntp/roc/content/profiles/naphthalene.pdf. May 9, 2022.
NTSB. 2023. Norfolk Southern Railway train derailment with subsequent hazardous material release and fires. National Transportation Safety Board. Preliminary Report: RRD23MR005. https://www.ntsb.gov/investigations/Pages/RRD23MR005.aspx. September 5, 2023.
O’Brien KA, Smith LL, Cohen GM. 1985. Differences in naphthalene-induced toxicity in the mouse and rat. Chem Biol Interact 55:109–122. 10.1016/S0009-2797(85)80122-8.4064188
Ohnishi S, Hiraku Y, Hasegawa K, . 2018. Mechanism of oxidative DNA damage induced by metabolites of carcinogenic naphthalene. Mutat Res Genet Toxicol Environ Mutagen 827:42–49. 10.1016/j.mrgentox.2018.01.005.29502736
Ojwang PJ, Ahmed-Jushuf IH, Abdullah MS. 1985. Naphthalene poisoning following ingestion of moth balls: Case report. East Afr Med J 62(1):71–73.4006819
Oliver JR, Kushwah R, Wu J, . 2009. Gender differences in pulmonary regenerative response to naphthalene-induced bronchiolar epithelial cell injury. Cell Prolif 42(5):672–687. 10.1111/j.1365-2184.2009.00629.x.19614675
Oliver JR, Kushwah R, Wu J, . 2011. Elf3 plays a role in regulating bronchiolar epithelial repair kinetics following Clara cell-specific injury. Lab Invest 91(10):1514–1529. 10.1038/labinvest.2011.100.21709667
Olukanni OD, Albert AA, Farinto M, . 2023. Tween-80 enhanced biodegradation of naphthalene by Klebsiella quasipneumoniae. Antonie Van Leeuwenhoek 116(7):697–709. 10.1007/s10482-023-01839-8.37188845
Omurtag GZ, Güranlioğlu FD, Sehirli O, . 2005. Protective effect of aqueous garlic extract against naphthalene-induced oxidative stress in mice. J Pharm Pharmacol 57(5):623–630. 10.1211/0022357055939.15901351
Orjuela MA, Liu X, Miller RL, . 2012. Urinary naphthol metabolites and chromosomal aberrations in 5-year-old children. Cancer Epidemiol Biomarkers Prev 21(7):1191–1202. 10.1158/1055-9965.Epi-12-0214.22573794
Orzalesi N, Migliavacca L, Miglior S. 1994. Subretinal neovascularization after naphthalene damage to the rabbit retina. Invest Ophthalmol Vis Sci 35(2):696–705.8113020
OSHA. 2023a. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z-2. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. https://www.govinfo.gov/content/pkg/CFR-2023-title29-vol6/pdf/CFR-2023-title29-vol6-sec1910-1000.pdf. September 13, 2024.
OSHA. 2023b. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. https://www.govinfo.gov/content/pkg/CFR-2023-title29-vol7/pdf/CFR-2023-title29-vol7-sec1915-1000.pdf. September 13, 2024.
OSHA. 2023c. Safety and health regulations for construction. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55. https://www.govinfo.gov/content/pkg/CFR-2023-title29-vol8/pdf/CFR-2023-title29-vol8-sec1926-55.pdf. September 13, 2024.
Owa JA. 1989. Relationship between exposure to icterogenic agents, glucose-6-phosphate dehydrogenase deficiency and neonatal jaundice in Nigeria. Acta Paediatr Scand 78(6):848–852. 10.1111/j.1651-2227.1989.tb11162.x.2603709
Owa JA, Izedonmwen OE, Ogundaini AO, . 1993. Quantitative analysis of 1-naphthol in urine of neonates exposed to mothballs: the value in infants with unexplained anaemia. Afr J Med Med Sci 22(1):71–76.7839885
Paiva JHHGL, Júnior GBS, Magalhaes KDN, . 2022. Acute kidney injury following naphthalene poisoning in children. Nefrologia 42(3):356–359. 10.1016/j.nefroe.2022.05.004.36210125
Pakenham G, Lango J, Buonarati M, . 2002. Urinary naphthalene mercapturates as biomarkers of exposure and stereoselectivity of naphthalene epoxidation. Drug Metab Dispos 30(3):247–253.11854141
Papciak RJ, Mallory VT. 1990. Acute toxicological evaluation of naphthalene. J Am Coll Toxicol Part B 1(1):17–19.
Park KS, Sims RC, Dupont RR, . 1990. Fate of PAH compounds in two soil types: Influence of volatilization, abiotic loss and biological activity. Environ Toxicol Chem 9:187–195. 10.1002/etc.5620090208.
Passarella S, Guerriero E, Quici L, . 2022. PAHs presence and source apportionment in honey samples: Fingerprint identification of rural and urban contamination by means of chemometric approach. Food Chem 382:132361. 10.1016/j.foodchem.2022.132361.35152011
Patel MR, Patel BG. 2018. Anti-cataract activity of Garcinia indica against naphthalene-induced cataract in rats. Asian J Pharm Clin Res 11(6):208–211. 10.22159/AJPCR.2018.V11I6.24913.
Paulsson B, Bende M, Ohlin P. 1985. Nasal mucosal blood flow at rest and during exercise. Acta Otolaryngol 99(1–2):140–143. 10.3109/00016488509119156.3976386
Pellizzari ED, Hartwell TD, Harris BS, . 1982. Purgeable organic compounds in mother’s milk. Bull Environ Contam Toxicol 28(3):322–328. 10.1007/BF01608515.7082873
Peng S, Lu T, Liu Y, . 2022. Short-term exposure to fine particulate matter and its constituents may affect renal function via oxidative stress: A longitudinal panel study. Chemosphere 293:133570. 10.1016/j.chemosphere.2022.133570.35007609
Pereira WE, Hostettler FD, Luoma SN, . 1999. Sedimentary record of anthropogenic and biogenic polycyclic aromatic hydrocarbons in San Francisco Bay, California. Mar Chem 64(1–2):99–113. 10.1016/s0304-4203(98)00087-5.
Pham NT, Jewell WT, Morin D, . 2012. Analysis of naphthalene adduct binding sites in model proteins by tandem mass spectrometry. Chem Biol Interact 199(2):120–128. 10.1016/j.cbi.2012.05.009.22659010
Phimister AJ, Lee MG, Morin D, . 2004. Glutathione depletion is a major determinant of inhaled naphthalene respiratory toxicity and naphthalene metabolism in mice. Toxicol Sci 82(1):268–278. 10.1093/toxsci/kfh258.15319489
Phimister AJ, Williams KJ, Van Winkle LS, . 2006. Consequences of abrupt glutathione depletion in murine Clara cells: ultrastructural and biochemical investigations into the role of glutathione loss in naphthalene cytotoxicity. J Pharmacol Exp Ther 314(2):506–513. 10.1124/jpet.105.084533.
Phousongphouang PT, Arey J. 2002. Rate constants for the gas-phase reactions of a series of alkylnaphthalenes with the OH radical. Environ Sci Technol 36(9):1947–1952. 10.1021/es011434c.12026975
Phousongphouang PT, Arey J. 2003. Rate constants for the gas-phase reactions of a series of alkylnaphthalenes with the nitrate radical. Environ Sci Technol 37(2):308–313. 10.1021/es026015+.12564902
Plasterer MR, Bradshaw WS, Booth GM, . 1985. Developmental toxicity of nine selected compounds following prenatal exposure in the mouse: naphthalene, p-nitrophenol, sodium selenite, dimethyl phthalate, ethylenethiourea, and four glycol ether derivatives. J Toxicol Environ Health 15(1):25–38. 10.1080/15287398509530633.3981663
Platt KL, Aderhold S, Kulpe K, . 2008. Unexpected DNA damage caused by polycyclic aromatic hydrocarbons under standard laboratory conditions. Mutat Res 650(2):96–103. 10.1016/j.mrgentox.2007.09.011.18160334
Plopper CG, Suverkropp C, Morin D, . 1992. Relationship of cytochrome P-450 activity to cell cytotoxicity. I. Histopathologic comparison of the respiratory tract of mice, rats and hamsters after parenteral administration of naphthalene. J Pharmacol Exp Ther 261(1):353–363.1560379
Plowchalk DR, Andersen ME, Bogdanffy MS. 1997. Physiologically based modeling of vinyl acetate uptake, metabolism, and intracellular pH changes in the rat nasal cavity. Toxicol Appl Pharmacol 142(2):386–400. 10.1006/taap.1996.8052.9070362
Polak-Śliwińska M, Paszczyk B, Sliwinski M. 2022. Evaluation of polycyclic aromatic hydrocarbons in smoked cheeses made in Poland by HPLC method. Molecules 27(20):6909. 10.3390/molecules27206909.36296506
Poppendieck D, Gong M, Pham V. 2020. Influence of temperature, relative humidity, and water saturation on airborne emissions from cigarette butts. Sci Total Environ 712:136422. 10.1016/j.scitotenv.2019.136422.31931215
Probst GS, McMahon RE, Hill LE, . 1981. Chemically induced unscheduled DNA synthesis in primary rat hepatocyte cultures: A comparison with bacterial mutagenicity tests using 218 compounds. Environ Mutagen 3:11–32. 10.1002/em.2860030103.7021142
Purchase IF, Longstaff E, Ashby J, . 1978. An evaluation of 6 short-term tests for detecting organic chemical carcinogens. Br J Cancer 37(6):873–903. 10.1038/bjc.1978.132.354672
Ranjbar M, Rotondi MA, Ardern CI, . 2015. Urinary biomarkers of polycyclic aromatic hydrocarbons are associated with cardiometabolic health risk. PLoS One 10(9):e0137536. 10.1371/journal.pone.0137536.26340343
Rao GS, Pandya KP. 1981. Biochemical changes induced by naphthalene after oral administration in albino rats. Toxicol Lett 8(6):311–315. 10.1016/0378-4274(81)90119-3.7302961
Rappaport SM, Waidyanatha S, Serdar B. 2004. Naphthalene and its biomarkers as measures of occupational exposure to polycyclic aromatic hydrocarbons. J Environ Monit 6(5):413–416. 10.1039/b314088c.15152308
Rathbun WB, Holleschau AM, Murray DL, . 1990. Glutathione synthesis and glutathione redox pathways in naphthalene cataract of the rat. Curr Eye Res 9(1):45–53. 10.3109/02713689009000054.
Rawlins EL, Ostrowski LE, Randell SH, . 2007. Lung development and repair: contribution of the ciliated lineage. Proc Natl Acad Sci USA 104(2):410–417. 10.1073/pnas.0610770104.17194755
Recio L, Shepard KG, Hernández LG, . 2012. Dose-response assessment of naphthalene-induced genotoxicity and glutathione detoxication in human TK6 lymphoblasts. Toxicol Sci 126(2):405–412. 10.1093/toxsci/kfs012.22253058
Recio L, Fowler J, Martin L, . 2023. Genotoxicity assessment in HepaRG™ cells as a new approach methodology follow up to a positive response in the human TK6 cell micronucleus assay: Naphthalene case study. Environ Mol Mutagen 64(8–9):458–465. 10.1002/em.22575.37704589
RePORTER. 2024. Naphthalene. Research Portfolio Online Reporting Tools. National Institutes of Health. https://reporter.nih.gov/. October 7, 2024.
Rhodes AG, LeMasters GK, Lockey JE, . 2003. The effects of jet fuel on immune cells of fuel system maintenance workers. J Occup Environ Med 45(1):79–86. 10.1097/00043764-200301000-00016.12553182
Rittman BE, McCarty PL, Roberts PV. 1980. Trace-organics biodegradation in aquifer recharge. Ground Water 18(3):236–243. 10.1111/j.1745-6584.1980.tb03395.x.
Roberts PV, McCarty PL, Reinhard M, . 1980. Organic contaminant behavior during groundwater recharge. J Water Pollut Control Fed 52(1):161–172.
Roberts SM, Rohr AC, Mikheev VB, . 2018. Influence of airborne particulates on respiratory tract deposition of inhaled toluene and naphthalene in the rat. Inhal Toxicol 30(1):19–28. 10.1080/08958378.2018.1438539.29465005
Rodrigues EG, Smith K, Maule AL, . 2014. Urinary polycyclic aromatic hydrocarbon (OH-PAH) metabolite concentrations and the effect of GST polymorphisms among US Air Force personnel exposed to jet fuel. J Occup Environ Med 56(5):465–471. 10.1097/jom.0000000000000142.24806557
Rooney AA, Boyles AL, Wolfe MS, . 2014. Systematic review and evidence integration for literature-based environmental health science assessments. Environ Health Perspect 122(7):711–718. 10.1289/ehp.1307972.24755067
Rosenfeld JK, Plumb RH. 1991. Ground water contamination at wood treatment facilities. Ground Water Monit Rev 11:133–140. 10.1111/j.1745-6592.1991.tb00360.x.
Rossa V, Pau H. 1988. Is the experimental naphthalene cataract a model for human senile cataract? Graefes Arch Clin Exp Ophthalmol 226:291–293. 10.1007/BF02181199.3402753
Royce SG, Patel KP, Samuel CS. 2014b. Characterization of a novel model incorporating airway epithelial damage and related fibrosis to the pathogenesis of asthma. Lab Invest 94(12):1326–1339. 10.1038/labinvest.2014.119.25264707
Royce SG, Li X, Tortorella S, . 2014a. Mechanistic insights into the contribution of epithelial damage to airway remodeling. Novel therapeutic targets for asthma. Am J Respir Cell Mol Biol 50(1):180–192. 10.1165/rcmb.2013-0008OC.23980699
Rozman K, Summer KH, Rozman T, . 1982. Elimination of thioethers following administration of naphthalene and diethylmaleate to the Rhesus monkey. Drug Chem Toxicol 5(3):265–275. 10.3109/01480548209041057.7151720
Ruiz P, Ray M, Fisher J, . 2011. Development of a human Physiologically Based Pharmacokinetic (PBPK) Toolkit for environmental pollutants. Int J Mol Sci 12(11):7469–7480. 10.3390/ijms12117469.22174611
Rundell JO, Guntakatta M, Matthews EJ. 1983. Criterion development for the application of BALB/c-3T3 cells to routine testing for chemical carcinogenic potential. Environ Sci Res 27:309–324. 10.1007/978-1-4613-3611-2_22.
Saeed M, Higginbotham S, Rogan E, . 2007. Formation of depurinating N3adenine and N7guanine adducts after reaction of 1,2-naphthoquinone or enzyme-activated 1,2-dihydroxynaphthalene with DNA. Implications for the mechanism of tumor initiation by naphthalene. Chem Biol Interact 165(3):175–188. 10.1016/j.cbi.2006.12.007.17224140
Saeed M, Higginbotham S, Gaikwad N, . 2009. Depurinating naphthalene-DNA adducts in mouse skin related to cancer initiation. Free Radic Biol Med 47(7):1075–1081. 10.1016/j.freeradbiomed.2009.07.020.19619639
Sahni M, Vibert Y, Bhandari V, . 2019. Newborn infant with mothball toxicity due to maternal ingestion. Pediatrics 143(6):e20183619. 10.1542/peds.2018-3619.31064798
Sakai M, Yoshida D, Mizusaki S. 1985. Mutagenicity of polycyclic aromatic hydrocarbons and quinones on Salmonella typhimurium TA97. Mutat Res 156:61–67. 10.1016/0165-1218(85)90007-2.3889628
Sampaio GR, Guizellini GM, da Silva SA, . 2021. Polycyclic aromatic hydrocarbons in foods: Biological effects, legislation, occurrence, analytical methods, and strategies to reduce their formation. Int J Mol Sci 22(11):6010. 10.3390/ijms22116010.34199457
Santhanakrishnan BR, Ranganathan G, Balagopala Raju V. 1973. Naphthalene induced haemolytic anaemia with haemoglobinuria. Indian J Pediatr 40:195–197. 10.1007/BF02755155.4757445
Santucci K, Shah M. 2000. Association of naphthalene with acute hemolytic anemia. Acad Emerg Med 7(1):42–47. 10.1111/j.1553-2712.2000.tb01889.x.10894241
Sasaki JC, Arey J, Eastmond DA, . 1997. Genotoxicity induced in human lymphoblasts by atmospheric reaction products of naphthalene and phenanthrene. Mutat Res 393(1–2):23–35. 10.1016/S1383-5718(97)00083-1.9357559
Sax NI, Lewis RJ. 1987. Methylnaphthalenes. In: Hawley’s condensed chemical dictionary. New York, NY: Van Nostrand Reinhold Company, 775, 806.
Schafer WB. 1951. Acute hemolytic anemia related to naphthalene: Report of a case in a newborn infant. Pediatrics 7:172–174. 10.1542/peds.7.2.172.14827617
Schauer JJ, Kleeman MJ, Cass GR, . 1999. Measurement of emissions from air pollution sources. 1. C_1_ through C_29_ organic compounds from meat charbroiling. Environ Sci Technol 33(10):1566–1577. 10.1021/es980076j.
Schauer JJ, Kleeman MJ, Cass GR, . 2001. Measurement of emissions from air pollution sources. 3. C_1_-C_29_ organic compounds from fireplace combustion of wood. Environ Sci Technol 35:1716–1728. 10.1021/es001331e.11355184
Schauer JJ, Kleeman MJ, Cass GR, . 2002. Measurement of emissions from air pollution sources. 5. C_1_-C_32_ organic compounds from gasoline-powered motor vehicles. Environ Sci Technol 36(6):1169–1180. 10.1021/es0108077.11944666
Scherer G, Scherer M, Rögner N, . 2022. Assessment of the exposure to polycyclic aromatic hydrocarbons in users of various tobacco/nicotine products by suitable urinary biomarkers. Arch Toxicol 96(11):3113–3126. 10.1007/s00204-022-03349-4.35909193
Schmahl D. 1955. [The testing of naphthalene and anthracene for a carcinogenic effect on rats]. Z Krebsforsch 60:697–710. (German)13300517
Schmeltz I, Tosk J, Hoffman D. 1976. Formation and determination of naphthalene in cigarette smoke. Anal Chem 48(4):645–650. 10.1021/ac60368a031.1259162
Schmeltz I, Tosk J, Hilfrich J, . 1978. Bioassays of naphthalene and alkylnaphthalenes for co-carcinogenic activity. Relation to tobacco carcinogenesis. Carcinogenesis 3:47–60.
Schwarzenbach RP, Westall J. 1981. Transport of nonpolar organic compounds from surface water to groundwater. Laboratory sorption studies. Environ Sci Technol 15(11):1360–1367. 10.1021/es00093a009.
Schwarzenbach RP, Giger W, Hoehn E, . 1983. Behavior of organic compounds during infiltration of river water to groundwater. Environ Sci Technol 17:472–479. 10.1021/es00114a007.22283166
Scinicariello F, Buser MC. 2014. Urinary polycyclic aromatic hydrocarbons and childhood obesity: NHANES (2001-2006). Environ Health Perspect 122(3):299–303. 10.1289/ehp.1307234.24380973
Sehirli O, Tozan A, Omurtag GZ, . 2008. Protective effect of resveratrol against naphthalene-induced oxidative stress in mice. Ecotoxicol Environ Saf 71(1):301–308. 10.1016/j.ecoenv.2007.08.023.18261796
Seitz LM, Ram MS, Rengarajan R. 1999. Volatiles obtained from whole and ground grain samples by supercritical carbon dioxide and direct helium purge methods: Observations on 2,3-butanediols and halogenated anisoles. J Agric Food Chem 47:1051–1061. 10.1021/jf980795h.10552415
Serdar B, Egeghy PP, Waidyanatha S, . 2003. Urinary biomarkers of exposure to jet fuel (JP-8). Environ Health Perspect 111(14):1760–1764. 10.1289/ehp.6275.14594628
Serdar B, Egeghy PP, Gibson R, . 2004. Dose-dependent production of urinary naphthols among workers exposed to jet fuel (JP-8). Am J Ind Med 46(3):234–244. 10.1002/ajim.20049.15307122
Serdar B, Brindley S, Dooley G, . 2016. Short-term markers of DNA damage among roofers who work with hot asphalt. Environ Health 15(1):99. 10.1186/s12940-016-0182-4.27765036
Shafer G, Arunachalam A, Lohmann P. 2020. Newborn with perinatal naphthalene toxicity after maternal ingestion of mothballs during pregnancy. Neonatology 117(1):127–130. 10.1159/000504345.31751989
Shahrokny P, Maison N, Riemann L, . 2023. Increased breath naphthalene in children with asthma and wheeze of the All Age Asthma Cohort (ALLIANCE). J Breath Res 18(1):016003. 10.1088/1752-7163/acf23e.
Shahsavani S, Fararouei M, Soveid M, . 2022. Exposure to polycyclic aromatic hydrocarbon-induced oxidative stress in Shiraz, Iran: urinary levels, health risk assessment and mediation effect of MDA on the risk of metabolic syndromes. Int Arch Occup Environ Health 95(5):1043–1058. 10.1007/s00420-021-01822-8.34997324
Shane BS, Henry CB, Hotchkiss JH, . 1990. Organic toxicants and mutagens in ashes from eighteen municipal refuse incinerators. Arch Environ Toxicol 19(5):665–673. 10.1007/BF01183982.
Shannon K, Buchanan GR. 1982. Severe hemolytic anemia in black children with glucose-6-phosphate dehydrogenase deficiency. Pediatrics 70(3):364–369. 10.1542/peds.70.3.364.7110809
Sherris AR, Loftus CT, Szpiro AA, . 2024. Prenatal polycyclic aromatic hydrocarbon exposure and asthma at age 8-9 years in a multi-site longitudinal study. Environ Health 23(1):26. 10.1186/s12940-024-01066-2.38454435
Shopp GM, White KL JR, Holsapple MP, . 1984. Naphthalene toxicity in CD-1 mice: General toxicology and immunotoxicology. Fundam Appl Toxicol 4(3 Pt 1):406–419. 10.1016/0272-0590(84)90198-2.6745531
Shultz MA, Choudary PV, Buckpitt A. 1999. Role of murine cytochrome P-450 2F2 in metabolic activation of naphthalene and metabolism of other xenobiotics. J Pharmacol Exp Ther 290(1):281–288.10381788
Shultz MA, Morin D, Chang AM, . 2001. Metabolic capabilities of CYP2F2 with various pulmonary toxicants and its relative abundance in mouse lung subcompartments. J Pharmacol Exp Ther 296(2):510–519.11160638
Siddiqui TA, Zafar S, Iqbal N, . 2002. Effect of Kohl-Chikni Dawa - a compound ophthalmic formulation of Unani medicine on naphthalene-induced cataracts in rats. BMC Complement Altern Med 2:13. 10.1186/1472-6882-2-13.12503996
Siegel E, Wason S. 1986. Mothball toxicity. Pediatr Clin North Am 33(2):369–374.3515301
Siemering GS, Thiboldeaux R. 2021. Background concentration, risk assessment and regulatory threshold development: Polycyclic aromatic hydrocarbons (PAH) in Milwaukee, Wisconsin surface soils. Environ Pollut 268(Pt B):115772. 10.1016/j.envpol.2020.115772.33065477
Simms LA, Borras E, Chew BS, . 2021. Environmental sampling of volatile organic compounds during the 2018 Camp Fire in Northern California. J Environ Sci 103:135–147. 10.1016/j.jes.2020.10.003.
Sina JF, Bean CL, Dysart GR, . 1983. Evaluation of the alkaline elution/rat hepatocyte assay as a predictor of carcinogenic/mutagenic potential. Mutat Res 113:357–391. 10.1016/0165-1161(83)90228-5.6877265
Singh S, Singh J. 2004. Dermal toxicity and microscopic alterations by JP-8 jet fuel components in vivo in rabbit. Environ Toxicol Pharmacol 16(3):153–161. 10.1016/j.etap.2003.12.001.21782702
Singh A, Bodakhe SH. 2020. Resveratrol delay the cataract formation against naphthalene-induced experimental cataract in the albino rats. J Biochem Mol Toxicol 34(1):e22420. 10.1002/jbt.22420.31746523
Snyder JC, Zemke AC, Stripp BR. 2009. Reparative capacity of airway epithelium impacts deposition and remodeling of extracellular matrix. Am J Respir Cell Mol Biol 40(6):633–642. 10.1165/rcmb.2008-0334OC.18978301
Soliman YS, Wade TL. 2008. Estimates of PAHs burdens in a population of ampeliscid amphipods at the head of the Mississippi Canyon (N. Gulf of Mexico). Deep Sea Res Part II Top Stud Oceanogr 55(24–26):2577–2584. 10.1016/j.dsr2.2008.07.007.
Solomou N, Fernández E, Szafnauer R, . 2023. Total and bioavailable polycyclic aromatic hydrocarbons in unused and operated heat-not-burn tobacco products and conventional cigarettes. Chemosphere 335:139050. 10.1016/j.chemosphere.2023.139050.37247679
Sonar SS, Schwinge D, Kilic A, . 2010. Nerve growth factor enhances Clara cell proliferation after lung injury. Eur Respir J 36(1):105–115. 10.1183/09031936.00165508.20075049
Sorg RM, Naismith RW, Matthews RJ. 1985. Micronucleus test (MNT) OECD. Texaco, Inc. Submitted to the U.S. Environmental Protection Agency under TSCA section 8D. OTS0513639. 86-870000561. PH 309A-TX-007-85. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0513639.xhtml. April 19, 2023.
Southworth GR, Beauchamp JJ, Schmieder PK. 1978. Bioaccumulation potential of polycyclic aromatic hydrocarbons in Daphnia pulex. Water Res 12:973–977. 10.1016/0043-1354(78)90080-5.
Srivastava SK, Nath R. 1969. Metabolic alterations in experimental cataract. Part I. Inhibition of lactate dehydrogenase and appearance of o-diphenol oxidase in cataractous lens of naphthalene fed rabbits. Indian J Med Res 57(2):225–227.4977064
Stagge JH, Seagren EA, Song X. 2016. Sorption of naphthalene onto natural and surfactant-amended soils. J Environ Eng 142(4):06015010. 10.1061/(ASCE)EE.1943-7870.0001076.
Stamatelopoulou A, Dasopoulou M, Bairachtari K, . 2021. Contamination and potential risk assessment of polycyclic aromatic hydrocarbons (PAHs) and heavy metals in house settled dust collected from residences of young children. Appl Sci 11(4):1479. 10.3390/app11041479.
Stern GA, Macdonald CR, Carvalho PC, . 2023. Baseline levels and characterization of hydrocarbons in surface marine sediments along the transportation corridor in Hudson Bay: A multivariate analysis of n-alkanes, PAHs and biomarkers. Sci Total Environ 855:158718. 10.1016/j.scitotenv.2022.158718.36113804
Sterner TR, Covington TR, Mattie DR. 2023. Complex mixtures: Array PBPK modeling of jet fuel components. Toxics 11(2):187. 10.3390/toxics11020187.36851061
Stillwell WG, Horning MG, Griffin GW, . 1982. Identification of new sulfur-containing metabolites of naphthalene in mouse urine. Drug Metab Dispos 10(6):624–631.6130911
Sucker K, Zschiesche W, Aziz M, . 2021. Naphthalene: irritative and inflammatory effects on the airways. Int Arch Occup Environ Health 94(5):889–899. 10.1007/s00420-020-01636-0.33462664
Sudakin DL, Smit E, Cardenas A, . 2011. Naphthalene biomarkers and relationship with hemoglobin and hematocrit in White, Black, and Hispanic adults: results from the 2003-2004 National Health and Nutrition Examination Survey. J Med Toxicol 9(2):133–138. 10.1007/s13181-012-0262-y.
Sugiyama K, Wang T-C, Simpson JT, . 1999. Aldose reductase catalyzes the oxidation of naphthalene-1,2-dihydrodiol for the formation of ortho-naphthoquinone. Drug Metab Dispos 27(1):60–67.9884310
Summer KH, Rozman K, Coulston F, . 1979. Urinary excretion of mercapturic acids in chimpanzees and rats. Toxicol Appl Pharmacol 50:207–212. 10.1016/0041-008X(79)90145-5.505452
Sun Y, Kan Z, Zhang ZF, . 2023. Association of occupational exposure to polycyclic aromatic hydrocarbons in workers with hypertension from a northeastern Chinese petrochemical industrial area. Environ Pollut 323:121266. 10.1016/j.envpol.2023.121266.36780976
Sutherland KM, Edwards PC, Combs TJ, . 2012. Sex differences in the development of airway epithelial tolerance to naphthalene. Am J Physiol Lung Cell Mol Physiol 302(1):L68–L81. 10.1152/ajplung.00089.2011.22003090
Swartz E, Stockburger L, Vallero DA. 2003. Polycyclic aromatic hydrocarbons and other semivolatile organic compounds collected in New York City in response to the events of 9/11. Environ Sci Technol 37:3537–3546. 10.1021/es030356l.12953863
Sweeney LM, Gearhart JM. 2020. Examples of physiologically based pharmacokinetic modeling applied to risk assessment. In: Fisher JW, Gearhart JM, Lin Z, eds. Physiologically based pharmacokinetic (PBPK) modeling. Academic Press: 281–299. 10.1016/B978-0-12-818596-4.00011-4.
Świercz R, Wąsowicz W. 2018. The distribution and excretion of 1-methylnaphthalene in rats exposed to 1-methylnaphthalene by inhalation. Int J Occup Med Environ Health 31(6):763–770. 10.13075/ijomeh.1896.01224.30568313
Świercz R, Stępnik M. 2020. The effects of 1-methylnaphthalene after inhalation exposure on the serum corticosterone levels in rats. Int J Occup Med Environ Health 33(5):691–699. 10.13075/ijomeh.1896.01476.32801368
Świercz R, Wąsowicz W, Majcherek W. 2010. The toxicokinetics of 2-methylnaphtalene in rats. Int J Occup Med Environ Health 23(4):385–389. 10.2478/v10001-010-0026-3.21306984
Świercz R, Wąsowicz W, Stetkiewicz J, . 2011. 4-Week inhalation toxicity of 2-methylnaphthalene in experimental animals. Int J Occup Med Environ Health 24(4):399–408. 10.2478/s13382-011-0036-9.22002322
Świercz R, Stępnik M, Gromadzińska J, . 2022. Metabolism and in vitro assessment of the mutagenic activity of urinary extracts from rats after inhalation exposure to 1-methylnaphthalene. Int J Occup Med Environ Health 35(6):731–746. 10.13075/ijomeh.1896.01955.36169319
Tabak HH, Quave SA, Mashni CI, . 1981. Biodegradability studies with organic priority pollutant compounds. J Water Pollut Control Fed 53(10):1503–1518.
Tabatabaei Z, Shamsedini N, Mohammadpour A, . 2022. Exposure assessment of children living in homes with hookah smoking parents to polycyclic aromatic hydrocarbons: urinary level, exposure predictors, and risk assessment. Environ Sci Pollut Res Int 29(45):68667–68679. 10.1007/s11356-022-20589-0.35543784
Tan YM, Chan M, Chukwudebe A, . 2020. PBPK model reporting template for chemical risk assessment applications. Regul Toxicol Pharmacol 115:104691. 10.1016/j.yrtph.2020.104691.32502513
Tang KY. 2017. A patient presented with dark brown urine after mothballs powder ingestion. Clin Toxicol 55(7):674–675. 10.1080/15563650.2017.1305110.
Tannor EK, Hutton-Mensah KA. 2019. Naphthalene induced acute kidney injury in an African patient in Ghana: a case report. Pan Afr Med J 32:201. 10.11604/pamj.2019.32.201.17886.31312313
Tao RV, Holleschau AM, Rathbun WB. 1991. Naphthalene-induced cataract in the rat. II. Contrasting effects of two aldose reductase inhibitors on glutathione and glutathione redox enzymes. Ophthalmic Res 23(5):272–283. 10.1159/000267123.1784459
Tarshis IB. 1981. Uptake and depuration of petroleum hydrocarbons by crayfish. Arch Environ Contam Toxicol 10:79–86. 10.1007/BF01057577.7235744
Teeguarden JG, Bogdanffy MS, Covington TR, . 2008. A PBPK model for evaluating the impact of aldehyde dehydrogenase polymorphisms on comparative rat and human nasal tissue acetaldehyde dosimetry. Inhal Toxicol 20(4):375–390. 10.1080/08958370801903750.18302046
Teke G, Hubai K, Diósi D, . 2020. Assessment of foliar uptake and accumulation of airborne polyaromatic hydrocarbons under laboratory conditions. Bull Environ Contam Toxicol 104(4):444–448. 10.1007/s00128-020-02814-z.32152686
Teshima R, Nagamatsu K, Ikebuchi H, . 1983. In vivo and in vitro metabolism of 2-methylnaphthalene in the guinea pig. Drug Metab Dispos 11(2):152–157.6133721
Texaco. 1985a. Primary dermal irritation study in rabbits (83/EPA): Naphthalene. Texaco, Inc. Submitted to the U.S. Environmental Protection Agency under TSCA section 8D. OTS0513633. 86-870000555. PH 420-TX-013-84. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0513633.xhtml. April 19, 2023.
Texaco. 1985b. Rabbit eye irritation study (WASH): Naphthalene. Texaco, Inc. Submitted to the U.S. Environmental Protection Agency under TSCA section 8D. OTS0513634. 86-870000556. PH 421-TX-009-84. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0513634.xhtml. February 9, 2023.
Texaco. 1985c. Delayed contact hypersensitivity in guinea pigs: Naphthalene. Texaco, Inc. Submitted to the U.S. Environmental Protection Agency under TSCA section 8. OTS0513632. 86-870000554. PH 424-TX-001-84. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0513632.xhtml. April 19, 2023.
Texaco. 1985d. Dose-range-finding - developmental toxicity study in rabbits. Texaco, Inc. Submitted to the U.S. Environmental Protection Agency under TSCA section 8D. OTS0513640. 86870000562. PH 329DR-TX-001-85. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0513640.xhtml. February 10, 2023.
Texaco. 1986. Developmental toxicity study in rabbits: Naphthalene. Texaco, Inc. Submitted to the U.S. Environmental Protection Agency under TSCA section 8D. OTS0513641. 86-870000563. PH 329-TX-001-85. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0513641.xhtml. April 19, 2023.
Thangatorai R. 2022. Naphthalene-induced acute oxidative hemolysis with methemoglobinemia in glucose-6-phosphate dehydrogenase (G6PD) deficiency. Cureus 14(3):e23496. 10.7759/cureus.23496.35494903
Thomann RV. 1989. Bioaccumulation model of organic chemical distribution in aquatic food chains. Environ Sci Technol 23:699–707. 10.1021/es00064a008.
Thomas JM, Yordy JR, Amador JA, . 1986. Rates of dissolution and biodegradation of water-insoluble organic compounds. Appl Environ Microbiol 52(2):290–296. 10.1128/aem.52.2.290-296.1986.3092736
Thornton-Manning JR, Dahl AR. 1997. Metabolic capacity of nasal tissue interspecies comparisons of xenobiotic-metabolizing enzymes. Mutat Res 380:43–59. 10.1016/S0027-5107(97)00126-7.9385389
Tidwell LG, Allan SE, O’Connell SG, . 2016. PAH and OPAH flux during the deepwater horizon incident. Environ Sci Technol 50(14):7489–7497. 10.1021/acs.est.6b02784.27391856
Tingle MD, Pirmohamed M, Templeton E, . 1993. An investigation of the formation of cytotoxic, genotoxic, protein-reactive and stable metabolites from naphthalene by human liver microsomes. Biochem Pharmacol 46(9):1529–1538. 10.1016/0006-2952(93)90319-r.8240407
Toba H, Wang Y, Bai X, . 2015. XB130 promotes bronchioalveolar stem cell and Club cell proliferation in airway epithelial repair and regeneration. Oncotarget 6(31):30803–30817. 10.18632/oncotarget.5062.26360608
Tomasetig F, Tebby C, Graillot V, . 2020. Comparative genotoxic potential of 27 polycyclic aromatic hydrocarbons in three human cell lines. Toxicol Lett 326:99–105. 10.1016/j.toxlet.2020.03.007.32184089
Tonelli QJ, Custer RP, Sorof S. 1979. Transformation of cultured mouse mammary glands by aromatic amines and amides and their derivatives. Cancer Res 39:1784–1792.427810
Traynor GW, Apte MG, Sokol HA. 1990. Selected organic pollutant emissions from unvented kerosene space heaters. Environ Sci Technol 24:1265–1270. 10.1021/es00078a017.
TRI23. 2024. Naphthalene. TRI search. Washington, DC: Toxics Release Inventory. U.S. Environmental Protection Agency. https://www.epa.gov/enviro/tri-search. October 10, 2024.
Troester MA, Lindstrom AB, Waidyanatha S, . 2002. Stability of hemoglobin and albumin adducts of naphthalene oxide, 1,2-naphthoquinone, and 1,4-naphthoquinone. Toxicol Sci 68:314–321. 10.1093/toxsci/68.2.314.12151627
Tsuda H, Lee G, Farber E. 1980. Induction of resistant hepatocytes as a new principle for a possible short-term in vivo test for carcinogens. Cancer Res 40:1157–1164.6101993
Tsuruda LS, Lamé MW, Jones AD. 1995. Formation of epoxide and quinone protein adducts in B6C3F1 mice treated with naphthalene, sulfate conjugate of 1,4-dihydroxynaphthalene and 1,4-naphthoquinone. Arch Toxicol 69(6):362–367. 10.1007/s002040050185.7495373
Turkall RM, Skowronski GA, Kadry AM, . 1994. A comparative study of the kinetics and bioavailability of pure and soil-adsorbed naphthalene in dermally exposed male rats. Arch Environ Contam Toxicol 26(4):504–509. 10.1007/BF00214154.8198429
Turney GL, Goerlitz DF. 1990. Organic contamination of ground water at Gas Works Park, Seattle, Washington. Ground Water Monit Rev 10(3):187–198. 10.1111/j.1745-6592.1990.tb00014.x.
USGS. 2004. Methods of analysis of the U.S. Geological Survey National Water Quality Laboratory - Determination of polycyclic aromatic hydrocarbon compounds in sediment by gas chromatography/mass spectrometry. Reston, VA: U.S. Geological Survey. Water-Resources Investigations Report 03-4318. https://www.nemi.gov/methods/method_summary/8947/. November 21, 2023.
USGS. 2006. Determination of wastewater compounds in whole water by continuous liquid-liquid extraction and capillary-column gas chromatography/mass spectrometry. Reston, VA: U.S. Geological Survey. Techniques and Methods 5–B4. https://www.nemi.gov/methods/method_summary/99999997833/. November 21, 2023.
USGS. 2015. Water quality in principal aquifers of the United States, 1991-2010. Reston, VA: U.S. Geological Survey. Circular 1360. https://pubs.usgs.gov/circ/1360/pdf/circ1360report.pdf. February 8, 2023.
USGS. 2018. Supplemental material: Assessment of polycyclic aromatic hydrocarbon concentrations in southern Lake Powell, Glen Canyon National Recreation Area, Arizona and Utah, 2016-17. U.S. Geological Survey. .
USGS. 2019. Assessment of polycyclic aromatic hydrocarbon concentrations in southern Lake Powell, Glen Canyon National Recreation Area, Arizona and Utah, 2016-17. U.S. Geological Survey. SIR20195065. 10.3133/sir20195065.
Uthuman AAA, Jayasinghe CS, Fernando AHN. 2019. Acute intravascular hemolysis due to naphthalene toxicity: a case report. J Med Case Rep 13(1):91. 10.1186/s13256-018-1963-x.30898168
Valaes T, Doxiadis SA, Fessas P. 1963. Acute hemolysis due to naphthalene inhalation. J Pediatr 63(5):904–915. 10.1016/S0022-3476(63)80221-8.14071045
van der Hoeve J. 1906. [Chorioretinitis in humans from the effects of naphthalene]. Arch Augenheilkd 56:259–262. (German)
van Heyningen R, Pirie A. 1967. The metabolism of naphthalene and its toxic effect on the eye. Biochem J 102(3):842–852. 10.1042/bj1020842.16742501
Van Metre PC, Mahler BJ, Wilson JT. 2009. PAHs underfoot: contaminated dust from coal-tar sealcoated pavement is widespread in the United States. Environ Sci Technol 43(1):20–25. 10.1021/es802119h.19209579
Van Winkle LS, Isaac JM, Plopper CG. 1996. Repair of naphthalene-injured microdissected airways in vitro. Am J Respir Cell Mol Biol 15:1–8. 10.1165/ajrcmb.15.1.8679213.8679213
Van Winkle LS, Isaac JM, Plopper CG. 1997. Distribution of epidermal growth factor receptor and ligands during bronchiolar epithelial repair from naphthalene-induced Clara cell injury in the mouse. Am J Pathol 151(2):443–459.9250157
Van Winkle LS, Gunderson AD, Shimizu JA, . 2002. Gender differences in naphthalene metabolism and naphthalene-induced acute lung injury. Am J Physiol Lung Cell Mol Physiol 282(5):L1122–L1134. 10.1152/ajplung.00309.2001.11943679
Van Winkle LS, Brown CD, Shimizu JA, . 2004. Impaired recovery from naphthalene-induced bronchiolar epithelial injury in mice exposed to aged and diluted sidestream cigarette smoke. Toxicol Lett 154(1–2):1–9. 10.1016/j.toxlet.2004.06.007.15475173
Veith GD, DeFoe DL, Bergstedt BV, . 1979. Measuring and estimating the bioconcentration factor of chemicals in fish. J Fish Res Board Can 36:1040–1048. 10.1139/f79-146.
Verschueren K. 1983. 2-Methylnapthalene. In: Handbook of environmental data on organic chemicals. 2^nd^ ed. New York, NY: Van Nostrand Reinhold Company, 862–865, 890–899.
Volckaert T, Dill E, Campbell A, . 2011. Parabronchial smooth muscle constitutes an airway epithelial stem cell niche in the mouse lung after injury. J Clin Invest 121(11):4409–4419. 10.1172/jci58097.21985786
Waidyanatha S, Troester MA, Lindstrom AB, . 2002. Measurement of hemoglobin and albumin adducts of naphthalene-1,2-oxide, 1,2-naphthoquinone after administration of naphthalene to F344 rats. Chem Biol Interact 141(3):189–210. 10.1016/S0009-2797(02)00048-0.12385719
Wakeham SG, Davis AC, Karas IL. 1983. Mesocosm experiments to determine the fate and persistence of volatile organic compounds in coastal seawater. Environ Sci Technol 17:611–617. 10.1021/es00116a009.22288706
Wang BM, Stern EJ, Schmidt RA, . 1997. Diagnostic pulmonary alveolar proteinosis. A review and an update. Chest 111:460–466. 10.1378/chest.111.2.460.9041997
Wang BL, Pang ST, Zhang XL, . 2014. Levels and neurodevelopmental effects of polycyclic aromatic hydrocarbons in settled house dust of urban dwellings on preschool-aged children in Nanjing, China. Atmos Pollut Res 5(2):292–302. 10.5094/apr.2014.035.
Wang Y, Zhao H, Wang T, . 2019. Polycyclic aromatic hydrocarbons exposure and hematotoxicity in occupational population: A two-year follow-up study. Toxicol Appl Pharmacol 378:114622. 10.1016/j.taap.2019.114622.31195003
Wang D, Bruyneel B, Kamelia L, . 2020. In vitro metabolism of naphthalene and its alkylated congeners by human and rat liver microsomes via alkyl side chain or aromatic oxidation. Chem Biol Interact 315:108905. 10.1016/j.cbi.2019.108905.31765606
Wang Y, Zhu L, James-Todd T, . 2022a. Urinary polycyclic aromatic hydrocarbon excretion and regional body fat distribution: evidence from the U.S. National Health and Nutrition Examination Survey 2001-2016. Environ Health 21(1):75. 10.1186/s12940-022-00890-8.35945606
Wang F, Wang Y, Wang Y, . 2022b. Urinary polycyclic aromatic hydrocarbon metabolites were associated with hypertension in US adults: data from NHANES 2009-2016. Environ Sci Pollut Res Int 29(53):80491–80501. 10.1007/s11356-022-21391-8.35716300
Wang X, Li A, Xu Q. 2022c. The association between urinary polycyclic aromatic hydrocarbons metabolites and type 2 diabetes mellitus. Int J Environ Res Public Health 19(13):7605. 10.3390/ijerph19137605.35805265
Wang C, Wang W, Deng W, . 2023. Distribution characteristics, air-water exchange, ozone formation potential and health risk assessments of VOCs emitted from typical coking wastewater treatment process. Sci Total Environ 862:160845. 10.1016/j.scitotenv.2022.160845.36526193
Wanying L, Okromelidze MT, . 2023. The association of in-utero exposure to polycyclic aromatic hydrocarbons and umbilical liver enzymes. Sci Total Environ 889:164220. 10.1016/j.scitotenv.2023.164220.37211114
Warren DL, Brown DL, Buckpitt AR. 1982. Evidence for cytochrome P-450 mediated metabolism in the bronchiolar damage of naphthalene. Chem Biol Interact 40:287–303. 10.1016/0009-2797(82)90152-1.7083396
Weiss T, Breuer D, Bury D, . 2020. (Mono-) exposure to naphthalene in the abrasives industry: Air monitoring and biological monitoring. Ann Work Expo Health 64(9):982–992. 10.1093/annweh/wxaa062.32656562
Weissenfels WD, Klewer HJ, Langhoff J. 1992. Adsorption of polycyclic aromatic hydrocarbons (PAHs) by soil particles: influence on biodegradability and biotoxicity. Appl Microbiol Biotechnol 36(5):689–696. 10.1007/BF00183251.1368071
Weissinger RH, Blackwell BR, Keteles K, . 2018. Bioactive contaminants of emerging concern in National Park waters of the northern Colorado Plateau, USA. Sci Total Environ 636:910–918. 10.1016/j.scitotenv.2018.04.332.29729508
Wells PG, Wilson B, Lubek BM. 1989. In vivo murine studies on the biochemical mechanism of naphthalene cataractogenesis. Toxicol Appl Pharmacol 99:466–473. 10.1016/0041-008X(89)90154-3.2749733
West JAA, Buckpitt AR, Plopper CG. 2000. Elevated airway GSH resynthesis confers protection to cells from naphthalene injury in mice made tolerant by repeated exposures. J Pharmacol Exp Ther 294(2):516–523.10900227
West JAA, Pakehham G, Morin D, . 2001. Inhaled naphthalene causes dose dependent Clara cell cytotoxicity in mice but not in rats. Toxicol Appl Pharmacol 173(2):114–119. 10.1006/taap.2001.9151.11384213
Wheeler AJ, Dobbin NA, Héroux ME, . 2014. Urinary and breast milk biomarkers to assess exposure to naphthalene in pregnant women: an investigation of personal and indoor air sources. Environ Health 13(1):30. 10.1186/1476-069x-13-30.24767676
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. World Health Organization. https://www.who.int/publications/i/item/9789289002134. September 13, 2024.
WHO. 2022. Guidelines for drinking-water quality. Fourth edition incorporating the first and second addenda. World Health Organization. https://www.who.int/publications/i/item/9789240045064. June 22, 2022.
Wild SR, Waterhouse KS, McGrath SP, . 1990. Organic contaminants in an agricultural soil with a known history of sewage sludge amendments: Polynuclear aromatic hydrocarbons. Environ Sci Technol 24:1706–1711. 10.1021/es00081a013.
Willems BA, Melnick RL, Kohn MC, . 2001. A physiologically based pharmacokinetic model for inhalation and intravenous administration of naphthalene in rats and mice. Toxicol Appl Pharmacol 176(2):81–91. 10.1006/taap.2001.9269.11601884
Williams KJ, Cruikshank MK, Plopper CG. 2003. Pulmonary heat shock protein expression after exposure to a metabolically activated Clara cell toxicant: relationship to protein adduct formation. Toxicol Appl Pharmacol 192(2):107–118. 10.1016/s0041-008x(03)00302-8.14550745
Wilson NK, Kuhlman MR, Chuang JC. 1989. A quiet sampler for the collection of semivolatile organic pollutants in indoor air. Environ Sci Technol 23:1112–1116. 10.1021/es00067a008.
Wilson AS, Tingle MD, Kelly MD, . 1995. Evaluation of the generation of genotoxic and cytotoxic metabolites of benzo[a]pyrene, aflatoxin B1, naphthalene and tamoxifen using human liver microsomes and human lymphocytes. Hum Exp Toxicol 14:507–515. 10.1177/096032719501400608.8519528
Wilson AS, Davis CD, Williams DP, . 1996. Characterisation of the toxic metabolite(s) of naphthalene. Toxicology 114:233–242. 10.1016/S0300-483X(96)03515-9.8980712
Wilson NK, Chuang JC, Lyu C. 1999. Multimedia concentrations of PAH in several day care centers. Polycycl Aromat Compd 17(1–4):255–265. 10.1080/10406639908020620.
Woolf AD, Saperstien A, Zarwin J, . 1993. Radiopacity of household deodorizers, air fresheners, and moth repellents. J Toxicol Clin Toxicol 31(3):415–428. 10.3109/15563659309000410.8355318
WQP. 2023. Water quality portal data: Naphthalene, 1-methylnaphthalene, and 2-methylnaphthalene. Environmental Protection Agency (EPA); National Water Quality Monitoring Council (NWQMC); United States Geological Survey (USGS). https://www.waterqualitydata.us/portal/. August 30, 2023.
Wu X, Hu Y, Wang Q, . 2023. Study on the correlation between the dominant microflora and the main flavor substances in the fermentation process of cigar tobacco leaves. Front Microbiol 14:1267447. 10.3389/fmicb.2023.1267447.38075898
Xia Y, Han Y, Zhu P, . 2009. Relation between urinary metabolites of polycyclic aromatic hydrocarbons and human semen quality. Environ Sci Technol 43(12):4567–4573. 10.1021/es9000642.19603678
Xu GT, Zigler JS, Lou MF. 1992a. Establishment of a naphthalene cataract model in vitro. Exp Eye Res 54:73–81. 10.1016/0014-4835(92)90071-Y.1541343
Xu GT, Zigler JS, Lou MF. 1992b. The possible mechanism of naphthalene cataract in rat and its prevention by an aldose reductase inhibitor (AL01576). Exp Eye Res 54:63–72. 10.1016/0014-4835(92)90070-9.1541342
Xu J, Niehoff NM, White AJ, . 2022. Fossil-fuel and combustion-related air pollution and hypertension in the Sister Study. Environ Pollut 315:120401. 10.1016/j.envpol.2022.120401.36228848
Yamauchi T, Komura S, Yagi K. 1986. Serum lipid peroxide levels of albino rats administered naphthalene. Biochem Int 13(1):1–6.3753501
Yang M, Koga M, Katoh T, . 1999. A study for the proper application of urinary naphthols, new biomarkers for airborne polycyclic aromatic hydrocarbons. Arch Environ Contam Toxicol 36(1):99–108. 10.1007/s002449900447.9828267
Yang P, Wang YX, Chen YJ, . 2017. Urinary polycyclic aromatic hydrocarbon metabolites and human semen quality in China. Environ Sci Technol 51(2):958–967. 10.1021/acs.est.6b04810.27966341
Ye X, Pan W, Li C, . 2020. Exposure to polycyclic aromatic hydrocarbons and risk for premature ovarian failure and reproductive hormones imbalance. J Environ Sci 91:1–9. 10.1016/j.jes.2019.12.015.
Yin S, Tang M, Chen F, . 2017. Environmental exposure to polycyclic aromatic hydrocarbons (PAHs): The correlation with and impact on reproductive hormones in umbilical cord serum. Environ Pollut 220(Pt B):1429–1437. 10.1016/j.envpol.2016.10.090.27838061
Yu X, Wang X, Bartha R, . 1990. Supercritical fluid extraction of coal tar contaminated soil. Environ Sci Technol 24:1732–1738. 10.1021/es00081a017.
Zelinkova Z, Wenzl T. 2015. The occurrence of 16 EPA PAHs in food - A review. Polycycl Aromat Compd 35(2–4):248–284. 10.1080/10406638.2014.918550.26681897
Zepp RG, Schlotzhauer PF. 1979. Photoreactivity of selected aromatic hydrocarbons in water. In: Jones PW, Leber P, eds. Polynuclear aromatic hydrocarbons. Ann Arbor, MI: Ann Arbor Science, 141–157.
Zhang X, Li Z. 2023. Co-PBK: a computational biomonitoring tool for assessing chronic internal exposure to chemicals and metabolites. Environ Sci Process Impacts 25(12):2167–2180. 10.1039/d3em00396e.37982278
Zhang X, Li Z. 2024. Assessing chronic gestational exposure to environmental chemicals in pregnant women: Advancing the co-PBK model. Environ Res 247:118160. 10.1016/j.envres.2024.118160.38199464
Zhang F, Zhang Y, Wang K, . 2015. Diallyl trisulfide inhibits naphthalene-induced oxidative injury and the production of inflammatory responses in A549 cells and mice. Int Immunopharmacol 29(2):326–333. 10.1016/j.intimp.2015.10.033.26548347
Zhang F, Zhang Y, Wang K, . 2016. Protective effect of diallyl trisulfide against naphthalene-induced oxidative stress and inflammatory damage in mice. Int J Immunopathol Pharmacol 29(2):205–216. 10.1177/0394632015627160.26813860
Zhang S, Li C, Li Y, . 2017. Bioaccessibility of PAHs in contaminated soils: Comparison of five in vitro methods with Tenax as a sorption sink. Sci Total Environ 601–602:968–974. 10.1016/j.scitotenv.2017.05.234.
Zhang Y, Wang X, Yang X, . 2022. Chemical mixture exposure patterns and obesity among U.S. adults in NHANES 2005-2012. Ecotoxicol Environ Saf 248:114309. 10.1016/j.ecoenv.2022.114309.36427371
Zhang H, Liu R, Yang L, . 2023. Exposure to polycyclic aromatic hydrocarbons (PAHs) in outdoor air and respiratory health, inflammation and oxidative stress biomarkers: A panel study in healthy young adults. Sci Total Environ 899:165582. 10.1016/j.scitotenv.2023.165582.37467979
Zhang D, Liu X, Tu J, . 2024. Mediating role of glucose-lipid metabolism in the association between the increased risk of coronary heart disease and exposure to organophosphate esters, phthalates, and polycyclic aromatic hydrocarbons. Environ Health 2(3):170–179. 10.1021/envhealth.3c00155.
Zhao W, Ramos JS. 1998. Cytotoxic response profiles of cultured rat hepatocytes to selected aromatic hydrocarbons. Toxicol In Vitro 12:175–182. 10.1016/S0887-2333(97)00099-4.20654398
Zheng J, Cho M, Jones AD, . 1997. Evidence of quinone metabolites of naphthalene covalently bound to sulfur nucleophiles of proteins of Murine cells after exposure to naphthalene. Chem Res Toxicol 10(9):1008–1014. 10.1021/tx970061j.9305583
Zhou F, Onizawa S, Nagai A, . 2011. Epithelial cell senescence impairs repair process and exacerbates inflammation after airway injury. Respir Res 12(1):78. 10.1186/1465-9921-12-78.21663649
Zhu X, Lu Y. 2012. Selenium supplementation can slow the development of naphthalene cataract. Curr Eye Res 37(3):163–169. 10.3109/02713683.2011.639123.22273266
Zhu P, Bian Z, Xia Y, . 2009. Relationship between urinary metabolites of polycyclic aromatic hydrocarbons and thyroid hormone levels in Chinese non-occupational exposure adult males. Chemosphere 77(7):883–888. 10.1016/j.chemosphere.2009.08.054.19766290
Zhu X, Li J, Deng S, . 2016. Genome-wide analysis of DNA methylation and cigarette smoking in a Chinese population. Environ Health Perspect 124(7):966–973. 10.1289/ehp.1509834.26756918
Zinkham WH, Childs B. 1957. Effect of vitamin K and naphthalene metabolites on glutathione metabolism of erythrocytes from normal newborns and patients with naphthalene hemolytic anemia. Am J Dis Child 94(6):420–423.
Zinkham WH, Childs B. 1958. A defect of glutathione metabolism in erythrocytes from patients with a naphthalene-induced hemolytic anemia. Pediatrics 22(3):461–471. 10.1542/peds.22.3.461.13578538
Zitko V, Stenson G, Hellou J. 1998. Levels of organochlorine and polycyclic aromatic compounds in harp seal beaters (Phoca groenlandica). Sci Total Environ 221:11–29. 10.1016/S0048-9697(98)00159-4.9810732
Zuelzer WW, Apt L. 1949. Acute hemolytic anemia due to naphthalene poisoning: A clinical and experimental study. J Am Med Assoc 141(3):185–190. 10.1001/jama.1949.02910030015004.18139544