# VERSION HISTORY

Date | Description
April 2025 | Final toxicological profile released
May 2024 | Draft for public comment toxicological profile released
June 2005 | Final toxicological profile released
August 1995 | Final toxicological profile released
December 1990 | Final toxicological profile released