# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding naphthalene, 1-methylnaphthalene, and 2-methylnaphthalene in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for naphthalene, 1-methylnaphthalene, and 2-methylnaphthalene.

Table 7-1 Regulations and Guidelines Applicable to Naphthalene, 1-Methylnaphthalene, and 2-Methylnaphthalene

Agency | Description | Information | Reference
Air
EPA | RfC
EPA | Naphthalene | 3x10^−3^ mg/m^3^ (6x10^−4^ ppm) | IRIS 1998
EPA | Provisional peer-reviewed toxicity values
EPA | 1-Methylnaphthalene | | EPA 2024
EPA | Chronic provisional RfC | 3x10^−6^ mg/m^3^ (6x10^−7^ ppm) | EPA 2024
EPA | Subchronic provisional RfC | 3x10^−5^ mg/m^3^ (6x10^−6^ ppm) | EPA 2024
WHO | Indoor air quality guidelines
WHO | Naphthalene | 0.01 mg/m³ (2x10^−3^ ppm) annual average | WHO 2010
Water & Food
EPA | Drinking water standards and health advisories | | EPA 2018a
EPA | Naphthalene | | EPA 2018a
EPA | 1-Day health advisory (10-kg child) | 0.5 mg/L | EPA 2018a
EPA | 10-Day health advisory (10-kg child) | 0.5 mg/L | EPA 2018a
EPA | DWEL | 0.7 mg/L | EPA 2018a
EPA | Lifetime health advisory | 0.1 mg/L | EPA 2018a
EPA | 10^−4^ Cancer risk | No data | EPA 2018a
EPA | National primary drinking water regulations | Not listed | EPA 2023c
EPA | Chronic RfD (IRIS)
EPA | Naphthalene | 2x10^−2^ mg/kg/day | IRIS 1998
EPA | 2-Methylnaphthalene | 4x10^−3^ mg/kg/day | IRIS 2003
EPA | Provisional peer reviewed toxicity values
EPA | 1-Methylnaphthalene | | EPA 2024
EPA | Screening chronic provisional RfD | 1x10^−2^ mg/kg/day | EPA 2024
EPA | Screening subchronic provisional RfD | 2x10^−1^ mg/kg/day | EPA 2024
EPA | 2-Methylnaphthalene
EPA | Subchronic provisional RfD | 4x10^−3^ mg/kg/day | EPA 2007b
EPA | Human health risk assessment in support of registration review (OPP)
EPA | Naphthalene | | EPA 2018b
EPA | Chronic RfD | 0.1 mg/kg/day | EPA 2018b
EPA | Acute RfD | 0.4 mg/kg/day | EPA 2018b
WHO | Drinking water quality guidelines | Not listed | WHO 2022
FDA | Substances added to food^a^
FDA | 1-Methylnaphthalene | FEMA GRAS | FDA 2024
Cancer
HHS | Carcinogenicity classification
HHS | Naphthalene | Reasonably anticipated to be a human carcinogen | NTP 2021
EPA | Carcinogenicity classification
EPA | Naphthalene | Group C^b^ | IRIS 1998
EPA | Provisional peer reviewed toxicity values
EPA | 1-Methylnaphthalene | | EPA 2024
EPA | Cancer WOE descriptor, oral | Suggestive evidence of carcinogenic potential | EPA 2024
EPA | Cancer WOE descriptor, inhalation | Inadequate information to assess carcinogenic potential | EPA 2024
EPA | Screening provisional oral slope factor | 0.051 (mg/kg/day)^−1^ | EPA 2024
IARC | Carcinogenicity classification
IARC | Naphthalene | Group 2B^c^ | IARC 2002
Occupational
OSHA | PEL (8-hour TWA) for general industry, shipyards, and construction
OSHA | Naphthalene | 10 ppm (50 mg/m³) | OSHA 2023a, 2023b, 2023c
NIOSH | REL and IDLH
NIOSH | Naphthalene
NIOSH | REL TWA (up to 10-hour TWA) | 10 ppm (50 mg/m³) | NIOSH 2019
NIOSH | REL ST (15-minute TWA) | 15 ppm (75 mg/m³)
NIOSH | IDLH | 250 ppm | NIOSH 1994
Emergency Criteria
EPA | AEGLs-air | No data | EPA 2018c
DOE | PACs-air | | DOE 2024a
DOE | Naphthalene | | DOE 2024a
DOE | PAC-1^d^ | 15 ppm | DOE 2024a
DOE | PAC-2^d^ | 83 ppm | DOE 2024a
DOE | PAC-3^d^ | 500 ppm | DOE 2024a
DOE | 1-Methylnaphthalene | | DOE 2024a
DOE | PAC-1^d^ | 20 mg/m³ | DOE 2024a
DOE | PAC-2^d^ | 61 mg/m³ | DOE 2024a
DOE | PAC-3^d^ | 360 mg/m³ | DOE 2024a
DOE | 2-Methylnaphthalene | | DOE 2024a
DOE | PAC-1^d^ | 9 mg/m³ | DOE 2024a
DOE | PAC-2^d^ | 54 mg/m³ | DOE 2024a
DOE | PAC-3^d^ | 320 mg/m³ | DOE 2024a

a The Substances Added to Food inventory replaces EAFUS and contains the following types of ingredients: food and color additives listed in FDA regulations, flavoring substances evaluated by FEMA or JECFA, GRAS substances listed in FDA regulations, substances approved for specific uses in food prior to September 6, 1958, substances that are listed in FDA regulations as prohibited from use in food, delisted color additives, and some substances “no longer FEMA GRAS.”

b Group C: possible human carcinogen.

c Group 2B: possibly carcinogenic to humans.

d Definitions of PAC terminology are available from DOE (2024b).

AEGL = acute exposure guideline levels; DOE = Department of Energy; DWEL = drinking water equivalent level; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; FAO = Food and Agriculture Organization; FDA = Food and Drug Administration; FEMA = Flavor and Extract Manufacturers Association of the United States; GRAS = generally recognized as safe; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; JECFA = Joint FAO/WHO Expert Committee on Food Additives; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OPP = Office of Pesticide Programs; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; ST = short-term; TWA = time-weighted average; WHO = World Health Organization; WOE = weight of evidence