# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Naphthalene is a two-ringed aromatic hydrocarbon with a molecular formula of C_10_H_8_; it is the smallest PAH with two fused benzene rings. Both 1- and 2-methylnaphthalene contain a single methyl substituent in their structure, connected one (alpha) or two (beta) carbon atoms away from the joined rings. Information regarding the chemical identity of naphthalene, 1-methylnaphthalene, and 2-methyl-naphthalene is presented in Table 4-1.

Table 4-1 Chemical Identity of Naphthalene, 1-Methylnaphthalene, and 2-Methylnaphthalene

Characteristic | Naphthalene | 1-Methylnaphthalene | 2-Methylnaphthalene | Reference
Synonyms and registered trade name(s) | Tar camphor; albocarbon; naphthene; mothballs; moth-flakes; white tar; and others; Caswell No. 587® | Alpha-methyl-naphthalene; naphthalene, 1-methyl; naphthalene, alpha-methyl | Beta-methyl-naphthalene; naphthalene, 2-methyl; naphthalene, beta-methyl | NLM 2023a, 2023b, 2023c
Chemical formula | C_10_H_8_ | C_11_H_10_ | C_11_H_10_ | NLM 2023a, 2023b, 2023c
SMILES | C1=CC=C2C=CC=CC2=C1 | CC1=CC=CC2=CC=CC=C12 | CC1=CC2=CC=CC=C2C=C1 | NLM 2023a, 2023b, 2023c
Chemical structure | [image] | [image] | [image] | NLM 2023a, 2023b, 2023c
CAS Registry Number | 91-20-3 | 90-12-0 | 91-57-6 | NLM 2023a, 2023b, 2023c

CAS = Chemical Abstracts Service; SMILES = simplified molecular-input line-entry system

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Naphthalene is a white solid with a strong characteristic odor. Naphthalene has relatively low vapor pressure; it sublimes slowly at room temperature and appreciably above its melting point. It has low solubility in water but is very soluble in several organic solvents such as benzene, ethanol, and ether.

Information regarding the physical and chemical properties of naphthalene, 1-methylnaphthalene, and 2-methylnaphthalene is presented in Table 4-2.

Table 4-2 Physical and Chemical Properties of Naphthalene, 1-Methylnaphthalene, and 2-Methylnaphthalene

Property | Naphthalene | 1-Methyl-naphthalene | 2-Methyl-naphthalene | Reference
Molecular weight | 128.17 | 142.20 | 142.20 | NLM 2023a, 2023b, 2023c
Color | White | Colorless | No data | NLM 2023a, 2023b, 2023c
Physical state | Solid | Liquid | Solid | NLM 2023a, 2023b, 2023c
Melting point | 80.2°C | −22°C | 34.6°C | NLM 2023a, 2023b, 2023c
Boiling point | 217.9°C | 244°C | 241.1°C | NLM 2023a, 2023b, 2023c
Density at 20°C | 1.162 g/mL | 1.0202 g/mL | 1.0058 g/mL | NLM 2023a, 2023b, 2023c
Vapor density (air = 1) | 4.42 | 4.91 | No data | NLM 2023a, 2023b, 2023c
Odor | Strong (tar or mothballs) | No data | No data | NLM 2023a, 2023b, 2023c
Odor threshold:
Water | 0.021 mg/L; 6.80 mg/L | 0.0075 mg/L | 0.01 mg/L | Amoore and Hautala 1983; NLM 2023a; Verschueren 1983
Air | 0.44 mg/m^3^ | 0.12 mg/m^3^ | 0.0581– 0.2905 mg/m^3^ | NLM 2023a, 2023b, 2023c
Solubility:
Water at 25°C | 31 mg/L | 25.8 mg/L | 24.6 mg/L | NLM 2023a, 2023b, 2023c
Organic solvents | Soluble in benzene, alcohol, ether, acetone | Soluble in alcohol, ether, benzene | Soluble in alcohol, ether, benzene | NLM 2023a, 2023b, 2023c
Partition coefficients:
Log K_ow_ | 3.30 | 3.87 | 3.86 | NLM 2023a, 2023b, 2023c
Log K_oc_ | 2.05–3.97 | 3.36; 3.64 | 3.00–5.96 | NLM 2023a, 2023b, 2023c
Vapor pressure at 25°C | 0.085 mmHg (sublimes) | 0.067 mmHg | 0.055 mmHg | NLM 2023a, 2023b, 2023c
Henry’s law constant at 25°C | 4.4x10^−4^ atm-m^3^/mol | 5.14x10^−4^ atm-m^3^/mol | 5.18x10^−4^ atm-m^3^/mol | NLM 2023a, 2023b, 2023c
Autoignition temperature | 526°C | 529°C | No data | NLM 2023a, 2023b, 2023c
Flashpoint (closed cup) | 79°C | 82°C | 98°C | NLM 2023a, 2023b, 2023c
Vapor pressure at 25°C | 0.085 mmHg | 0.067 mmHg | 0.055 mmHg | NLM 2023a, 2023b, 2023c
Henry’s law constant at 25°C | 4.4x10^−4^ atm-m^3^/mol | 5.14x10^−4^ atm-m^3^/mol | 5.18x10^−4^ atm-m^3^/mol | NLM 2023a, 2023b, 2023c
Autoignition temperature | 526°C | 529°C | No data | NLM 2023a, 2023b, 2023c
Flashpoint (closed cup) | 79°C | 82°C | 98°C | NLM 2023a, 2023b, 2023c
Flammability limits | 0.9–5.9% | No data | No data | NLM 2023a, 2023b, 2023c
Conversion factors | 1 ppm=5.24 mg/m^3^; 1 mg/m^3^=0.191 ppm | 1 ppm=5.91 mg/m^3^; 1 mg/m^3^=0.17 ppm | 1 ppm=5.91 mg/m^3^; 1 mg/m^3^=0.17 ppm | Verschueren 1983
Explosive limits | No data | No data | No data