# APPENDIX C FRAMEWORK FOR ATSDR’S SYSTEMATIC REVIEW OF HEALTH EFFECTS DATA FOR NAPHTHALENE, 1-METHYLNAPHTHALENE, AND 2-METHYLNAPHTHALENE

To increase the transparency of ATSDR’s process of identifying, evaluating, synthesizing, and interpreting the scientific evidence on the health effects associated with exposure to naphthalene, 1-methylnaphthalene, and 2-methylnaphthalene, ATSDR utilized a slight modification of NTP’s Office of Health Assessment and Translation (OHAT) systematic review methodology (NTP 2013, 2015; Rooney et al. 2014). ATSDR’s framework is an eight-step process for systematic review with the goal of identifying the potential health hazards of exposure to naphthalene, 1-methylnaphthalene, and 2-methylnaphthalene:

- Step 1. Problem Formulation
- Step 2. Literature Search and Screen for Health Effects Studies
- Step 3. Extract Data from Health Effects Studies
- Step 4. Identify Potential Health Effect Outcomes of Concern
- Step 5. Assess the Risk of Bias for Individual Studies
- Step 6. Rate the Confidence in the Body of Evidence for Each Relevant Outcome
- Step 7. Translate Confidence Rating into Level of Evidence of Health Effects
- Step 8. Integrate Evidence to Develop Hazard Identification Conclusions

The systematic review for this profile is divided into four sections:

1. Steps 1, 2, and 3 for naphthalene, 1-methylnaphthalene, and 2-methylnaphthalene (Sections C.1, C.2, and C.3)
2. Steps 4, 5, 6, 7, and 8 for naphthalene (Sections C.4, C.5, C.6, C.7, and C.8)
3. Steps 4, 5, 6, 7, and 8 for 1-methylnaphthalene (Sections C.9, C.10, C.11, C.12, and C.13)
4. Steps 4, 5, 6, 7, and 8 for 2-methylnaphthalene (Sections C.14, C.15, C.16, C.17, and C.18)

## C.1 PROBLEM FORMULATION

The objective of the toxicological profile and this systematic review was to identify the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to naphthalene, 1-methylnaphthalene, and 2-methylnaphthalene. The inclusion criteria used to identify relevant studies examining the health effects of naphthalene, 1-methylnaphthalene, and 2-methylnaphthalene are presented in Table C-1.

Data from human and laboratory animal studies were considered relevant for addressing this objective. Human studies were divided into two broad categories: observational epidemiology studies and controlled exposure studies. The observational epidemiology studies were further divided: cohort studies (retrospective and prospective studies), population studies (with individual data or aggregate data), and case-control studies.

Table C-1 Inclusion Criteria for Identifying Health Effects Studies

Species; Human; Laboratory mammals
Route of exposure; Inhalation; Oral; Dermal (or ocular); Parenteral (these studies will be considered supporting data)
Health outcome; Death; Systemic effects; Body weight effects; Respiratory effects; Cardiovascular effects; Gastrointestinal effects; Hematological effects; Musculoskeletal effects; Hepatic effects; Renal effects; Dermal effects; Ocular effects; Endocrine effects; Immunological effects; Neurological effects; Reproductive effects; Developmental effects; Other noncancer effects; Cancer

## C.2 LITERATURE SEARCH AND SCREEN FOR HEALTH EFFECTS STUDIES

A literature search and screen were conducted to identify studies examining the health effects of naphthalene, 1-methylnaphthalene, and 2-methylnaphthalene. The literature search framework for the toxicological profile is discussed in detail in Appendix B.

### C.2.1 Literature Search

As noted in Appendix B, the literature searches were intended to update the Toxicological Profile for Naphthalene, 1-Methylnaphthalene, and 2-Methylnaphthalene. See Appendix B for the databases searched and the search strategy.

A total of 14,468 and 2,051 records relevant to all sections of the toxicological profile were identified in the initial and update literature search, respectively.

### C.2.2 Literature Screening

As described in Appendix B, a two-step process was used to screen the literature search to identify relevant studies examining the health effects of naphthalene, 1-methylnaphthalene, and 2-methylnaphthalene.

Title and Abstract Screen. In the Title and Abstract Screen step, 153 documents (inclusive of all literature searches) were considered to meet the health effects inclusion criteria in Table C-1 and were moved to the next step in the process.

Full Text Screen. In the second step in the literature screening process for the systematic review, a full text review of 153 health effect documents (documents identified in the update literature search and documents cited in older versions of the profile) was performed. From those 153 documents (169 studies), 39 documents (45 studies) were included in the qualitative review.

Naphthalene, 1-methylnaphthalene, and 2-methylnaphthalene are PAHs, and the epidemiological database for PAHs is extensive. Only studies presenting effect estimates specific to naphthalene, 1-methylnaphthalene, or 2-methylnaphthalene were included in the Toxicological Profile.

## C.3 EXTRACT DATA FROM HEALTH EFFECTS STUDIES

Relevant data extracted from the individual studies selected for inclusion in the systematic review were collected in customized data forms. A summary of the type of data extracted from each study is presented in Table C-2. For references that included more than one experiment or species, data extraction records were created for each experiment or species.

Table C-2 Data Extracted From Individual Studies

Citation
Chemical form
Route of exposure (e.g., inhalation, oral, dermal)
Specific route (e.g., gavage in oil, drinking water)
Species
Strain
Exposure duration category (e.g., acute, intermediate, chronic)
Exposure duration
Frequency of exposure (e.g., 6 hours/day, 5 days/week)
Exposure length
Number of animals or subjects per sex per group
Dose/exposure levels
Parameters monitored
Description of the study design and method
Summary of calculations used to estimate doses (if applicable)
Summary of the study results
Reviewer’s comments on the study
Outcome summary (one entry for each examined outcome)
No-observed-adverse-effect level (NOAEL) value
Lowest-observed-adverse-effect level (LOAEL) value
Effect observed at the LOAEL value

A summary of the extracted data for each study is presented in the Supplemental Documents for naphthalene, 1-methylnaphthalene, and 2-methylnaphthalene isomers and overviews of the results of the inhalation, oral, and dermal exposure studies are presented in Sections 2.2–2.18 of the profile and in the Levels Significant Exposures tables in Section 2.1 of the profile (Tables 2-1 through 2-6).

## C.4 IDENTIFY POTENTIAL HEALTH EFFECT OUTCOMES OF CONCERN—NAPHTHALENE

Overviews of the potential health effect outcomes for naphthalene identified in human and animal studies are presented in Tables C-3 and C-4, respectively. The human epidemiological studies examined a variety of endpoints; the largest number of studies evaluated reproductive and developmental endpoints. A number of case reports documented gastrointestinal symptoms. Many of the human studies used measures of naphthalene in blood or metabolites in urine to assess exposure, so the route is unknown; for the purpose of enumerations, these studies are considered to reflect inhalation exposure. Most of the animal studies used oral administration of naphthalene; there were very few dermal animal studies. The available animal studies primarily examined respiratory and ocular effects. The most sensitive effects in animal studies were respiratory, neurological, and immunological. Studies examining these potential outcomes were carried through to Steps 4–8 of the systematic review. There were 45 studies (published in 39 documents) examining these potential outcomes carried through to Steps 4–8 of the systematic review.

Table C-3 Overview of the Health Outcomes for Naphthalene Evaluated In Human Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological | Neurological | Reproductive | Developmental | Other Noncancer | Cancer
Inhalation studies
Cohort | | 3 | | | 2 | | | | | 2 | 1 | 2 | 1 | 3 | 1 | 2
Cohort | | 3 | | | 2 | | | | | 2 | 0 | 2 | 1 | 3 | 0 | 2
Case control | | | | | | | | | | | | | | 1 | | | 1
Case control | | | | | | | | | | | | | | 1 | | | 1
Population | | 1 | 3 | | | 1 | | | | | 1 | 2 | | 5 | 6 | 1
Population | | 1 | 2 | | | 1 | | | | | 0 | 2 | | 5 | 5 | 1
Case series | | | 1
Case series | | | 1
Oral studies
Cohort
Case control
Population | | | | 1
Population | | | | 1
Case series | | 1 | | 11 | 3 | | 4 | 7 | | | | | 6 | | 3 | 6
Case series | | 1 | | 11 | 3 | | 4 | 7 | | | | | 6 | | 3 | 6
Dermal studies
Cohort
Case control
Population
Case series | | | | | | | 2
Case series | | | | | | | 2

Number of studies examining endpoint | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10
Number of studies reporting outcome | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10

Table C-4 Overview of the Health Outcomes for Naphthalene Evaluated in Experimental Animal Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological^a^ | Neurological^a^ | Reproductive^a^ | Developmental | Other Noncancer | Cancer
Inhalation studies
Acute-duration | 4 | 14 | | | 1 | | | | | 1
Acute-duration | 0 | 13 | | | 0 | | | | | 1
Intermediate-duration | 1 | 1 | 1 | | | | 1 | 1 | | | 1 | 1 | 1 | 1
Intermediate-duration | 0 | 1 | 1 | | | | 0 | 0 | | | 0 | 1 | 0 | 0
Chronic-duration | 2 | 2 | 2 | 2 | | 2 | 2 | 2 | 2 | 1 | 2 | 2 | 2 | 2 | | 1 | 2
Chronic-duration | 0 | 2 | 0 | 0 | | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | | 0 | 2
Oral studies
Acute-duration | 2 | 4 | | | 3 | | 3 | 2 | | 2 | | 1 | 2 | 3 | 4
Acute-duration | 2 | 4 | | | 2 | | 2 | 0 | | 1 | | 1 | 1 | 1 | 2
Intermediate-duration | 6 | 3 | 2 | 2 | 5 | | 5 | 5 | | 21 | | 2 | 4 | 2
Intermediate-duration | 3 | 0 | 0 | 1 | 2 | | 2 | 2 | | 18 | | 1 | 2 | 0
Chronic-duration | | | | | | | | | | 1 | | | | | | | 1
Chronic-duration | | | | | | | | | | | | | | | | | 0
Dermal studies
Acute-duration | | | | | | | | | 4 | | | 1
Acute-duration | | | | | | | | | 2 | | | 0
Intermediate-duration | | 1 | 1 | 1 | 1 | | 1 | 1 | 1 | | | 1 | | 1
Intermediate-duration | | 0 | 0 | 0 | 0 | | 0 | 0 | 1 | | | 0 | | 1
Chronic-duration

Number of studies examining endpoint | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10
Number of studies reporting outcome | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10

a Number of studies examining endpoint includes studies evaluating histopathology, but not evaluating function.

## C.5 ASSESS THE RISK OF BIAS FOR INDIVIDUAL STUDIES—NAPHTHALENE

### C.5.1 Risk of Bias Assessment—Naphthalene

The risk of bias of individual studies was assessed using OHAT’s Risk of Bias Tool (NTP 2015). The risk of bias questions for observational epidemiology studies, human-controlled exposure studies, and animal experimental studies are presented in Tables C-5, C-6, and C-7, respectively. Each risk of bias question was answered on a four-point scale:

- Definitely low risk of bias (++)
- Probably low risk of bias (+)
- Probably high risk of bias (-)
- Definitely high risk of bias (− −)

In general, “definitely low risk of bias” or “definitely high risk of bias” were used if the question could be answered with information explicitly stated in the study report. If the response to the question could be inferred, then “probably low risk of bias” or “probably high risk of bias” responses were typically used.

Table C-5 Risk of Bias Questionnaire for Observational Epidemiology Studies

Selection bias; Were the comparison groups appropriate?
Confounding bias; Did the study design or analysis account for important confounding and modifying variables?
Attrition/exclusion bias; Were outcome data complete without attrition or exclusion from analysis?
Detection bias; Is there confidence in the exposure characterization?; Is there confidence in outcome assessment?
Selective reporting bias; Were all measured outcomes reported?

Table C-6 Risk of Bias Questionnaire for Human-Controlled Exposure Studies

Selection bias; Was administered dose or exposure level adequately randomized?; Was the allocation to study groups adequately concealed?
Performance bias; Were the research personnel and human subjects blinded to the study group during the study?
Attrition/exclusion bias; Were outcome data complete without attrition or exclusion from analysis?
Detection bias; Is there confidence in the exposure characterization?; Is there confidence in outcome assessment?
Selective reporting bias; Were all measured outcomes reported?

Table C-7 Risk of Bias Questionnaire for Experimental Animal Studies

Selection bias; Was administered dose or exposure level adequately randomized?; Was the allocation to study groups adequately concealed?
Performance bias; Were experimental conditions identical across study groups?; Were the research personnel blinded to the study group during the study?
Attrition/exclusion bias; Were outcome data complete without attrition or exclusion from analysis?
Detection bias; Is there confidence in the exposure characterization?; Is there confidence in outcome assessment?
Selective reporting bias; Were all measured outcomes reported?

After the risk of bias questionnaires were completed for the health effects studies, the studies were assigned to one of three risk of bias tiers based on the responses to the key questions listed below and the responses to the remaining questions.

- Is there confidence in the exposure characterization? (only relevant for observational studies)
- Is there confidence in the outcome assessment?
- Does the study design or analysis account for important confounding and modifying variables? (only relevant for observational studies)

First Tier. Studies placed in the first tier received ratings of “definitely low” or “probably low” risk of bias on the key questions AND received a rating of “definitely low” or “probably low” risk of bias on the responses to at least 50% of the other applicable questions.

Second Tier. A study was placed in the second tier if it did not meet the criteria for the first or third tiers.

Third Tier. Studies placed in the third tier received ratings of “definitely high” or “probably high” risk of bias for the key questions AND received a rating of “definitely high” or “probably high” risk of bias on the response to at least 50% of the other applicable questions.

The results of the risk of bias assessment for the naphthalene health effects studies (human observational epidemiology studies and experimental animal studies of respiratory, neurological, and immune system effects) are presented in Tables C-8 and C-9. There were no human controlled experimental studies of naphthalene.

Table C-8 Summary of Risk of Bias Assessment for Naphthalene—Observational Epidemiology Studies

Reference | Risk of bias criteria and ratings | | | | | | Risk of bias tier
Reference | Selection bias | Confounding bias | Attrition/exclusion bias | Detection bias | | Selective reporting bias | Risk of bias tier
Reference | Were the comparison groups appropriate? | Did the study design or analysis account for important confounding and modifying variables?^*^ | Were outcome data complete without attrition or exclusion from analysis? | Is there confidence in the exposure characterization?^*^ | Is there confidence in the outcome assessment?^*^ | Were all measured outcomes reported? | Risk of bias tier
Outcome: Respiratory effects
Cohort
Cilluffo et al. 2022 | – | – | ++ | ++ | – | + | Second
Mu et al. 2019 | – | – | ++ | + | + | + | Second
Sucker et al. 2021 | ++ | + | ++ | + | ++ | + | First
Zhang et al. 2023 | ++ | + | – | + | ++ | ++ | First
Cross-sectional
Cakmak et al. 2014 | – | – | + | + | + | – | Second
Outcome: Immunological effects
Cohort
Lehmann et al. 2001 | – | – | – | – | + | ++ | Third
Lehmann et al. 2002 | – | – | – | – | + | + | Third
Zhang et al. 2023 | + | + | – | + | ++ | ++ | First
Case-control
Aslam et al. 2023 | ++ | + | ++ | + | + | ++ | First
Jin et al. 2024 | + | ++ | ++ | + | + | ++ | First
Cross-sectional
Lin et al. 2018 | + | ++ | ++ | ++ | + | + | First
Rhodes et al. 2003 | – | – | – | + | + | + | Second
Outcome: Neurological effects
Cohort
Heaton et al. 2017 | + | + | ++ | ++ | + | + | First
Liu et al. 2024 | ++ | + | + | – | + | + | First

++ = definitely low risk of bias; + = probably low risk of bias; – = probably high risk of bias; – – = definitely high risk of bias; na = not applicable

* Key question used to assign risk of bias tier

Table C-9 Summary of Risk of Bias Assessment for Naphthalene—Experimental Animal Studies

Reference | Risk of bias criteria and ratings | | | | | | | | | Risk of bias tier
Reference | Selection bias | | Performance bias | | Attrition/exclusion bias | Detection bias | | Selective reporting bias | Other bias | Risk of bias tier
Reference | Was administered dose or exposure level adequately randomized? | Was the allocation to study groups adequately concealed? | Were experimental conditions identical across study groups? | Were the research personnel blinded to the study group during the study? | Were outcome data complete without attrition or exclusion from analysis? | Is there confidence in the exposure characterization? | Is there confidence in the outcome assessment?^*^ | Were all measured outcomes reported? | Did the study design or analysis account for important confounding and modifying variables? | Risk of bias tier
Outcome: Respiratory effects
Oral acute exposure
Kelty et al. 2020 (mouse, once) | – | – | + | – | + | + | + | ++ | NA | First
Shopp et al. 1984 (mouse, 14 days) | + | – | + | – | + | ++ | + | ++ | NA | First
Zhang et al. 2015 (mouse, once) | – | – | + | – | – | – | ++ | + | NA | Second
Zhang et al. 2016 (mouse, once) | – | – | – | – | – | – | ++ | + | NA | Second
Oral intermediate exposure
Germansky and Jamall 1988 (rat, 9 weeks) | – | – | ++ | – | – | – | + | ++ | NA | Second
NTP 1980b (rat, 13 weeks) | ++ | – | ++ | – | + | + | ++ | ++ | NA | First
NTP 1980a (mouse, 13 weeks) | ++ | – | ++ | – | + | + | ++ | ++ | NA | First
Shopp et al. 1984 (mouse, 90 days) | + | – | + | – | + | ++ | + | + | NA | First
Inhalation acute exposure
Cichocki et al. 2014 (rat, 4 or 6 hours) | – | – | ++ | – | – | + | + | + | NA | Second
Dodd et al. 2010 (rat, 6 hours) | + | – | ++ | – | ++ | + | + | ++ | NA | First
Dodd et al. 2010 (rat, 5 days) | + | – | ++ | – | ++ | + | + | ++ | NA | First
Lee et al. 2005 (rat, 4 hours) | – | – | ++ | – | – | + | + | + | NA | Second
West et al. 2001 (mouse, 4 hours) | – | – | ++ | – | – | – | + | + | NA | Second
West et al. 2001 (rat, 4 hours) | – | – | ++ | – | – | – | + | + | NA | Second
Carratt et al. 2016 (mouse, 4 hours) | – | – | ++ | – | – | – | ++ | + | NA | Second
Carratt et al. 2019b (mouse, 4 hours) | – | – | – | – | – | – | + | + | NA | Second
Kovalchuk et al. 2020 (mouse, 4 hours) | – | – | ++ | – | + | + | ++ | + | NA | First
Li et al. 2017 (mouse, 4 hours) | – | – | ++ | – | + | + | + | + | NA | First
Phimister et al. 2004 (mouse, 2 or 4 hours) | – | – | ++ | – | + | + | + | + | NA | First
Inhalation intermediate exposure
Dodd et al. 2012 (rat, 90 days) | ++ | – | ++ | – | + | + | + | ++ | NA | First
Inhalation chronic exposure
NTP 2000 (Abdo et al. 2001) (rat, 105 weeks) | – | – | ++ | – | ++ | ++ | ++ | ++ | NA | First
NTP 1992a (mouse, 104 weeks) | – | – | ++ | – | + | ++ | ++ | ++ | NA | First
Outcome: Neurological effects
Oral acute exposure
NTP 1991 (rat, 9-day gestational exposure) | + | – | ++ | – | ++ | ++ | + | ++ | NA | First
Shopp et al. 1984 (mouse, 14 days) | + | – | + | – | + | + | + | ++ | NA | First
Oral intermediate exposure
Katsnelson et al. 2014 (rat, 20 times over 40 days) | – | – | – | – | – | – | – | ++ | NA | Third
NTP 1980b (rat, 13 weeks) | ++ | – | ++ | – | + | ++ | – | ++ | NA | Second
NTP 1980a (mouse, 13 weeks) | ++ | – | ++ | – | – | + | – | ++ | NA | Second
Shopp et al. 1984 (mouse, 90 days) | + | – | + | – | + | ++ | – | + | NA | Second
Inhalation chronic exposure
NTP 2000 (Abdo et al. 2001) (rat, 105 weeks) | – | – | ++ | – | ++ | ++ | – | ++ | NA | Second
NTP 1992a (mouse, 104 weeks) | – | – | ++ | – | – | + | – | ++ | NA | Third
Outcome: Immune effects
Oral acute exposure
Shopp et al. 1984 (mouse, 14 days) | + | – | + | – | + | ++ | + | ++ | NA | First
Oral intermediate exposure
NTP 1980b (rat, 13 weeks) | ++ | – | ++ | – | + | ++ | ++ | ++ | NA | First
Shopp et al. 1984 (mouse, 90 days) | + | – | + | – | + | ++ | + | + | NA | First
Inhalation intermediate exposure
Dodd et al. 2012 (rat, 90 days) | ++ | – | ++ | – | + | + | + | ++ | NA | First

++ = definitely low risk of bias; + = probably low risk of bias; – = probably high risk of bias; – – = definitely high risk of bias; NA = not applicable

* Key question used to assign risk of bias tier

## C.6 RATE THE CONFIDENCE IN THE BODY OF EVIDENCE FOR EACH RELEVANT OUTCOME—NAPHTHALENE

Confidence in the body of human and animal evidence were evaluated independently for each potential outcome. ATSDR did not evaluate the confidence in the body of evidence for carcinogenicity; rather, the Agency defaulted to the cancer weight-of-evidence assessment of other agencies including HHS, EPA, and IARC. The confidence in the body of evidence for an association or no association between exposure to naphthalene and a particular outcome was based on the strengths and weaknesses of individual studies. Four descriptors were used to describe the confidence in the body of evidence for effects or when no effect was found:

- High confidence: the true effect is highly likely to be reflected in the apparent relationship
- Moderate confidence: the true effect may be reflected in the apparent relationship
- Low confidence: the true effect may be different from the apparent relationship
- Very low confidence: the true effect is highly likely to be different from the apparent relationship

Confidence in the body of evidence for a particular outcome was rated for each type of study: case-control, case series, cohort, population, human-controlled exposure, and experimental animal. In the absence of data to the contrary, data for a particular outcome were collapsed across animal species, routes of exposure, and exposure durations. If species (or strain), route, or exposure duration differences were noted, then the data were treated as separate outcomes.

### C.6.1 Initial Confidence Rating—Naphthalene

In ATSDR’s modification to the OHAT approach, the body of evidence for an association (or no association) between exposure to naphthalene and a particular outcome was given an initial confidence rating based on the key features of the individual studies examining that outcome. The presence of these key features of study design was determined for individual studies using four “yes or no” questions, which were customized for epidemiology, human controlled exposure, or experimental animal study designs. Separate questionnaires were completed for each outcome assessed in a study. The key features for observational epidemiology (cohort, population, and case-control) studies, human controlled exposure studies, and experimental animal studies are presented in Tables C-10, C-11, and C-12, respectively. The initial confidence in the study was determined based on the number of key features present in the study design:

- High Initial Confidence: Studies in which the responses to the four questions were “yes”.
- Moderate Initial Confidence: Studies in which the responses to only three of the questions were “yes”.
- Low Initial Confidence: Studies in which the responses to only two of the questions were “yes”.
- Very Low Initial Confidence: Studies in which the response to one or none of the questions was “yes”.

Table C-10 Key Features of Study Design for Observational Epidemiology Studies

Exposure was experimentally controlled
Exposure occurred prior to the outcome
Outcome was assessed on individual level rather than at the population level
A comparison group was used

Table C-11 Key Features of Study Design for Human Controlled Exposure Studies

A comparison group was used or the subjects served as their own control
A sufficient number of subjects were tested
Appropriate methods were used to measure outcomes (i.e., clinically-confirmed outcome versus self-reported)
Appropriate statistical analyses were performed and reported or the data were reported in such a way to allow independent statistical analysis

Table C-12 Key Features of Study Design for Experimental Animal Studies

A concurrent control group was used
A sufficient number of animals per group were tested
Appropriate parameters were used to assess a potential adverse effect
Appropriate statistical analyses were performed and reported or the data were reported in such a way to allow independent statistical analysis

The presence or absence of the key features and the initial confidence levels for studies examining respiratory, neurological, and immune system effects observed in the observational epidemiology and animal experimental studies are presented in Tables C-13 and C-14, respectively.

Table C-13 Presence of Key Features of Study Design for Naphthalene—Observational Epidemiology Studies

Reference | Key features | | | | Initial study confidence
Reference | Controlled exposure | Exposure prior to outcome | Outcomes assessed on an individual level | Comparison group | Initial study confidence
Respiratory effects:
Cohort
Cilluffo et al. 2022 | No | Yes | Yes | Yes | Moderate
Mu et al. 2019 | No | Yes | Yes | Yes | Moderate
Sucker et al. 2021 | No | Yes | Yes | Yes | Moderate
Zhang et al. 2023 | No | Yes | Yes | Yes | Moderate
Cross-sectional
Cakmak et al. 2014 | No | Yes | Yes | Yes | Moderate
Immune system effects:
Cohort
Lehmann et al. 2001 | No | Yes | Yes | Yes | Moderate
Lehmann et al. 2002 | No | Yes | Yes | Yes | Moderate
Zhang et al. 2023 | No | Yes | Yes | Yes | Moderate
Case-control
Aslam et al. 2023 | No | No | Yes | Yes | Low
Jin et al. 2024 | No | No | Yes | Yes | Low
Cross-sectional
Lin et al. 2018 | No | Yes | Yes | Yes | Moderate
Rhodes et al. 2003 | No | Yes | Yes | Yes | Moderate
Neurological effects:
Cohort
Heaton et al. 2017 | No | Yes | Yes | Yes | Moderate
Liu et al. 2024 | No | Yes | No | Yes | Low

Table C-14 Presence of Key Features of Study Design for Naphthalene—Experimental Animal Studies

Reference | Key feature | | | | Initial study confidence
Reference | Concurrent control group | Sufficient number of animals per group | Appropriate parameters to assess potential effect | Adequate data for statistical analysis | Initial study confidence
Outcome: Respiratory effects
Oral acute exposure
Kelty et al. 2020 (mouse, once) | Yes | No | Yes | Yes | Moderate
Shopp et al. 1984 (mouse, 14 days) | Yes | Yes | No | Yes | Moderate
Zhang et al. 2015 (mouse, once) | Yes | Yes | Yes | Yes | High
Zhang et al. 2016 (mouse, once) | Yes | Yes | Yes | Yes | High
Oral intermediate exposure
Germansky and Jamall 1988 (rat, 9 weeks) | Yes | No | No | No | Very Low
NTP 1980b (rat, 13 weeks) | Yes | Yes | Yes | Yes | High
NTP 1980a (mouse, 13 weeks) | Yes | Yes | Yes | Yes | High
Shopp et al. 1984 (mouse, 90 days) | Yes | Yes | No | Yes | Moderate
Inhalation acute exposure
Cichocki et al. 2014 (rat; 4 or 6 hours) | Yes | Yes | No | Yes | Moderate
Dodd et al. 2010 (rat, 6 hours) | Yes | Yes | Yes | Yes | High
Dodd et al. 2010 (rat, 5 days) | Yes | Yes | Yes | Yes | High
Lee et al. 2005 (rat, 4 hours) | Yes | No | Yes | Yes | Moderate
West et al. 2001 (rat, 4 hours) | Yes | No | Yes | Yes | Moderate
Carratt et al. 2016 (mouse, 4 hours) | Yes | No | Yes | Yes | Moderate
Carratt et al. 2019b (mouse, 4 hours) | Yes | No | Yes | Yes | Moderate
Kovalchuk et al. 2020 (mouse, 4 hours) | Yes | No | Yes | Yes | Moderate
Li et al. 2017 (mouse, 4 hours) | Yes | No | Yes | Yes | Moderate
Phimister et al. 2004 (mouse, 2 or 4 hours) | Yes | No | Yes | Yes | Moderate
West et al. 2001 (mouse, 4 hours) | Yes | No | Yes | Yes | Moderate
Inhalation intermediate exposure
Dodd et al. 2012 (rat, 90 days) | Yes | Yes | Yes | Yes | High
Inhalation chronic exposure
NTP 2000 (Abdo et al. 2001) (rat, 105 weeks) | Yes | Yes | Yes | Yes | High
NTP 1992a (mouse, 104 weeks) | Yes | Yes | Yes | Yes | High
Outcome: Immune effects
Oral acute exposure
Shopp et al. 1984 (mouse; 14 days) | Yes | Yes | Yes | Yes | Moderate
Oral intermediate exposure
NTP 1980b (rat, 13 weeks) | Yes | Yes | No | Yes | High
Shopp et al. 1984 (mouse, 90 days) | Yes | Yes | Yes | Yes | Moderate
Inhalation intermediate exposure
Dodd et al. 2012 (rat, 90 days) | Yes | Yes | No | Yes | High
Outcome: Neurological effects
Oral acute exposure
NTP 1991 (rat, 9-day gestational exposure) | Yes | Yes | No | Yes | Moderate
Shopp et al. 1984 (mouse, 14 days) | Yes | Yes | No | Yes | Moderate
Oral intermediate exposure
Katsnelson et al. 2014 (rat, 20 times over 40 days) | Yes | Yes | No | Yes | Moderate
NTP 1980b (rat, 13 weeks) | Yes | Yes | No | No | Low
NTP 1980a (mouse, 13 weeks) | Yes | Yes | No | No | Low
Shopp et al. 1984 (mouse, 90 days) | Yes | Yes | No | Yes | Moderate
Inhalation chronic exposure
NTP 2000 (Abdo et al. 2001) (rat, 105 weeks) | Yes | Yes | No | Yes | Moderate
NTP 1992a (mouse, 104 weeks) | Yes | Yes | No | Yes | Moderate

A summary of the initial confidence ratings for each outcome is presented in Table C-15. If individual studies for a particular outcome and study type had different study quality ratings, then the highest confidence rating for the group of studies was used to determine the initial confidence rating for the body of evidence; any exceptions were noted in Table C-15.

Table C-15 Initial Confidence Rating for Naphthalene Health Effects Studies

| Initial study confidence | Initial confidence rating
Outcome: Respiratory effects
Oral acute exposure
Animal studies
Kelty et al. 2020 (mouse, once) | Moderate | High
Shopp et al. 1984 (mouse, 14 days) | Moderate | High
Zhang et al. 2015 (mouse, once) | High | High
Zhang et al. 2016 (mouse, once) | High | High
Oral intermediate exposure
Animal studies
Germansky and Jamall 1988 (rat, 9 weeks) | Very Low | High
NTP 1980b (rat, 13 weeks) | High | High
NTP 1980a (mouse, 13 weeks) | High | High
Shopp et al. 1984 (mouse, 90 days) | Moderate | High
Inhalation acute exposure
Animal studies
Cichocki et al. 2014 (rat, 4 or 6 hours) | Moderate | High
Dodd et al. 2010 (rat, 6 hours) | High | High
Dodd et al. 2010 (rat, 5 days) | High | High
Lee et al. 2005 (rat, 4 hours) | Moderate | High
West et al. 2001 (rat, 4 hours) | Moderate | High
Carratt et al. 2016 (mouse, 4 hours) | Moderate | High
Carratt et al. 2019b (mouse, 4 hours) | Moderate | High
Kovalchuk et al. 2020 (mouse, 4 hours) | Moderate | High
Li et al. 2017 (mouse, 4 hours) | Moderate | High
Phimister et al. 2004 (mouse, 2 or 4 hours) | Moderate | High
West et al. 2001 (mouse, 4 hours) | Moderate | High
Inhalation intermediate exposure
Human studies
Cakmak et al. 2014 | Moderate | Moderate
Cilluffo et al. 2022 | Moderate | Moderate
Mu et al. 2019 | Moderate | Moderate
Zhang et al. 2023 | Moderate | Moderate
Animal studies
Dodd et al. 2012 (rat, 90 days) | High | High
Inhalation chronic exposure
Human studies
Sucker et al. 2021 | Moderate | Moderate
Animal studies
NTP 2000 (Abdo et al. 2001) (rat, 105 weeks) | High | High
NTP 1992a (mouse, 104 weeks) | High | High
Outcome: Immune effects
Oral acute exposure
Animal studies
Shopp et al. 1984 (mouse, 14 days) | High | High
Oral intermediate exposure
Animal studies
NTP 1980b (rat, 13 weeks) | Moderate | High
Shopp et al. 1984 (mouse, 90 days) | High | High
Inhalation intermediate exposure
Human studies
Aslam et al. 2023 | Low | Moderate
Jin et al. 2024 | Low | Moderate
Lehmann et al. 2001 | Moderate | Moderate
Lehmann et al. 2002 | Moderate | Moderate
Lin et al. 2018 | Moderate | Moderate
Rhodes et al. 2003 | Moderate | Moderate
Zhang et al. 2023 | Moderate | Moderate
Animal studies
Dodd et al. 2012 (rat, 90 days) | Moderate | Moderate
Outcome: Neurological effects
Oral acute exposure
Animal studies
NTP 1991 (rat, 9-day gestational exposure) | Moderate | Moderate
Shopp et al. 1984 (mouse, 14 days) | Moderate | Moderate
Oral intermediate exposure
Animal studies
Katsnelson et al. 2014 (rat, 20 times over 40 days) | Moderate | Moderate
NTP 1980b (rat, 13 weeks) | Low | Moderate
NTP 1980a (mouse, 13 weeks) | Low | Moderate
Shopp et al. 1984 (mouse, 90 days) | Moderate | Moderate
Inhalation chronic exposure
Human studies
Heaton et al. 2017 | Moderate | Moderate
Liu et al. 2024 | Low | Moderate
Animal studies
NTP 2000 (Abdo et al. 2001) (rat, 105 weeks) | Moderate | Moderate
NTP 1992a (mouse, 104 weeks) | Moderate | Moderate

### C.6.2 Adjustment of the Confidence Rating—Naphthalene

The initial confidence rating was then downgraded or upgraded depending on whether there were substantial issues that would decrease or increase confidence in the body of evidence. The nine properties of the body of evidence that were considered are listed below. The summaries of the assessment of the confidence in the body of evidence for hepatic effects are presented in Table C-16. If the confidence ratings for a particular outcome were based on more than one type of human study, then the highest confidence rating was used for subsequent analyses. An overview of the confidence in the body of evidence for all health effects associated with naphthalene exposure is presented in Table C-17.

Five properties of the body of evidence were considered to determine whether the confidence rating should be downgraded:

- Risk of bias. Evaluation of whether there is substantial risk of bias across most of the studies examining the outcome. This evaluation used the risk of bias tier groupings for individual studies examining a particular outcome. Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for risk of bias:
  ○ No downgrade if most studies are in the risk of bias first tier
  ○ Downgrade one confidence level if most studies are in the risk of bias second tier
  ○ Downgrade two confidence levels if most studies are in the risk of bias third tier
- Unexplained inconsistency. Evaluation of whether there is inconsistency or large variability in the magnitude or direction of estimates of effect across studies that cannot be explained. Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for unexplained inconsistency:
  ○ No downgrade if there is little inconsistency across studies or if only one study evaluated the outcome
  ○ Downgrade one confidence level if there is variability across studies in the magnitude or direction of the effect
  ○ Downgrade two confidence levels if there is substantial variability across studies in the magnitude or direction of the effect
- Indirectness. Evaluation of four factors that can affect the applicability, generalizability, and relevance of the studies:
  ○ Relevance of the animal model to human health—unless otherwise indicated, studies in rats, mice, and other mammalian species are considered relevant to humans
  ○ Directness of the endpoints to the primary health outcome—examples of secondary outcomes or nonspecific outcomes include organ weight in the absence of histopathology or clinical chemistry findings in the absence of target tissue effects
  ○ Nature of the exposure in human studies and route of administration in animal studies—inhalation, oral, and dermal exposure routes are considered relevant unless there are compelling data to the contrary
  ○ Duration of treatment in animal studies and length of time between exposure and outcome assessment in animal and prospective human studies—this should be considered on an outcome-specific basis
  Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for indirectness:
  ○ No downgrade if none of the factors are considered indirect
  ○ Downgrade one confidence level if one of the factors is considered indirect
  ○ Downgrade two confidence levels if two or more of the factors are considered indirect
- Imprecision. Evaluation of the narrowness of the effect size estimates and whether the studies have adequate statistical power. Data are considered imprecise when the ratio of the upper to lower 95% CIs for most studies is ≥10 for tests of ratio measures (e.g., odds ratios) and ≥100 for absolute measures (e.g., percent control response). Adequate statistical power is determined if the study can detect a potentially biologically meaningful difference between groups (20% change from control response for categorical data or risk ratio of 1.5 for continuous data). Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for imprecision:
  ○ No downgrade if there are no serious imprecisions
  ○ Downgrade one confidence level for serious imprecisions
  ○ Downgrade two confidence levels for very serious imprecisions
- Publication bias. Evaluation of the concern that studies with statistically significant results are more likely to be published than studies without statistically significant results.
  ○ Downgrade one level of confidence for cases where there is serious concern with publication bias

Four properties of the body of evidence were considered to determine whether the confidence rating should be upgraded:

- Large magnitude of effect. Evaluation of whether the magnitude of effect is sufficiently large so that it is unlikely to have occurred as a result of bias from potential confounding factors.
  ○ Upgrade one confidence level if there is evidence of a large magnitude of effect in a few studies, provided that the studies have an overall low risk of bias and there is no serious unexplained inconsistency among the studies of similar dose or exposure levels; confidence can also be upgraded if there is one study examining the outcome, provided that the study has an overall low risk of bias
- Dose response. Evaluation of the dose-response relationships measured within a study and across studies. Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level for evidence of a monotonic dose-response gradient
  ○ Upgrade one confidence level for evidence of a non-monotonic dose-response gradient where there is prior knowledge that supports a non-monotonic dose-response and a non-monotonic dose-response gradient is observed across studies
- Plausible confounding or other residual biases. This factor primarily applies to human studies and is an evaluation of unmeasured determinants of an outcome such as residual bias towards the null (e.g., “healthy worker” effect) or residual bias suggesting a spurious effect (e.g., recall bias). Below is the criterion used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level for evidence that residual confounding or bias would underestimate an apparent association or treatment effect (i.e., bias toward the null) or suggest a spurious effect when results suggest no effect
- Consistency in the body of evidence. Evaluation of consistency across animal models and species, consistency across independent studies of different human populations and exposure scenarios, and consistency across human study types. Below is the criterion used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level if there is a high degree of consistency in the database

Table C-16 Adjustments to the Initial Confidence in the Body of Evidence

| Initial confidence | Adjustments to the initial confidence rating | Final confidence
Respiratory effects:
Human studies | Moderate | −1 risk of bias | Low
Animal studies | High | +1 consistency, +1 magnitude, +1 dose-response | High
Immune effects:
Human studies | Moderate | −1 inconsistency | Low
Animal studies | High | −1 indirectness, −1 inconsistency | Low
Neurological effects:
Human studies | Moderate | None | Moderate
Animal studies | Moderate | +1 consistency, −1 indirectness | Moderate

Table C-17 Confidence in the Body of Evidence for Naphthalene

Outcome | Confidence in body of evidence
Outcome | Human studies | Animal studies
Respiratory | Low | High
Immune | Low | Low
Neurological | Moderate | Moderate

## C.7 TRANSLATE CONFIDENCE RATING INTO LEVEL OF EVIDENCE OF HEALTH EFFECTS—NAPHTHALENE

In the seventh step of the systematic review of the health effects data for naphthalene, the confidence in the body of evidence for specific outcomes was translated to a level of evidence rating. The level of evidence rating reflected the confidence in the body of evidence and the direction of the effect (i.e., toxicity or no toxicity); route-specific differences were noted. The level of evidence for health effects was rated on a five-point scale:

- High level of evidence: High confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Moderate level of evidence: Moderate confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Low level of evidence: Low confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Evidence of no health effect: High confidence in the body of evidence that exposure to the substance is not associated with the health outcome
- Inadequate evidence: Low or moderate confidence in the body of evidence that exposure to the substance is not associated with the health outcome OR very low confidence in the body of evidence for an association between exposure to the substance and the health outcome

A summary of the level of evidence of health effects for naphthalene is presented in Table C-18.

Table C-18 Level of Evidence of Health Effects for Naphthalene

Outcome | Confidence in body of evidence | Direction of health effect | Level of evidence for health effect
Human studies
Respiratory | Low | Health Effect | Low
Neurological | Moderate | No health effect | Inadequate
Immune | Low | Health Effect | Low
Animal studies
Respiratory | High | Health Effect | High
Neurological | Moderate | Health effect | Moderate
Immune | Low | Health Effect | Low

## C.8 INTEGRATE EVIDENCE TO DEVELOP HAZARD IDENTIFICATION CONCLUSIONS—NAPHTHALENE

The final step involved the integration of the evidence streams for the human studies and animal studies to allow for a determination of hazard identification conclusions. For health effects, there were four hazard identification conclusion categories:

- Known to be a hazard to humans
- Presumed to be a hazard to humans
- Suspected to be a hazard to humans
- Not classifiable as to the hazard to humans

The initial hazard identification was based on the highest level of evidence in the human studies and the level of evidence in the animal studies; if there were no data for one evidence stream (human or animal), then the hazard identification was based on the one data stream (equivalent to treating the missing evidence stream as having low level of evidence). The hazard identification scheme is presented in Figure C-1:

- Known: A health effect in this category would have:
  ○ High level of evidence for health effects in human studies AND a high, moderate, or low level of evidence in animal studies.
- Presumed: A health effect in this category would have:
  ○ Moderate level of evidence in human studies AND high or moderate level of evidence in animal studies OR
  ○ Low level of evidence in human studies AND high level of evidence in animal studies
- Suspected: A health effect in this category would have:
  ○ Moderate level of evidence in human studies AND low level of evidence in animal studies OR
  ○ Low level of evidence in human studies AND moderate level of evidence in animal studies
- Not classifiable: A health effect in this category would have:
  ○ Low level of evidence in human studies AND low level of evidence in animal studies

Figure C-1 Hazard Identification Scheme

Other relevant data such as mechanistic or mode-of-action data were considered to raise or lower the level of the hazard identification conclusion by providing information that supported or opposed biological plausibility.

Two hazard identification conclusion categories were used when the data indicated that there may be no health effect in humans:

- Not identified to be a hazard in humans
- Inadequate to determine hazard to humans

If the human level of evidence conclusion of no health effect was supported by the animal evidence of no health effect, then the hazard identification conclusion category of “not identified” was used. If the human or animal level of evidence was considered inadequate, then a hazard identification conclusion category of “inadequate” was used. As with the hazard identification for health effects, the impact of other relevant data was also considered for no health effect data.

The hazard identification conclusions for naphthalene are listed below and summarized in Table C-19.

Presumed Health Effects

- Respiratory
  ○ Low level of evidence in humans based on associations between nasal irritation and inflammation and occupational exposure to naphthalene (Sucker et al. 2021) and associations between decreases in lung function and airborne naphthalene in general population studies (Cakmak et al. 2014; Mu et al. 2019).
  ○ High evidence level in animals including nasal histopathological lesions in rats and mice after inhalation exposure for acute, intermediate, and chronic durations (Abdo et al. 2001; Carratt et al. 2016, 2019a; Cichocki et al. 2014; Dodd et al. 2010, 2012; Lee et al. 2005; Li et al. 2017; NTP 1992a, 2000) and lung pathology in mice after acute- and chronic-duration exposures (Kovalchuk et al. 2020; Li et al. 2017; NTP 1992a; Phimister et al. 2004; West et al. 2001).
  ○ Plausible mechanism based on metabolism to electrophilic intermediates that bind to proteins, deplete reduced glutathione levels, and increase oxidative stress (see Section 2.4).

Suspected Health Effects

- Neurological
  ○ Inadequate evidence in humans based on lack of association between neurocognitive endpoints and occupational exposure to JP-8 (Heaton et al. 2017) and between schizophrenia severity scores and PM_2.5_-bound-naphthalene in ambient air (Liu et al. 2024).
  ○ Moderate level of evidence for effects in animals exposed orally based on clinical signs of neurotoxicity (lethargy) in Sprague-Dawley rats during gestation (NTP 1991) and in F344 rats and B6C3F1 mice exposed for 13 weeks (NTP 1980a, 1980b).

Not Classifiable

- Immune
  ○ Low level of evidence for immune effects in humans based on associations between altered cytokine levels and/or differential leukocyte counts and naphthalene concentrations in air (Lehmann et al. 2001, 2002; Rhodes et al. 2003), between asthma and urinary 2-naphthol levels (Lin et al. 2018), and between serum naphthalene and serum IgE (Aslam et al. 2023).
  ○ Low level of evidence in animals based on decreases in thymus weights in rats exposed by inhalation for 13 weeks (Dodd et al. 2012) and mice exposed orally for 13 weeks (Shopp et al. 1984); a low incidence of lymphoid depletion of the thymus in female rats exposed by gavage for 13 weeks (NTP 1980b); increased serum inflammatory markers in mice given a single oral dose of naphthalene (Zhang et al. 2016); and reduced mitogenic response to concanavalin A in mice exposed orally for 2 weeks (Shopp et al. 1984).

Table C-19 Hazard Identification Conclusions for Naphthalene

Outcome | Hazard identification
Respiratory effects | Presumed health effect
Neurological effects | Suspected health effect
Immune system effects | Not classifiable

## C.9 IDENTIFY POTENTIAL HEALTH EFFECT OUTCOMES OF CONCERN—1-METHYLNAPHTHALENE

Overviews of the potential health effect outcomes for 1-methylnaphthalene identified in animal studies are presented in Table C-20. No human studies of 1-methylnaphthalene were located. There were few animal studies, but they examined a number of endpoints. The animal data show that the respiratory tract and liver are sensitive effects of exposure to 1-methylnaphthalene; studies examining these potential outcomes were carried through to Steps 4–8 of the systematic review. There were three studies examining these potential outcomes carried through to Steps 4–8 of the systematic review.

Table C-20 Overview of the Health Outcomes for 1-Methylnaphthalene Evaluated in Experimental Animal Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological^a^ | Neurological^a^ | Reproductive^a^ | Developmental | Other Noncancer | Cancer
Inhalation studies
Acute-duration | 1 | | | | | | | | | | | | 1
Acute-duration | 0 | | | | | | | | | | | | 1
Intermediate-duration | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | | 1 | 1 | | 1
Intermediate-duration | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | | 0 | 0 | | 0
Chronic-duration
Oral studies
Acute-duration
Intermediate-duration | 1 | 1 | 1 | 1 | 1 | | 1 | 1 | | | 1 | 1 | 1 | 1 | 1
Intermediate-duration | 0 | 0 | 0 | 0 | 0 | | 1 | 1 | | | 0 | 0 | 0 | 0 | 0
Chronic-duration | 1 | 1 | 1 | 1 | 1 | | 1 | 1 | | | 1 | 1 | 1 | 1 | | | 1
Chronic-duration | 0 | 1 | 0 | 0 | 0 | | 0 | 0 | | | 0 | 0 | 0 | 0 | | | 1
Dermal studies
Acute-duration | | | | | | | | | 1
Acute-duration | | | | | | | | | 1
Intermediate-duration | | 1
Intermediate-duration | | 1
Chronic-duration | | 1
Chronic-duration | | 1

Number of studies examining endpoint | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10
Number of studies reporting outcome | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10

a Number of studies examining endpoint includes study evaluating histopathology, but not evaluating function.

## C.10 ASSESS THE RISK OF BIAS FOR INDIVIDUAL STUDIES—1-METHYLNAPHTHALENE

### C.10.1 Risk of Bias Assessment—1-Methylnaphthalene

The risk of bias of individual studies was assessed using OHAT’s Risk of Bias Tool (NTP 2015). The risk of bias questions for observational epidemiology studies, human-controlled exposure studies, and animal experimental studies were presented above in Tables C-5, C-6, and C-7, respectively. As described in Section C.5.1, each risk of bias question was answered on a four-point scale and studies were assigned to one of three risk of bias tiers.

The results of the risk of bias assessment for the different types of 1-methylnaphthalene health effects studies (animal experimental studies) are presented in Table C-21. No human studies of 1-methylnaphthalene were located.

Table C-21 Summary of Risk of Bias Assessment for 1-Methylnaphthalene—Experimental Animal Studies

Reference | Risk of bias criteria and ratings | | | | | | | | | Risk of bias tier
Reference | Selection bias | | Performance bias | | Attrition/exclusion bias | Detection bias | | Selective reporting bias | Other bias | Risk of bias tier
Reference | Was administered dose or exposure level adequately randomized? | Was allocation to study groups adequately concealed? | Were experimental conditions identical across study groups? | Were research personnel blinded to the study group during the study? | Were outcome data complete without attrition or exclusion from analysis? | Is there confidence in the exposure characterization? | Is there confidence in the outcome assessment?^*^ | Were all measured outcomes reported? | Did the study design or analysis account for important confounding and modifying variables? | Risk of bias tier
Outcome: Respiratory effects
Oral intermediate exposure
NITE 2009 (Rat, 42 days) | + | – | ++ | – | ++ | ++ | + | ++ | NA | First
Oral chronic exposure
Murata et al. 1993 (mouse, 81 weeks) | – | – | + | – | + | – – | + | ++ | – – | Second
Inhalation intermediate exposure
Kim et al. 2020 (rat; 13 weeks) | – | – | ++ | – | + | + | ++ | ++ | NA | First
Outcome: Hepatic effects
Oral intermediate exposure
NITE 2009 (Rat, 42 days) | + | – | ++ | – | ++ | ++ | + | ++ | NA | First
Oral chronic exposure
Murata et al. 1993 (mouse, 81 weeks) | – | – | + | – | + | – – | + | ++ | – – | Second
Inhalation intermediate exposure
Kim et al. 2020 (Rat 90 days) | – | – | ++ | – | + | + | + | ++ | NA | First

++ = definitely low risk of bias; + = probably low risk of bias; – = probably high risk of bias; – – = definitely high risk of bias; na = not applicable

* Key question used to assign risk of bias tier

## C.11 RATE THE CONFIDENCE IN THE BODY OF EVIDENCE FOR EACH RELEVANT OUTCOME—1-METHYLNAPHTHALENE

As discussed in greater detail in Section C.6, confidences in the bodies of human and animal evidence were evaluated independently for each potential outcome for each type of study: case-control, case series, cohort, population, human-controlled exposure, and experimental animal. In the absence of data to the contrary, data for a particular outcome were collapsed across animal species, routes of exposure, and exposure durations. If species (or strain), route, or exposure duration differences were noted, then the data were treated as separate outcomes.

### C.11.1 Initial Confidence Rating—1-Methylnaphthalene

As discussed in greater detail in Section C.6.1, the body of evidence for an association (or no association) between exposure to 1-methylnaphthalene and a particular outcome was given an initial confidence rating based on the key features of the individual studies examining that outcome. Refer to Tables C-9, C-10, and C-11, respectively, for the key features for observational epidemiology (cohort, population, and case-control) studies, human controlled exposure studies, and experimental animal studies.

The presence or absence of the key features and the initial confidence levels for studies examining respiratory and hepatic effects observed in the animal experimental studies are presented in Table C-22.

Table C-22 Presence of Key Features of Study Design for 1-Methylnaphthalene—Experimental Animal Studies

Reference | Key feature | | | | Initial study confidence
Reference | Concurrent control group | Sufficient number of animals per group | Appropriate parameters to assess potential effect | Adequate data for statistical analysis | Initial study confidence
Outcome: Respiratory effects
Oral Intermediate exposure
NITE 2009 | Yes | Yes | Yes | Yes | High
Oral chronic exposure
Murata et al. 1993 (mouse; 81 weeks) | Yes | Yes | Yes | Yes | High
Inhalation intermediate exposure
Kim et al. 2020 (rat; 13 weeks) | Yes | Yes | Yes | Yes | High
Outcome: Hepatic effects
Oral intermediate exposure
NITE 2009 | Yes | Yes | Yes | Yes | High
Oral chronic exposure
Murata et al. 1993 | Yes | Yes | Yes | Yes | High
Inhalation intermediate exposure
Kim et al. 2020 (rat; 13 weeks) | Yes | Yes | Yes | Yes | High

A summary of the initial confidence ratings for each outcome is presented in Table C-23. If individual studies for a particular outcome and study type had different study quality ratings, then the highest confidence rating for the group of studies was used to determine the initial confidence rating for the body of evidence; any exceptions were noted in Table C-23.

Table C-23 Initial Confidence Rating for 1-Methylnaphthalene Health Effects Studies

| Initial study confidence | Initial confidence rating
Outcome: Respiratory effects
Animal studies
Oral Intermediate exposure
NITE 2009 (rat; 6 weeks) | High | High
Oral chronic exposure
Murata et al. 1993 (mouse; 81 weeks) | High | High
Inhalation intermediate exposure
Kim et al. 2020 (rat; 13 weeks) | High | High
Outcome: Hepatic effects
Animal studies
Oral intermediate exposure
NITE 2009 (rat; 6 weeks) | High | High
Oral chronic exposure
Murata et al. 1993 (mouse; 81 weeks) | High | High
Inhalation intermediate exposure
Kim et al. 2020 (rat; 13 weeks) | High | High

### C.11.2 Adjustment of the Confidence Rating—1-Methylnaphthalene

The initial confidence rating was then downgraded or upgraded depending on whether there were substantial issues that would decrease or increase confidence in the body of evidence. The five properties of the body of evidence that were considered to determine whether the confidence rating should be downgraded and the four properties of the body of evidence that were considered to determine whether the confidence rating should be upgraded are described above in Section C.6.2. The summaries of the assessment of the confidence in the body of evidence for respiratory and hepatic effects are presented in Table C-24. If the confidence ratings for a particular outcome were based on more than one type of human study, then the highest confidence rating was used for subsequent analyses. An overview of the confidence in the body of evidence for all health effects associated with 1-methylnaphthalene exposure is presented in Table C-25.

Table C-24 Adjustments to the Initial Confidence in the Body of Evidence

| Initial confidence | Adjustments to the initial confidence rating | Final confidence
Respiratory effects
Human studies | Not applicable
Animal studies | High | None | High
Hepatic effects
Human studies | Not applicable
Animal studies | High | −1 Indirectness | Moderate

Table C-25 Confidence in the Body of Evidence for 1-Methylnaphthalene

Outcome | Confidence in body of evidence
Outcome | Human studies | Animal studies
Respiratory | Not applicable | High
Hepatic | Not applicable | Moderate

## C.12 TRANSLATE CONFIDENCE RATING INTO LEVEL OF EVIDENCE OF HEALTH EFFECTS—1-METHYLNAPHTHALENE

As described in Section C.7, the confidence in the body of evidence for specific outcomes was translated to a level of evidence rating. The level of evidence rating reflected the confidence in the body of evidence and the direction of the effect (i.e., toxicity or no toxicity); route-specific differences were noted.

A summary of the level of evidence of health effects for 1-methylnaphthalene is presented in Table C-26.

Table C-26 Level of Evidence of Health Effects for 1-Methylnaphthalene

Outcome | Confidence in body of evidence | Direction of health effect | Level of evidence for health effect
Human studies
Respiratory | NA
Hepatic | NA
Animal studies
Respiratory | High | Health effect | High
Hepatic | Moderate | Health effect | Moderate

## C.13 INTEGRATE EVIDENCE TO DEVELOP HAZARD IDENTIFICATION CONCLUSIONS–1-METHYLNAPHTHALENE

The final step involved the integration of the evidence streams for the human studies and animal studies to allow for a determination of hazard identification conclusions. Refer to Section C.8 for the four hazard identification conclusion categories for health effects, the hazard characterization scheme (see Figure C-1), and the hazard identification conclusion categories.

The hazard identification conclusions for 1-methylnaphthalene are listed below and summarized in Table C-27.

Presumed Health Effects

- Respiratory
  ○ No data in humans.
  ○ High level of evidence in animals based on significantly increased incidences of nasal lesions in rats exposed for 13 weeks by inhalation (Kim et al. 2020) and significantly increased incidences of pulmonary alveolar proteinosis in mice exposed chronically by dietary administration (Murata et al. 1993).
  ○ Supported by finding of pulmonary alveolar proteinosis in mice exposed to the structurally related compound 2-methylnaphthalene in the diet (Murata et al. 1997) and in mice exposed by dermal application to a mixture of methylnaphthalenes (Emi and Konishi 1985; Murata et al. 1992).

Suspected Health Effects

- Hepatic
  ○ No data in humans.
  ○ Moderate level of evidence in animals based on significantly increased liver weights in combined repeat-dose and reproduction/developmental toxicity screening study of rats exposed via gavage (NITE 2009). No liver effects were reported in the chronic dietary study of 1-methylnaphthalene (Murata et al. 1993), but the estimated doses were lower, and there is uncertainty in the dose estimates for Murata et al. (1993) due to potential for volatilization of the test material from the diet.
  ○ Supported by observations of liver effects (liver weight, serum enzyme, and/or histopathology changes) in animals exposed to the structurally related compounds, 2-methylnaphthalene (Świercz et al. 2011) and naphthalene (Chen et al. 2012; Katsnelson et al. 2014; Zhang et al. 2016).

Table C-27 Hazard Identification Conclusions for 1-Methylnaphthalene

Outcome | Hazard identification
Respiratory | Presumed health effect
Hepatic | Suspected health effect

## C.14 IDENTIFY POTENTIAL HEALTH EFFECT OUTCOMES OF CONCERN—2-METHYLNAPHTHALENE

An overview of the potential health effect outcomes for 2-methylnaphthalene identified in animal studies is presented in Table C-28. Human studies of 2-methylnaphthalene were not located. There were few animal studies, but they examined a number of endpoints. The animal data show that the respiratory tract and liver are sensitive effects of exposure to 2-methylnaphthalene; studies examining these potential outcomes were carried through to Steps 4–8 of the systematic review. There were two studies examining these potential outcomes carried through to Steps 4–8 of the systematic review.

Table C-28 Overview of the Health Outcomes for 2-Methylnaphthalene Evaluated in Experimental Animal Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological^a^ | Neurological^a^ | Reproductive^a^ | Developmental | Other Noncancer | Caner
Inhalation studies
Acute-duration | | | | | | | | | | | | | 1
Acute-duration | | | | | | | | | | | | | 1
Intermediate-duration | 1 | 1 | 1 | | 1 | | 1 | 1 | | | | 1
Intermediate-duration | 0 | 1 | 0 | | 0 | | 1 | 0 | | | | 0
Chronic-duration
Oral studies
Acute-duration
Intermediate-duration
Chronic-duration | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | | 1 | 1 | 1 | | | 1
Chronic-duration | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | | 0 | 0 | 0 | | | 1
Dermal studies
Acute-duration | | | | | | | | | 1
Acute-duration | | | | | | | | | 1
Intermediate-duration | | 1
Intermediate-duration | | 1
Chronic-duration | | 1
Chronic-duration | | 1

Number of studies examining endpoint | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10
Number of studies reporting outcome | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10

a Number of studies examining endpoint includes study evaluating histopathology, but not evaluating function.

## C.15 ASSESS THE RISK OF BIAS FOR INDIVIDUAL STUDIES—2-METHYLNAPHTHALENE

### C.15.1 Risk of Bias Assessment—2-Methylnaphthalene

The risk of bias of individual studies was assessed using OHAT’s Risk of Bias Tool (NTP 2015). The risk of bias questions for observational epidemiology studies, human-controlled exposure studies, and animal experimental studies were presented above in Tables C-5, C-6, and C-7, respectively. As described in Section C.5.1, each risk of bias question was answered on a four-point scale and studies were assigned to one of three risk of bias tiers.

The results of the risk of bias assessment for the 2-methylnaphthalene health effects studies (animal experimental studies) are presented in Table C-29.

Table C-29 Summary of Risk of Bias Assessment for 2-Methylnaphthalene—Experimental Animal Studies

Reference | Risk of bias criteria and ratings | | | | | | | | | Risk of bias tier
Reference | Selection bias | | Performance bias | | Attrition/exclusion bias | Detection bias | | Selective reporting bias | Other bias | Risk of bias tier
Reference | Was administered dose or exposure level adequately randomized? | Was allocation to study groups adequately concealed? | Were experimental conditions identical across study groups? | Were research personnel blinded to the study group during the study? | Were outcome data complete without attrition or exclusion from analysis? | Is there confidence in the exposure characterization? | Is there confidence in the outcome assessment?^*^ | Were all measured outcomes reported? | Did the study design or analysis account for important confounding and modifying variables? | Risk of bias tier
Outcome: Respiratory effects
Oral chronic exposure
Murata et al. 1997 (mouse; 81 weeks) | – | – | + | – | + | – – | + | + | – – | Second
Inhalation intermediate exposure
Świercz et al. 2011 | – | – | ++ | – | + | + | + | + | NA | First
Outcome: Hepatic effects
Inhalation intermediate exposure
Świercz et al. 2011 | – | – | ++ | – | + | + | + | + | NA | First

++ = definitely low risk of bias; + = probably low risk of bias; – = probably high risk of bias; – – = definitely high risk of bias; na = not applicable

* Key question used to assign risk of bias tier

## C.16 RATE THE CONFIDENCE IN THE BODY OF EVIDENCE FOR EACH RELEVANT OUTCOME—2-METHYLNAPHTHALENE

As discussed in greater detail in Section C.6, confidences in the bodies of human and animal evidence were evaluated independently for each potential outcome for each type of study: case-control, case series, cohort, population, human-controlled exposure, and experimental animal. In the absence of data to the contrary, data for a particular outcome were collapsed across animal species, routes of exposure, and exposure durations. If species (or strain), route, or exposure duration differences were noted, then the data were treated as separate outcomes.

### C.16.1 Initial Confidence Rating—2-Methylnaphthalene

As discussed in greater detail in Section C.6.1, the body of evidence for an association (or no association) between exposure to 2-methylnaphthalene and a particular outcome was given an initial confidence rating based on the key features of the individual studies examining that outcome. Refer to Tables C-9, C-10, and C-11, respectively, for the key features for observational epidemiology (cohort, population, and case-control) studies, human controlled exposure studies, and experimental animal studies.

The presence or absence of the key features and the initial confidence levels for studies examining respiratory and hepatic system effects in the animal experimental studies are presented in Table C-30.

Table C-30 Presence of Key Features of Study Design for 2-Methylnaphthalene—Experimental Animal Studies

Reference | Key feature | | | | Initial study confidence
Reference | Concurrent control group | Sufficient number of animals per group | Appropriate parameters to assess potential effect | Adequate data for statistical analysis | Initial study confidence
Outcome: Respiratory effects
Oral chronic exposure
Murata et al. 1997 (mouse; 81 weeks) | Yes | Yes | Yes | Yes | High
Inhalation intermediate exposure
Świercz et al. 2011 | Yes | Yes | Yes | Yes | High
Outcome: Hepatic effects
Inhalation intermediate exposure
Świercz et al. 2011 (rat; 28 days) | Yes | Yes | Yes | Yes | High

A summary of the initial confidence ratings for each outcome is presented in Table C-31. If individual studies for a particular outcome and study type had different study quality ratings, then the highest confidence rating for the group of studies was used to determine the initial confidence rating for the body of evidence; any exceptions were noted in Table C-31.

Table C-31 Initial Confidence Rating for 2-Methylnaphthalene Health Effects Studies (Animal Studies)

| Initial study confidence | Initial confidence rating
Outcome: Respiratory effects
Oral chronic exposure
Murata et al. 1997 (mouse; 81 weeks) | High | High
Inhalation intermediate exposure
Świercz et al. 2011 | High | High
Outcome: Hepatic effects
Inhalation intermediate exposure
Świercz et al. 2011 | High | High

### C.16.2 Adjustment of the Confidence Rating—2-Methylnaphthalene

The initial confidence rating was then downgraded or upgraded depending on whether there were substantial issues that would decrease or increase confidence in the body of evidence. The five properties of the body of evidence that were considered to determine whether the confidence rating should be downgraded and the four properties of the body of evidence that were considered to determine whether the confidence rating should be upgraded are described above in Section C.6.2. The summaries of the assessment of the confidence in the body of evidence for respiratory and hepatic effects are presented in Table C-32. If the confidence ratings for a particular outcome were based on more than one type of human study, then the highest confidence rating was used for subsequent analyses. An overview of the confidence in the body of evidence for all health effects associated with 2-methylnaphthalene exposure is presented in Table C-33.

Table C-32 Adjustments to the Initial Confidence in the Body of Evidence

| Initial confidence | Adjustments to the initial confidence rating | Final confidence
Respiratory effects
Human studies | NA
Animal studies | High | None | High
Hepatic effects
Human studies | NA
Animal studies | High | None | High

Table C-33 Confidence in the Body of Evidence for 2-Methylnaphthalene

Outcome | Confidence in body of evidence
Outcome | Human studies | Animal studies
Respiratory | NA | High
Hepatic | NA | High

## C.17 TRANSLATE CONFIDENCE RATING INTO LEVEL OF EVIDENCE OF HEALTH EFFECTS—2-METHYLNAPHTHALENE

As described in Section C.7, the confidence in the body of evidence for specific outcomes was translated to a level of evidence rating. The level of evidence rating reflected the confidence in the body of evidence and the direction of the effect (i.e., toxicity or no toxicity); route-specific differences were noted.

A summary of the level of evidence of health effects for 2-methylnaphthalene is presented in Table C-34.

Table C-34 Level of Evidence of Health Effects for 2-Methylnaphthalene

Outcome | Confidence in body of evidence | Direction of health effect | Level of evidence for health effect
Human studies
Respiratory | NA
Hepatic | NA
Animal studies
Respiratory | High | Health effect | High
Hepatic | High | Health effect | High

## C.18 INTEGRATE EVIDENCE TO DEVELOP HAZARD IDENTIFICATION CONCLUSIONS—2-METHYLNAPHTHALENE

The final step involved the integration of the evidence streams for the human studies and animal studies to allow for a determination of hazard identification conclusions. Refer to Section C.8 for the four hazard identification conclusion categories for health effects, the hazard characterization scheme (see Figure C-1), and the hazard identification conclusion categories.

The hazard identification conclusions for 2-methylnaphthalene are listed below and summarized in Table C-35.

Presumed Health Effects

- Respiratory
  ○ No data in humans.
  ○ High level of evidence in animals based on significantly increased incidences of bronchial lesions in rats exposed for 4 weeks by inhalation (Świercz et al. 2011) and significantly increased incidences of pulmonary alveolar proteinosis in mice exposed chronically by dietary administration (Murata et al. 1997).
  ○ Supported by finding of pulmonary alveolar proteinosis in mice exposed to the structurally related compound 1-methylnaphthalene in the diet (Murata et al. 1993) and in mice exposed by dermal application to a mixture of methylnaphthalenes (Emi and Konishi 1985; Murata et al. 1992).
- Hepatic
  ○ No data in humans.
  ○ High level of evidence in animals based on dose-related increased incidences of bile duct hyperplasia in rats exposed by inhalation for 4 weeks (Świercz et al. 2011).
  ○ Supported by observations of liver effects (liver weight, serum enzyme, and/or histopathology changes) in animals exposed to the structurally related compounds, 1-methylnaphthalene (NITE 2009) and naphthalene (Chen et al. 2012; Katsnelson et al. 2014; Zhang et al. 2016).

Table C-35 Hazard Identification Conclusions for 2-Methylnaphthalene

Outcome | Hazard identification
Respiratory | Presumed health effect
Hepatic | Presumed health effect