# APPENDIX B LITERATURE SEARCH FRAMEWORK FOR NAPHTHALENE, 1-METHYLNAPHTHALENE, AND 2-METHYLNAPHTHALENE

The objective of the toxicological profile is to evaluate the potential for human exposure and the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to naphthalene, 1-methylnaphthalene, and 2-methylnaphthalene.

## B.1 LITERATURE SEARCH AND SCREEN

A literature search and screen were conducted to identify studies examining health effects, toxicokinetics, mechanisms of action, susceptible populations, biomarkers, chemical interactions, physical and chemical properties, production, use, environmental fate, environmental releases, and environmental and biological monitoring data for naphthalene, 1-methylnaphthalene, and 2-methylnaphthalene. ATSDR primarily focused on peer-reviewed articles without language restrictions. Foreign language studies are reviewed based on available English-language abstracts and/or tables (or summaries in regulatory assessments, such as International Agency for Research on Cancer [IARC] documents). If the study appears critical for hazard identification or MRL derivation, translation into English is requested. Non-peer-reviewed studies that were considered relevant to the assessment of the health effects of naphthalene, 1-methylnaphthalene, and 2-methylnaphthalene have undergone peer review by at least three ATSDR-selected experts who have been screened for conflict of interest. The inclusion criteria used to identify relevant studies examining the health effects of naphthalene, 1-methylnaphthalene, and 2-methylnaphthalene are presented in Table B-1.

Table B-1 Inclusion Criteria for the Literature Search and Screen^a^

Health Effects
Species
Human
Laboratory mammals
Route of exposure
Inhalation
Oral
Dermal (or ocular)
Parenteral (these studies will be considered supporting data)
Health outcome
Death
Systemic effects
Body weight effects
Respiratory effects
Cardiovascular effects
Gastrointestinal effects
Hematological effects
Musculoskeletal effects
Hepatic effects
Renal effects
Dermal effects
Ocular effects
Endocrine effects
Immunological effects
Neurological effects
Reproductive effects
Developmental effects
Other noncancer effects
Cancer
Toxicokinetics
Absorption
Distribution
Metabolism
Excretion
PBPK models
Biomarkers
Biomarkers of exposure
Biomarkers of effect
Interactions with other chemicals
Potential for human exposure
Releases to the environment
Air
Water
Soil
Environmental fate
Transport and partitioning
Transformation and degradation
Environmental monitoring
Air
Water
Sediment and soil
Other media
Biomonitoring
General populations
Occupation populations

a Physical-chemical properties are not generally obtained from literature searches, but rather from curated governmental databases such as PubChem.

### B.1.1 Literature Search

The literature search was conducted to update the Toxicological Profile for Naphthalene, 1-Methylnaphthalene, and 2-Methylnaphthalene released in 2005. All literature cited in the previous (2005) toxicological profile were considered for inclusion in the updated profile. The initial literature search, which was performed in April 2022, was restricted to studies added to databases since January 2003. An updated literature search was performed after the Toxicological Profile for Naphthalene, 1-Methylnaphthalene, and 2-Methylnaphthalene Draft for Public Comment was released in May 2024 to identify any additional studies added to databases between January 2022 and June 2024.

The following main databases were searched in April 2022 and May 2024:

- PubMed
- National Technical Reports Library (NTRL)
- Scientific and Technical Information Network’s TOXCENTER

The search strategy used the chemical names, Chemical Abstracts Service (CAS) numbers, synonyms, Medical Subject Headings (MeSH) headings, and keywords for naphthalene, 1-methylnaphthalene, and 2-methylnaphthalene. The query strings used for the literature search are presented in Table B-2.

The search was augmented by searching the Toxic Substances Control Act Test Submissions (TSCATS), NTP website, and National Institute of Health Research Portfolio Online Reporting Tools Expenditures and Results (NIH RePORTER) databases using the queries presented in Table B-3. Additional databases were searched in the creation of various tables and figures, such as the TRI Explorer, the Substance Priority List (SPL) resource page, and other items as needed. Regulations applicable to naphthalene, 1-methylnaphthalene, and 2-methylnaphthalene were identified by searching international and U.S. agency websites and documents.

Review articles were identified and used for the purpose of providing background information and identifying additional references. ATSDR also identified reports from the grey literature, which included unpublished research reports, technical reports from government agencies, conference proceedings and abstracts, and theses and dissertations.

Table B-2 Database Query Strings

Database search date | Query string
PubMed
06/2024 | (((91-20-3[rn] OR 90-12-0[rn] OR 91-57-6[rn] OR 1321-94-4[rn]) AND (2022/04/01:3000[mhda] OR 2022:3000[dp])) OR (((“Albocarbon”[tw] OR “Camphor tar”[tw] OR “Dezodorator”[tw] OR “Mighty 150”[tw] OR “Mighty RD1”[tw] OR “Moth balls”[tw] OR “Moth flakes”[tw] OR “Mothballs”[tw] OR “Naphtalene”[tw] OR “Naphtalinum”[tw] OR “Naphthalene”[tw] OR “Naphthalin”[tw] OR “Naphthaline”[tw] OR “Naphthalinum”[tw] OR “Naphthene”[tw] OR “Napthalene”[tw] OR “Tar camphor”[tw] OR “White tar”[tw] OR “1-METHYL-NAPHTHALENE”[tw] OR “1-Methylnaphtalene”[tw] OR “1-Methylnaphthalene”[tw] OR “1-Methylnaphthalin”[tw] OR “alpha-Methylnaphthalene”[tw] OR “Mechinafu H”[tw] OR “METHYL NAPHTHALENE”[tw] OR “Methylnaphthalene”[tw] OR “Methylnaphthalene, 1-”[tw] OR “Methynaph H”[tw] OR “Naphthalene, 1-methyl-”[tw] OR “Naphthalene, alpha-methyl-”[tw] OR “α-Methylnaphthalene”[tw] OR “2-Methylnaphtalene”[tw] OR “2-Methylnaphthalene”[tw] OR “2-Methylnaphthalin”[tw] OR “2-Methylnapthalene”[tw] OR “beta-Methylnaphthalene”[tw] OR “Methylnaphthalene, 2-”[tw] OR “Naphthalene, 2-methyl-”[tw] OR “Naphthalene, beta-methyl-”[tw] OR “β-Methylnaphthalene”[tw] OR “C1-Naphthalenes”[tw] OR “Dycar MN”[tw] OR “Methylated naphthalenes”[tw] OR “Methylnaphtalene”[tw] OR “Methylnaphthalenes”[tw] OR “Methylnaphthalin”[tw] OR “Methylnapthalene”[tw] OR “Monomethylnaphthalene”[tw] OR “Naphthalene, methyl-”[tw] OR “PETROL CARBON HYDROXIDE”[tw] OR “Sure-Sol 187”[tw] OR “Tetrosin MNLF”[tw]) AND (2022/04/01:3000[mhda] OR 2022:3000[dp])) AND ((“Naphthalenes/toxicity”[mh] OR “Naphthalenes/adverse effects”[mh] OR “Naphthalenes/poisoning”[mh] OR “Naphthalenes/pharmacokinetics”[mh] OR (“Naphthalenes”[mh] AND (“environmental exposure”[mh] OR “chemically induced”[sh])) OR (“Naphthalenes”[mh] AND toxicokinetics[mh:noexp])) OR (“Naphthalenes”[mh] AND (indexingmethod_automated OR indexingmethod_curated) AND (“RNA”[mh] OR “DNA”[mh] OR “DNA Replication”[mh] OR “Salmonella typhimurium”[mh] OR ((antagonist*[tw] OR inhibitor*[tw]) AND (“humans”[mh] OR “animals”[mh])) OR “blood”[tw] OR “serum”[tw] OR (“plasma”[tw] NOT spectromet*[tw]) OR pharmacokinetic*[tw] OR toxicokinetic*[tw] OR “pbpk”[tw] OR “poisoned”[tw] OR “poisoning”[tw] OR “urine”[tw] OR “urinary”[tw] OR “toxicity”[sh] OR “occupational diseases”[mh] OR “hazardous substances”[mh] OR “epidemiology”[sh] OR “epidemiologic studies”[mh])) OR (“Naphthalenes/blood”[mh] OR “Naphthalenes/cerebrospinal fluid”[mh] OR “Naphthalenes/urine”[mh]) OR (“Naphthalenes”[mh] AND (“endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh])) OR (“Naphthalenes”[mh] AND (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic “[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“Naphthalenes/antagonists and inhibitors”[mh]) OR (“Naphthalenes/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“Naphthalenes/pharmacology”[majr]) OR (“Naphthalenes”[mh] AND ((“Neoplasms”[mh] OR “Carcinogens”[mh] OR “Lymphoproliferative disorders”[mh] OR “Myeloproliferative disorders”[mh] OR “Toxicity Tests”[mh] OR ((cancer*[tiab] OR carcinogen*[tiab]) AND (risk*[tiab] OR health[tiab]) AND assessment*[tiab]) OR “Mutagens”[mh] OR “Mutagenicity Tests”[mh] OR “Chromosome Aberrations”[mh] OR “DNA Damage”[mh] OR “DNA Repair”[mh] OR “DNA Replication/drug effects”[mh] OR “DNA/drug effects”[mh] OR “DNA/metabolism”[mh] OR “Genomic Instability”[mh] OR “Salmonella typhimurium/drug effects”[mh] OR “Salmonella typhimurium/genetics”[mh] OR “Sister Chromatid Exchange”[mh] OR strand-break*[tiab]))) OR (“Polycyclic Aromatic Hydrocarbons/toxicity”[mh] OR “Polycyclic Aromatic Hydrocarbons/adverse effects”[mh] OR “Polycyclic Aromatic Hydrocarbons/poisoning”[mh] OR “Polycyclic Aromatic Hydrocarbons/pharmacokinetics”[mh] OR (“Polycyclic Aromatic Hydrocarbons”[mh] AND (“environmental exposure”[mh] OR “chemically induced”[sh])) OR (“Polycyclic Aromatic Hydrocarbons”[mh] AND toxicokinetics[mh:noexp])) OR (“Polycyclic Aromatic Hydrocarbons”[mh] AND (indexingmethod_automated OR indexingmethod_curated) AND (“RNA”[mh] OR “DNA”[mh] OR “DNA Replication”[mh] OR “Salmonella typhimurium”[mh] OR ((antagonist*[tw] OR inhibitor*[tw]) AND (“humans”[mh] OR “animals”[mh])) OR “blood”[tw] OR “serum”[tw] OR (“plasma”[tw] NOT spectromet*[tw]) OR pharmacokinetic*[tw] OR toxicokinetic*[tw] OR “pbpk”[tw] OR “poisoned”[tw] OR “poisoning”[tw] OR “urine”[tw] OR “urinary”[tw] OR “toxicity”[sh] OR “occupational diseases”[mh] OR “hazardous substances”[mh] OR “epidemiology”[sh] OR “epidemiologic studies”[mh])) OR (“Polycyclic Aromatic Hydrocarbons/blood”[mh] OR “Polycyclic Aromatic Hydrocarbons/cerebrospinal fluid”[mh] OR “Polycyclic Aromatic Hydrocarbons/urine”[mh]) OR (“Polycyclic Aromatic Hydrocarbons”[mh] AND (“endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh])) OR (“Polycyclic Aromatic Hydrocarbons”[mh] AND (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic “[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“Polycyclic Aromatic Hydrocarbons/antagonists and inhibitors”[mh]) OR (“Polycyclic Aromatic Hydrocarbons/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“Polycyclic Aromatic Hydrocarbons/pharmacology”[majr]) OR (“Polycyclic Aromatic Hydrocarbons”[mh] AND ((“Neoplasms”[mh] OR “Carcinogens”[mh] OR “Lymphoproliferative disorders”[mh] OR “Myeloproliferative disorders”[mh] OR “Toxicity Tests”[mh] OR ((cancer*[tiab] OR carcinogen*[tiab]) AND (risk*[tiab] OR health[tiab]) AND assessment*[tiab]) OR “Mutagens”[mh] OR “Mutagenicity Tests”[mh] OR “Chromosome Aberrations”[mh] OR “DNA Damage”[mh] OR “DNA Repair”[mh] OR “DNA Replication/drug effects”[mh] OR “DNA/drug effects”[mh] OR “DNA/metabolism”[mh] OR “Genomic Instability”[mh] OR “Salmonella typhimurium/drug effects”[mh] OR “Salmonella typhimurium/genetics”[mh] OR “Sister Chromatid Exchange”[mh] OR strand-break*[tiab]))))) OR ((((“Albocarbon”[tw] OR “Camphor tar”[tw] OR “Dezodorator”[tw] OR “Mighty 150”[tw] OR “Mighty RD1”[tw] OR “Moth balls”[tw] OR “Moth flakes”[tw] OR “Mothballs”[tw] OR “Naphtalene”[tw] OR “Naphtalinum”[tw] OR “Naphthalene”[tw] OR “Naphthalin”[tw] OR “Naphthaline”[tw] OR “Naphthalinum”[tw] OR “Naphthene”[tw] OR “Napthalene”[tw] OR “Tar camphor”[tw] OR “White tar”[tw] OR “1-METHYL-NAPHTHALENE”[tw] OR “1-Methylnaphtalene”[tw] OR “1-Methylnaphthalene”[tw] OR “1-Methylnaphthalin”[tw] OR “alpha-Methylnaphthalene”[tw] OR “Mechinafu H”[tw] OR “METHYL NAPHTHALENE”[tw] OR “Methylnaphthalene”[tw] OR “Methylnaphthalene, 1-”[tw] OR “Methynaph H”[tw] OR “Naphthalene, 1-methyl-”[tw] OR “Naphthalene, alpha-methyl-”[tw] OR “α-Methylnaphthalene”[tw] OR “2-Methylnaphtalene”[tw] OR “2-Methylnaphthalene”[tw] OR “2-Methylnaphthalin”[tw] OR “2-Methylnapthalene”[tw] OR “beta-Methylnaphthalene”[tw] OR “Methylnaphthalene, 2-”[tw] OR “Naphthalene, 2-methyl-”[tw] OR “Naphthalene, beta-methyl-”[tw] OR “β-Methylnaphthalene”[tw] OR “C1-Naphthalenes”[tw] OR “Dycar MN”[tw] OR “Methylated naphthalenes”[tw] OR “Methylnaphtalene”[tw] OR “Methylnaphthalenes”[tw] OR “Methylnaphthalin”[tw] OR “Methylnapthalene”[tw] OR “Monomethylnaphthalene”[tw] OR “Naphthalene, methyl-”[tw] OR “PETROL CARBON HYDROXIDE”[tw] OR “Sure-Sol 187”[tw] OR “Tetrosin MNLF”[tw]) NOT medline[sb]) AND (2022/04/01:3000[edat] OR 2022/04/01:3000[crdt] OR 2022:3000[dp])) AND (toxicity[ti] OR death OR lethal OR fatal OR fatality OR necrosis OR LC50* OR “LC 50” OR LD50* OR “LD 50” OR “body weight” OR “body mass index” OR “weight loss” OR “weight gain” OR weight-change* OR overweight OR obesity OR inhala* OR “inhale” OR “inhaled” OR “inhalent” OR “inhales” OR “inhaling” OR respiratory OR “pulmonary” OR airway OR trachea OR tracheobronchial OR lung OR lungs OR nose OR nasal OR nasopharyngeal OR larynx OR laryngeal OR pharynx OR bronchial OR bronchi OR bronchioles OR bronchitis OR hemothorax OR alveolar OR alveoli OR irritation OR irritant OR sensitization OR sensitizer OR “asthma” OR cilia OR mucocilliary OR cardio OR vascular OR cardiovascular OR “circulatory system” OR “circulatory function” OR “circulatory effect” OR “circulatory effects” OR “circulatory toxicity” OR “cardiac” OR “coronary” OR “heart rate” OR “heart failure” OR “heart attack” OR “heart muscle” OR “heartbeat” OR “myocardial-infarction” OR “chest pain” OR artery OR arteries OR veins OR venules OR cardiotox* OR “gastro-intestinal” OR gastrointestinal OR “digestive system” OR “digestive organs” OR “digestive function” OR “digestive effect” OR “digestive effects” OR “intestinal” OR intestine* OR “gi tract” OR “gi disorder” OR abdominal OR esophagus OR esophageal OR stomach OR pancreas OR pancreatic OR diarrhea OR nausea OR vomit OR ulcer* OR constipation OR emesis OR “gut microbes” OR “gut flora” OR “gut microflora” OR anorexia OR hematological OR hematology OR hemato OR haemato OR blood OR anemia OR anaemia OR cyanosis OR “cyanotic” OR erythrocytopenia OR leukopenia OR thrombocytopenia OR hemoglobin OR erythrocyte OR hematocrit OR “bone marrow” OR reticulocyte OR methemoglobin OR red-blood-cell OR musculoskeletal OR skeletal OR muscle OR muscular OR arthritis OR “altered bone” OR “joint pain” OR “limb pain” OR hepatic OR “liver” OR hepatocytes OR gallbladder OR cirrhosis OR jaundice OR “hepatocellular degeneration” OR “hepatocellular hypertrophy” OR hepatomegaly OR hepatotox* OR renal OR “kidney” OR “kidneys” OR “urinary” OR “bladder” OR “urine” OR “blood urea nitrogen” OR bun OR nephropath* OR nephrotox* OR dermal OR “cutaneous application” OR “skin contact” OR “skin rash” OR “skin irritation” OR “skin redness” OR “skin effect” OR “skin effects” OR “skin exposure” OR “skin contact” OR acanthosis OR dermatitis OR psoriasis OR edema OR acne OR eczema OR ocular OR “retinal” OR “eye function” OR “eye effects” OR “eye effect” OR “eye irritation” OR “blurred vision” OR blindness OR myopia OR cataracts OR “auditory system” OR “hearing loss” OR ototoxic* OR endocrine OR “hormone changes” OR “hormone excess” OR “hormone deficiency” OR “hormone secretion” OR “hormone toxicity” OR “hormone levels” OR “sella turcica” OR thyroid OR thyroxine OR adrenal OR pituitary OR immunological OR immunologic OR immune OR immunotox* OR lymphoreticular OR lymph-node OR spleen OR thymus OR macrophage OR leukocyte* OR lymphocyt* OR white-blood-cell OR immunotox* OR neurological OR neurologic OR neurotoxic OR neurotoxicity OR “neuropathy” OR neurodegenerat* OR “neurodevelopment” OR “nervous system” OR “nerve” OR brain OR “cerebrovascular” OR neurotoxicant OR neurochemistry OR neurophysiology OR neuropathology OR “motor activity” OR motor change* OR tremor OR behavior-change* OR behavioral-change* OR sensory-change* OR cognitive OR “cognition” OR vertigo OR drowsiness OR headache OR ataxia OR reproductive OR “reproduction system” OR “reproduction function” OR “reproduction effect” OR “reproduction toxicity” OR “infertility” OR “maternal toxicity” OR developmental OR “in utero” OR placenta OR pregnan* OR terata* OR terato* OR embryo* OR fetus* OR foetus* OR fetal* OR foetal* OR prenatal* OR “pre-natal” OR perinatal* OR “post-natal” OR postnatal* OR neonat* OR newborn* OR zygote* OR child OR children OR infant* OR offspring OR weanling* OR elderly OR oocyte OR ovary OR ovarian OR uterus OR uterine OR testes OR testicular OR sperm OR estrogen* OR androgen* OR “human milk” OR “breast milk” OR “altered food consumption” OR “altered water consumption” OR “metabolic effect” OR “metabolic toxicity” OR fever OR cytotox* OR cancer OR cancerous OR neoplas* OR tumor OR tumors OR tumour* OR malignan* OR carcinoma OR carcinogen OR carcinogen* OR angiosarcoma OR blastoma OR fibrosarcoma OR glioma OR leukemia OR leukaemia OR lymphoma OR melanoma OR meningioma OR mesothelioma OR myeloma OR neuroblastoma OR osteosarcoma OR sarcoma OR mutation OR mutations OR genotoxicity OR genotoxic OR “micronuclei” OR “micronucleus” OR “chromosomal aberrations” OR “chromosome aberrations” OR mutagenicity OR mutagenic OR “mechanism of action”[tiab:~0] OR “mode of action”[tiab:~0] OR “mechanism of toxicity”[tiab:~0] OR “adverse effect” OR “adverse effects” OR “health effects” OR noncancer OR poisoning OR morbidity OR inflammation OR “inflammatory response” OR histopathology OR antagonist OR inhibitor OR metabolism OR “environmental exposure” OR toxicokinetics OR pharmacokinetics OR “pbpk” OR “gene expression” OR “adverse outcome pathway” OR metabolom* OR proteom* OR genomic* OR transcriptom* OR epigenom* OR epigene* OR “transcription factor” OR “transcriptional activation” OR epidemiology OR epidemiological OR case-control* OR case-referent OR case-report OR case-series OR cohort* OR correlation-stud* OR cross-sectional-stud* OR ecological-studies OR ecological-study OR follow-up-stud* OR longitudinal-stud* OR metaanalyses OR metaanalysis OR meta-analysis OR prospective-stud* OR record-link* OR retrospective-stud* OR seroepidemiologic-stud* OR “population health” OR occupation* OR worker* OR workmen* OR workplace* OR “volunteers” OR “human health” OR “dietary” OR “oral intake” OR “oral exposure” OR “oral administration” OR ingest* OR gavage* OR “drinking-water” OR biomarker* OR biomonitor* OR “biological monitoring” OR “environmental fate” OR NHANES OR “Nutrition Examination Survey” OR (cvd NOT “chemical vapor deposition”) OR (human AND (risk OR toxic* OR safety)) OR “in vitro” OR “cell line” OR “cell lines” OR “cultured” OR “3T3” OR “A549” OR “BEAS-2B” OR “CACO-2” OR “CHO cells” OR “HELA” OR “HepG2” OR “HepaRG” OR “Jurkat” OR “MCF-7” OR mammal* OR ape OR apes OR baboon* OR balb OR beagle* OR boar OR boars OR bonobo* OR bovine OR C57 OR C57bl OR callithrix OR canine OR canis OR capra OR capuchin* OR cats OR cattle OR cavia OR chicken OR chickens OR chimpanzee* OR chinchilla* OR cow OR cows OR cricetinae OR dog OR dogs OR equus OR feline OR felis OR ferret OR ferrets OR flying-fox OR fruit-bat OR gerbil* OR gibbon* OR goat OR goats OR guinea-pig* OR guppy OR hamster OR hamsters OR horse OR horses OR jird OR jirds OR lagomorph* OR leontopithecus OR longevans OR macaque* OR marmoset* OR medaka OR merione OR meriones OR mice OR monkey OR monkeys OR mouse OR muridae OR murinae OR murine OR mustela-putorius OR nomascus OR non-human-primate* OR orangutan* OR pan-paniscus OR pan-troglodytes OR pig OR piglet* OR pigs OR polecat* OR pongopygmaeus OR quail OR rabbit OR rabbits OR rat OR rats OR rhesus OR rodent OR rodentia OR rodents OR saguinus OR sheep OR sheeps OR siamang* OR sow OR sows OR Sprague-Dawley OR swine OR swines OR symphalangus OR tamarin* OR vervet* OR wistar OR wood-mouse OR zebra-fish OR zebrafish)))
04/2022 | ((((91-20-3[rn] OR 90-12-0[rn] OR 91-57-6[rn]) OR (“1-METHYL-NAPHTHALENE”[tw] OR “1-Methylnaphtalene”[tw] OR “1-Methylnaphthalene”[tw] OR “1-Methylnaphthalin”[tw] OR “alpha-Methylnaphthalene”[tw] OR “Mechinafu H”[tw] OR “METHYL NAPHTHALENE”[tw] OR “Methylnaphthalene”[tw] OR “Methylnaphthalene, 1-”[tw] OR “Methynaph H”[tw] OR “Naphthalene, 1-methyl-”[tw] OR “Naphthalene, alpha-methyl-”[tw] OR “α-Methylnaphthalene”[tw] OR “2-Methylnaphtalene”[tw] OR “2-Methylnaphthalene”[tw] OR “2-Methylnaphthalin”[tw] OR “2-Methylnapthalene”[tw] OR “beta-Methylnaphthalene”[tw] OR “Methylnaphthalene, 2-”[tw] OR “Naphthalene, 2-methyl-”[tw] OR “Naphthalene, beta-methyl-”[tw] OR “β-Methylnaphthalene”[tw])) OR (((“Albocarbon”[tiab] OR “Camphor tar”[tiab] OR “Dezodorator”[tiab] OR “Mighty 150”[tiab] OR “Mighty RD1”[tiab] OR “Moth balls”[tiab] OR “Moth flakes”[tiab] OR “Mothballs”[tiab] OR “Naphtalene”[tiab] OR “Naphtalinum”[tiab] OR “Naphthalene”[tiab] OR “Naphthalin”[tiab] OR “Naphthaline”[tiab] OR “Naphthalinum”[tiab] OR “Naphthene”[tiab] OR “Napthalene”[tiab] OR “Tar camphor”[tiab] OR “White tar”[tiab])) AND (((“Naphthalenes/toxicity”[mh] OR “Naphthalenes/adverse effects”[mh] OR “Naphthalenes/poisoning”[mh] OR “Naphthalenes/pharmacokinetics”[mh]) OR (“Naphthalenes”[mh] AND (“environmental exposure”[mh] OR ci[sh])) OR (“Naphthalenes”[mh] AND toxicokinetics[mh:noexp]) OR (“Naphthalenes/blood”[mh] OR “Naphthalenes/cerebrospinal fluid”[mh] OR “Naphthalenes/urine”[mh]) OR (“Naphthalenes”[mh] AND (“endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh])) OR (“Naphthalenes”[mh] AND (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic “[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“Naphthalenes/antagonists and inhibitors”[mh]) OR (“Naphthalenes/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“Naphthalenes/pharmacology”[majr])) OR ((“Polycyclic Aromatic Hydrocarbons/toxicity”[mh] OR “Polycyclic Aromatic Hydrocarbons/adverse effects”[mh] OR “Polycyclic Aromatic Hydrocarbons/poisoning”[mh] OR “Polycyclic Aromatic Hydrocarbons/pharmacokinetics”[mh]) OR (“Polycyclic Aromatic Hydrocarbons”[mh] AND (“environmental exposure”[mh] OR ci[sh])) OR (“Polycyclic Aromatic Hydrocarbons”[mh] AND toxicokinetics[mh:noexp]) OR (“Polycyclic Aromatic Hydrocarbons/blood”[mh] OR “Polycyclic Aromatic Hydrocarbons/cerebrospinal fluid”[mh] OR “Polycyclic Aromatic Hydrocarbons/urine”[mh]) OR (“Polycyclic Aromatic Hydrocarbons”[mh] AND (“endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh])) OR (“Polycyclic Aromatic Hydrocarbons”[mh] AND (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic “[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“Polycyclic Aromatic Hydrocarbons/antagonists and inhibitors”[mh]) OR (“Polycyclic Aromatic Hydrocarbons/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“Polycyclic Aromatic Hydrocarbons/pharmacology”[majr]))))) AND 2003:3000[dp]); (((“Albocarbon”[tw] OR “Camphor tar”[tw] OR “Dezodorator”[tw] OR “Mighty 150”[tw] OR “Mighty RD1”[tw] OR “Moth balls”[tw] OR “Moth flakes”[tw] OR “Mothballs”[tw] OR “Naphtalene”[tw] OR “Naphtalinum”[tw] OR “Naphthalene”[tw] OR “Naphthalin”[tw] OR “Naphthaline”[tw] OR “Naphthalinum”[tw] OR “Naphthene”[tw] OR “Napthalene”[tw] OR “Tar camphor”[tw] OR “White tar”[tw] OR “1-METHYL-NAPHTHALENE”[tw] OR “1-Methylnaphtalene”[tw] OR “1-Methylnaphthalene”[tw] OR “1-Methylnaphthalin”[tw] OR “alpha-Methylnaphthalene”[tw] OR “Mechinafu H”[tw] OR “METHYL NAPHTHALENE”[tw] OR “Methylnaphthalene”[tw] OR “Methylnaphthalene, 1-”[tw] OR “Methynaph H”[tw] OR “Naphthalene, 1-methyl-”[tw] OR “Naphthalene, alpha-methyl-”[tw] OR “α-Methylnaphthalene”[tw] OR “2-Methylnaphtalene”[tw] OR “2-Methylnaphthalene”[tw] OR “2-Methylnaphthalin”[tw] OR “2-Methylnapthalene”[tw] OR “beta-Methylnaphthalene”[tw] OR “Methylnaphthalene, 2-”[tw] OR “Naphthalene, 2-methyl-”[tw] OR “Naphthalene, beta-methyl-”[tw] OR “β-Methylnaphthalene”[tw]) NOT medline[sb]) AND 2003:3000[dp]) NOT ((((91-20-3[rn] OR 90-12-0[rn] OR 91-57-6[rn]) OR (“1-METHYL-NAPHTHALENE”[tw] OR “1-Methylnaphtalene”[tw] OR “1-Methylnaphthalene”[tw] OR “1-Methylnaphthalin”[tw] OR “alpha-Methylnaphthalene”[tw] OR “Mechinafu H”[tw] OR “METHYL NAPHTHALENE”[tw] OR “Methylnaphthalene”[tw] OR “Methylnaphthalene, 1-”[tw] OR “Methynaph H”[tw] OR “Naphthalene, 1-methyl-”[tw] OR “Naphthalene, alpha-methyl-”[tw] OR “α-Methylnaphthalene”[tw] OR “2-Methylnaphtalene”[tw] OR “2-Methylnaphthalene”[tw] OR “2-Methylnaphthalin”[tw] OR “2-Methylnapthalene”[tw] OR “beta-Methylnaphthalene”[tw] OR “Methylnaphthalene, 2-”[tw] OR “Naphthalene, 2-methyl-”[tw] OR “Naphthalene, beta-methyl-”[tw] OR “β-Methylnaphthalene”[tw])) OR (((“Albocarbon”[tiab] OR “Camphor tar”[tiab] OR “Dezodorator”[tiab] OR “Mighty 150”[tiab] OR “Mighty RD1”[tiab] OR “Moth balls”[tiab] OR “Moth flakes”[tiab] OR “Mothballs”[tiab] OR “Naphtalene”[tiab] OR “Naphtalinum”[tiab] OR “Naphthalene”[tiab] OR “Naphthalin”[tiab] OR “Naphthaline”[tiab] OR “Naphthalinum”[tiab] OR “Naphthene”[tiab] OR “Napthalene”[tiab] OR “Tar camphor”[tiab] OR “White tar”[tiab])) AND (((“Naphthalenes/toxicity”[mh] OR “Naphthalenes/adverse effects”[mh] OR “Naphthalenes/poisoning”[mh] OR “Naphthalenes/pharmacokinetics”[mh]) OR (“Naphthalenes”[mh] AND (“environmental exposure”[mh] OR ci[sh])) OR (“Naphthalenes”[mh] AND toxicokinetics[mh:noexp]) OR (“Naphthalenes/blood”[mh] OR “Naphthalenes/cerebrospinal fluid”[mh] OR “Naphthalenes/urine”[mh]) OR (“Naphthalenes”[mh] AND (“endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh])) OR (“Naphthalenes”[mh] AND (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic “[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“Naphthalenes/antagonists and inhibitors”[mh]) OR (“Naphthalenes/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“Naphthalenes/pharmacology”[majr])) OR ((“Polycyclic Aromatic Hydrocarbons/toxicity”[mh] OR “Polycyclic Aromatic Hydrocarbons/adverse effects”[mh] OR “Polycyclic Aromatic Hydrocarbons/poisoning”[mh] OR “Polycyclic Aromatic Hydrocarbons/pharmacokinetics”[mh]) OR (“Polycyclic Aromatic Hydrocarbons”[mh] AND (“environmental exposure”[mh] OR ci[sh])) OR (“Polycyclic Aromatic Hydrocarbons”[mh] AND toxicokinetics[mh:noexp]) OR (“Polycyclic Aromatic Hydrocarbons/blood”[mh] OR “Polycyclic Aromatic Hydrocarbons/cerebrospinal fluid”[mh] OR “Polycyclic Aromatic Hydrocarbons/urine”[mh]) OR (“Polycyclic Aromatic Hydrocarbons”[mh] AND (“endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh])) OR (“Polycyclic Aromatic Hydrocarbons”[mh] AND (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic “[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“Polycyclic Aromatic Hydrocarbons/antagonists and inhibitors”[mh]) OR (“Polycyclic Aromatic Hydrocarbons/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“Polycyclic Aromatic Hydrocarbons/pharmacology”[majr]))))) AND 2003:3000[dp]); ((((1321-94-4[rn] OR “C1-Naphthalenes”[tiab] OR “Dycar MN”[tiab] OR “Methylated naphthalenes”[tiab] OR “Methylnaphtalene”[tiab] OR “Methylnaphthalenes”[tiab] OR “Methylnaphthalin”[tiab] OR “Methylnapthalene”[tiab] OR “Monomethylnaphthalene”[tiab] OR “Naphthalene, methyl-”[tiab] OR “PETROL CARBON HYDROXIDE”[tiab] OR “Sure-Sol 187”[tiab] OR “Tetrosin MNLF”[tiab]) AND (((“Naphthalenes/toxicity”[mh] OR “Naphthalenes/adverse effects”[mh] OR “Naphthalenes/poisoning”[mh] OR “Naphthalenes/pharmacokinetics”[mh]) OR (“Naphthalenes”[mh] AND (“environmental exposure”[mh] OR ci[sh])) OR (“Naphthalenes”[mh] AND toxicokinetics[mh:noexp]) OR (“Naphthalenes/blood”[mh] OR “Naphthalenes/cerebrospinal fluid”[mh] OR “Naphthalenes/urine”[mh]) OR (“Naphthalenes”[mh] AND (“endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh])) OR (“Naphthalenes”[mh] AND (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic “[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“Naphthalenes/antagonists and inhibitors”[mh]) OR (“Naphthalenes/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“Naphthalenes/pharmacology”[majr])) OR ((“Polycyclic Aromatic Hydrocarbons/toxicity”[mh] OR “Polycyclic Aromatic Hydrocarbons/adverse effects”[mh] OR “Polycyclic Aromatic Hydrocarbons/poisoning”[mh] OR “Polycyclic Aromatic Hydrocarbons/pharmacokinetics”[mh]) OR (“Polycyclic Aromatic Hydrocarbons”[mh] AND (“environmental exposure”[mh] OR ci[sh])) OR (“Polycyclic Aromatic Hydrocarbons”[mh] AND toxicokinetics[mh:noexp]) OR (“Polycyclic Aromatic Hydrocarbons/blood”[mh] OR “Polycyclic Aromatic Hydrocarbons/cerebrospinal fluid”[mh] OR “Polycyclic Aromatic Hydrocarbons/urine”[mh]) OR (“Polycyclic Aromatic Hydrocarbons”[mh] AND (“endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh])) OR (“Polycyclic Aromatic Hydrocarbons”[mh] AND (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic “[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“Polycyclic Aromatic Hydrocarbons/antagonists and inhibitors”[mh]) OR (“Polycyclic Aromatic Hydrocarbons/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“Polycyclic Aromatic Hydrocarbons/pharmacology”[majr])))) OR ((“C1-Naphthalenes”[tw] OR “Dycar MN”[tw] OR “Methylated naphthalenes”[tw] OR “Methylnaphtalene”[tw] OR “Methylnaphthalenes”[tw] OR “Methylnaphthalin”[tw] OR “Methylnapthalene”[tw] OR “Monomethylnaphthalene”[tw] OR “Naphthalene, methyl-”[tw] OR “PETROL CARBON HYDROXIDE”[tw] OR “Sure-Sol 187”[tw] OR “Tetrosin MNLF”[tw]) NOT medline[sb])) AND (2003:3000[dp]))
NTRL
06/2024 | Limited to 2021 to present “Albocarbon” OR “Camphor tar” OR “Dezodorator” OR “Mighty 150” OR “Mighty RD1” OR “Moth balls” OR “Moth flakes” OR “Mothballs” OR “Naphtalene” OR “Naphtalinum” OR “Naphthalene” OR “Naphthalin” OR “Naphthaline” OR “Naphthalinum” OR “Naphthene” OR “Napthalene” OR “Tar camphor” OR “White tar” OR “1-METHYL-NAPHTHALENE” OR “1-Methylnaphtalene” OR “1-Methylnaphthalene” OR “1-Methylnaphthalin” OR “alpha-Methylnaphthalene” OR “Mechinafu H” OR “METHYL NAPHTHALENE” OR “Methylnaphthalene” OR “Methylnaphthalene, 1-” OR “Methynaph H” OR “Naphthalene, 1-methyl-” OR “Naphthalene, alpha-methyl-” OR “α-Methylnaphthalene” OR “2-Methylnaphtalene” OR “2-Methylnaphthalene” OR “2-Methylnaphthalin” OR “2-Methylnapthalene” OR “beta-Methylnaphthalene” OR “Methylnaphthalene, 2-” OR “Naphthalene, 2-methyl-” OR “Naphthalene, beta-methyl-” OR “β-Methylnaphthalene” OR “C1-Naphthalenes” OR “Dycar MN” OR “Methylated naphthalenes” OR “Methylnaphtalene” OR “Methylnaphthalenes” OR “Methylnaphthalin” OR “Methylnapthalene” OR “Monomethylnaphthalene” OR “Naphthalene, methyl-” OR “PETROL CARBON HYDROXIDE” OR “Sure-Sol 187” OR “Tetrosin MNLF”
04/2022 | “Albocarbon” OR “Camphor tar” OR “Dezodorator” OR “Mighty 150” OR “Mighty RD1” OR “Moth balls” OR “Moth flakes” OR “Mothballs” OR “Naphtalene” OR “Naphtalinum” OR “Naphthalene” OR “Naphthalin” OR “Naphthaline” OR “Naphthalinum” OR “Naphthene” OR “Napthalene” OR “Tar camphor” OR “White tar” OR “1-METHYL-NAPHTHALENE” OR “1-Methylnaphtalene” OR “1-Methylnaphthalene” OR “1-Methylnaphthalin” OR “alpha-Methylnaphthalene” OR “Mechinafu H” OR “METHYL NAPHTHALENE” OR “Methylnaphthalene” OR “Methylnaphthalene, 1-” OR “Methynaph H” OR “Naphthalene, 1-methyl-” OR “Naphthalene, alpha-methyl-” OR “α-Methylnaphthalene” OR “2-Methylnaphtalene” OR “2-Methylnaphthalene” OR “2-Methylnaphthalin” OR “2Methylnapthalene” OR “beta-Methylnaphthalene” OR “Methylnaphthalene, 2-” OR “Naphthalene, 2-methyl-” OR “Naphthalene, beta-methyl-” OR “β-Methylnaphthalene”; “C1-Naphthalenes” OR “Dycar MN” OR “Methylated naphthalenes” OR “Methylnaphtalene” OR “Methylnaphthalenes” OR “Methylnaphthalin” OR “Methylnapthalene” OR “Monomethylnaphthalene” OR “Naphthalene, methyl-” OR “PETROL CARBON HYDROXIDE” OR “Sure-Sol 187” OR “Tetrosin MNLF”; “Albocarbon” OR “Camphor tar” OR “Dezodorator” OR “Mighty 150” OR “Mighty RD1” OR “Moth balls” OR “Moth flakes” OR “Mothballs” OR “Naphtalene” OR “Naphtalinum” OR “Naphthalene” OR “Naphthalin” OR “Naphthaline” OR “Naphthalinum” OR “Naphthene” OR “Napthalene” OR “Tar camphor” OR “White tar” OR “1-METHYL-NAPHTHALENE” OR “1-Methylnaphtalene” OR “1-Methylnaphthalene” OR “1-Methylnaphthalin” OR “alpha-Methylnaphthalene” OR “Mechinafu H” OR “METHYL NAPHTHALENE” OR “Methylnaphthalene” OR “Methylnaphthalene, 1-” OR “Methynaph H” OR “Naphthalene, 1-methyl-” OR “Naphthalene, alpha-methyl-” OR “α-Methylnaphthalene” OR “2-Methylnaphtalene” OR “2-Methylnaphthalene” OR “2-Methylnaphthalin” OR “2-Methylnapthalene” OR “beta-Methylnaphthalene” OR “Methylnaphthalene, 2-” OR “Naphthalene, 2-methyl-” OR “Naphthalene, beta-methyl-” OR “β-Methylnaphthalene” OR “C1-Naphthalenes” OR “Dycar MN” OR “Methylated naphthalenes” OR “Methylnaphtalene” OR “Methylnaphthalenes” OR “Methylnaphthalin” OR “Methylnapthalene” OR “Monomethylnaphthalene” OR “Naphthalene, methyl-” OR “PETROL CARBON HYDROXIDE” OR “Sure-Sol 187” OR “Tetrosin MNLF”
Toxcenter
06/2024 | FILE ‘TOXCENTER’ ENTERED AT 15:18:23 ON 28 JUN 2024; L43 36475 SEA FILE=TOXCENTER 91-20-3 OR 90-12-0 OR 91-57-6 OR 1321-94-4; L47 33840 SEA FILE=TOXCENTER L43 NOT PATENT/DT; L48 2802 SEA FILE=TOXCENTER L47 AND ED>=20220401; ACT TOXQUERY/Q; ---------; L49 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?); L50 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT,IT); L51 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50); L52 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT; L53 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?); L54 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?); L55 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS OR DIETARY OR DRINKING(W)WATER?); L56 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE)); L57 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?); L58 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM? OR OVUM?); L59 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?); L60 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?); L61 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR SPERMATOB? OR SPERMATOC? OR SPERMATOG?); L62 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?); L63 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?); L64 QUE (ENDOCRIN? AND DISRUPT?); L65 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?); L66 QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?); L67 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?); L68 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR NEOPLAS?); L69 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?); L70 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?); L71 QUE (NEPHROTOX? OR HEPATOTOX?); L72 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?); L73 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?); L74 QUE L49 OR L50 OR L51 OR L52 OR L53 OR L54 OR L55 OR L56 OR L57 OR L58 OR L59 OR L60 OR L61 OR L62 OR L63 OR L64 OR L65 OR L66 OR L67 OR L68 OR L69 OR L70 OR L71 OR L72 OR L73; L75 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR SWINE OR PORCINE OR MONKEY? OR MACAQUE?); L76 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE); L77 QUE L74 OR L75 OR L76; L78 QUE (NONHUMAN MAMMALS)/ORGN; L79 QUE L77 OR L78; L80 QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL? OR PRIMATES OR PRIMATE?); L81 QUE L79 OR L80; ---------; L82 1477 SEA FILE=TOXCENTER L48 AND L81; L83 1470 SEA FILE=TOXCENTER L82 AND PY>2020; L84 51 SEA FILE=TOXCENTER L82 AND MEDLINE/FS; L85 1426 SEA FILE=TOXCENTER L82 NOT MEDLINE/FS; L86 1395 DUP REM L82 (82 DUPLICATES REMOVED); D SCAN L86; L88 3163 SEA FILE=TOXCENTER L47 AND PY>2021; L89 1699 SEA FILE=TOXCENTER L88 AND L81; L90 261 SEA FILE=TOXCENTER L89 NOT L82; L91 257 DUP REM L90 (4 DUPLICATES REMOVED); D SCAN L91
04/2022 | FILE ‘TOXCENTER’ ENTERED AT 16:10:03 ON 06 APR 2022; CHARGED TO COST=EH038.15.05.LB.04; L1 33022 SEA 91-20-3 OR 90-12-0 OR 91-57-6; L2 32785 SEA L1 NOT TSCATS/FS; L3 30517 SEA L2 NOT PATENT/DT; L4 20636 SEA L3 AND PY>=2002; ACTIVATE TOXQUERY/Q; ---------; L5 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?); L6 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT,IT); L7 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50); L8 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT; L9 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?); L10 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?); L11 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS OR DIETARY OR DRINKING(W)WATER?); L12 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE)); L13 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?); L14 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM? OR OVUM?); L15 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?); L16 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?); L17 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR SPERMATOB? OR SPERMATOC? OR SPERMATOG?); L18 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?); L19 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?); L20 QUE (ENDOCRIN? AND DISRUPT?); L21 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?); L22 QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?); L23 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?); L24 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR NEOPLAS?); L25 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?); L26 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?); L27 QUE (NEPHROTOX? OR HEPATOTOX?); L28 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?); L29 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?); L30 QUE L5 OR L6 OR L7 OR L8 OR L9 OR L10 OR L11 OR L12 OR L13 OR L14 OR L15 OR L16 OR L17 OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26 OR L27 OR L28 OR L29; L31 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR SWINE OR PORCINE OR MONKEY? OR MACAQUE?); L32 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE); L33 QUE L30 OR L31 OR L32; L34 QUE (NONHUMAN MAMMALS)/ORGN; L35 QUE L33 OR L34; L36 QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL? OR PRIMATES OR PRIMATE?); L37 QUE L35 OR L36; ---------; L38 9198 SEA L4 AND L37; L39 614 SEA L38 AND MEDLINE/FS; L40 8584 SEA L38 NOT MEDLINE/FS; L41 8313 DUP REM L39 L40 (885 DUPLICATES REMOVED); FILE ‘TOXCENTER’ ENTERED AT 11:22:56 ON 04 MAY 2022; CHARGED TO COST=EH038.15.05.LB.04; L1 1062 SEA FILE=TOXCENTER 1321-94-4; L2 1044 SEA FILE=TOXCENTER L1 NOT TSCATS/FS; L3 894 SEA FILE=TOXCENTER L2 NOT PATENT/DT; L4 444 SEA FILE=TOXCENTER L3 AND PY>2002; ACTIVATE TOXQUERY/Q; ---------; L5 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?); L6 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT,IT); L7 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50); L8 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT; L9 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?); L10 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?); L11 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS OR DIETARY OR DRINKING(W)WATER?); L12 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE)); L13 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?); L14 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM? OR OVUM?); L15 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?); L16 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?); L17 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR SPERMATOB? OR SPERMATOC? OR SPERMATOG?); L18 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?); L19 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?); L20 QUE (ENDOCRIN? AND DISRUPT?); L21 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?); L22 QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?); L23 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?); L24 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR NEOPLAS?); L25 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?); L26 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?); L27 QUE (NEPHROTOX? OR HEPATOTOX?); L28 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?); L29 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?); L30 QUE L5 OR L6 OR L7 OR L8 OR L9 OR L10 OR L11 OR L12 OR L13 OR L14 OR L15 OR L16 OR L17 OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26 OR L27 OR L28 OR L29; L31 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR SWINE OR PORCINE OR MONKEY? OR MACAQUE?); L32 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE); L33 QUE L30 OR L31 OR L32; L34 QUE (NONHUMAN MAMMALS)/ORGN; L35 QUE L33 OR L34; L36 QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL? OR PRIMATES OR PRIMATE?); L37 QUE L35 OR L36; ---------; L38 158 SEA FILE=TOXCENTER L4 AND L37; L39 0 SEA FILE=TOXCENTER L38 AND MEDLINE/FS; L40 154 DUP REM L38 (4 DUPLICATES REMOVED)

Table B-3 Strategies to Augment the Literature Search

Source | Query and number screened when available
TSCATS via ChemView
06/2024; 04/2022 | Compounds searched: 91-20-3; 90-12-0; 91-57-6; 1321-94-4
NPIRS
06/2024 | Compounds searched: 91-20-3; 90-12-0; 91-57-6; 1321-94-4
04/2022 | Compounds searched: 91-20-3; 90-12-0; 91-57-6
NTP
06/2024 | Limited 2020 to present or not dated; 91-20-3; 90-12-0; 91-57-6; 1321-94-4; “Naphthalene” “Methylnaphthalene”
04/2022 | Limited: 2000- present; 91-20-3; 90-12-0; 91-57-6; 1321-94-4; “Naphthalene” “Methylnaphthalene”
Regulations.gov
06/2024 | Notices limited to posted date 2022 to present; Naphthalene; “Methyl naphthalene”; 91-20-3; 91-57-6; Methylnaphthalene; 90-12-0; 1321-94-4
04/2022 | Limited: posted 2003-present; dockets or EPA notices; 91-20-3; 90-12-0; 91-57-6; 1321-94-4; Naphthalene; Methylnaphthalene; “Methyl naphthalene”
NIH RePORTER
09/2024 | Search Criteria: Fiscal Year: Active Projects Text Search: “Albocarbon” OR “Camphor tar” OR “Dezodorator” OR “Mighty 150” OR “Mighty RD1” OR “Moth balls” OR “Moth flakes” OR “Mothballs” OR “Naphtalene” OR “Naphtalinum” OR “Naphthalene” OR “Naphthalin” OR “Naphthaline” OR “Naphthalinum” OR “Naphthene” OR “Napthalene” OR “Tar camphor” OR “White tar” OR “1-METHYL-NAPHTHALENE” OR “1-Methylnaphtalene” OR “1-Methylnaphthalene” OR “1-Methylnaphthalin” OR “alpha-Methylnaphthalene” OR “Mechinafu H” OR “METHYL NAPHTHALENE” OR “Methylnaphthalene” OR “Methylnaphthalene, 1-” OR “Methynaph H” OR “Naphthalene, 1-methyl-” OR “Naphthalene, alpha-methyl-” OR “α-Methylnaphthalene” OR “2-Methylnaphtalene” OR “2-Methylnaphthalene” OR “2-Methylnaphthalin” OR “2-Methylnapthalene” OR “beta-Methylnaphthalene” OR “Methylnaphthalene, 2-” OR “Naphthalene, 2-methyl-” OR “Naphthalene, beta-methyl” OR “β-Methylnaphthalene” OR “C1-Naphthalenes” OR “Dycar MN” OR “Methylated naphthalenes” OR “Methylnaphtalene” OR “Methylnaphthalenes” OR “Methylnaphthalin” OR “Methylnapthalene” OR “Monomethylnaphthalene” OR “Naphthalene, methyl-” OR “PETROL CARBON HYDROXIDE” OR “Sure-Sol 187” OR “Tetrosin MNLF” (advanced) Limit to: Project Title, Project Terms, Project Abstracts
01/2023 | Search Criteria-- Fiscal Year: Active Projects, Text Search: “Albocarbon” OR “Camphor tar” OR “Dezodorator” OR “Mighty 150” OR “Mighty RD1” OR “Moth balls” OR “Moth flakes” OR “Mothballs” OR “Naphtalene” OR “Naphtalinum” OR “Naphthalene” OR “Naphthalin” OR “Naphthaline” OR “Naphthalinum” OR “Naphthene” OR “Napthalene” OR “Tar camphor” OR “White tar” OR “1-METHYL-NAPHTHALENE” OR “1-Methylnaphtalene” OR “1-Methylnaphthalene” OR “1-Methylnaphthalin” OR “alpha-Methylnaphthalene” OR “Mechinafu H” OR “METHYL NAPHTHALENE” OR “Methylnaphthalene” OR “Methylnaphthalene, 1-” OR “Methynaph H” OR “Naphthalene, 1-methyl-” OR “Naphthalene, alpha-methyl-” OR “α-Methylnaphthalene” OR “2-Methylnaphtalene” OR “2-Methylnaphthalene” OR “2-Methylnaphthalin” OR “2-Methylnapthalene” OR “beta-Methylnaphthalene” OR “Methylnaphthalene, 2-” OR “Naphthalene, 2-methyl-” OR “Naphthalene, beta-methyl-” OR “β-Methylnaphthalene” OR “C1-Naphthalenes” OR “Dycar MN” OR “Methylated naphthalenes” OR “Methylnaphtalene” OR “Methylnaphthalenes” OR “Methylnaphthalin” OR “Methylnapthalene” OR “Monomethylnaphthalene” OR “Naphthalene, methyl-” OR “PETROL CARBON HYDROXIDE” OR “Sure-Sol 187” OR “Tetrosin MNLF” (advanced), Limit to: Project Title, Project Terms, Project Abstracts
Other | Includes additional reference identified throughout the assessment process, which may include studies found by tree searching; recommended by intraagency, interagency, peer, or public reviewers; or published more recently than the date of literature search(es). Additional references include those for specific regulations or guidelines and publications found by targeted searches for specific information (e.g., searches for reviews of general [not chemical-specific] mechanisms of toxicity).

The 2022 pre-public comment search results were:

- Number of records identified from PubMed, NTRL, and TOXCENTER (after duplicate removal): 14,258
- Number of records identified from other strategies: 210
- Total number of records to undergo literature screening: 14,468

The 2024 post-public comment search results were:

- Number of records identified from PubMed, NTRL, and TOXCENTER (after duplicate removal): 2,022
- Number of records identified from other strategies: 29
- Total number of records to undergo literature screening: 2,051

### B.1.2 Literature Screening

A two-step process was used to screen the literature search to identify relevant studies on naphthalene, 1-methylnaphthalene, and 2-methylnaphthalene during the pre- and post-public comment drafts:

- Title and abstract screen
- Full text screen

Pre-Public Comment Title and Abstract Screen. Within the reference library, titles and abstracts were screened manually for relevance. Studies that were considered (see Table B-1 for inclusion criteria) were moved to the second step of the literature screening process. Studies were excluded when the title and abstract clearly indicated that the study was not relevant to the toxicological profile.

- Number of titles and abstracts screened: 14,468
- Number of studies considered relevant and moved to the next step: 720

Pre-Public Comment Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the title and abstract screen step. Each study was reviewed to determine whether it was relevant for inclusion in the toxicological profile.

- Number of studies undergoing full text review: 720
- Number of studies cited in the previous toxicological profile: 345
- Total number of studies cited in the profile: 566

A summary of the results of the pre-public literature search and screening is presented in Figure B-1.

Figure B-1 April 2022 Pre-Public Comment Literature Search Results and Screen for Naphthalene, 1 Methylnaphthalene, and 2-Methylnaphthalene^*^ * The chemistry studies category includes studies pertaining to the potential for human exposure (Table B-1). The toxicology studies category includes human and animal studies of health effects as well as studies of toxicokinetics, biomarkers, and interactions with other chemicals (Table B-1). The regulatory studies category includes those studies cited in Chapter 7.

Post-Public Comment Title and Abstract Screen. Within the reference library, titles and abstracts were screened manually for relevance. Studies that were considered relevant (see Table B-1 for inclusion criteria) were moved to the second step of the literature screening process. Studies were excluded when the title and abstract clearly indicated that the study was not relevant to the toxicological profile.

- Number of titles and abstracts screened: 2,051
- Number of studies considered relevant and moved to the next step: 167

Post-Public Comment Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the title and abstract screen step. Each study was reviewed to determine whether it was relevant for inclusion in the toxicological profile.

- Number of studies undergoing full text review: 167
- Number of studies cited in the pre-public draft of the toxicological profile: 566
- Total number of studies cited in the profile: 632

A summary of the results of the post-public comment literature search and screening is presented in Figure B-2.

Figure B-2 June 2024 Post-Public Comment Literature Search Results and Screen for Naphthalene, 1-Methylnaphthalene, and 2-Methylnaphthalene^*^ * The chemistry studies category includes studies pertaining to the potential for human exposure (Table B-1). The toxicology studies category includes human and animal studies of health effects as well as studies of toxicokinetics, biomarkers, and interactions with other chemicals (Table B-1). The regulatory studies category includes those studies cited in Chapter 7.