# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. LOAELs for serious health effects (such as irreparable damage to the liver or kidneys, or serious birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Office of Innovation and Analytics, Toxicology Section, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Office of Innovation and Analytics, Toxicology Section, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S106-5, Atlanta, Georgia 30329-4027.

## Naphthalene Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Naphthalene
CAS Numbers: | 91-20-3
Date: | March 2025
Profile Status: | Final
Route: | Inhalation
Duration: | Acute
MRL: | 6×10^−5^ ppm (3×10^−4^ mg/m^3^)
Critical Effect: | Nasal olfactory epithelial necrosis
References: | Dodd et al. 2010
Point of Departure: | BMCL_HEC_ of 0.0017 ppm
Uncertainty Factor: | 30
LSE Graph Key: | 4
Species: | Rat

MRL Summary: An acute-duration inhalation MRL of 6×10^−5^ ppm was derived for naphthalene based on a BMCL_10_, adjusted for continuous exposure and converted to a BMCL_HEC_ of 0.0017 ppm for increased incidences of nasal olfactory epithelial necrosis in Sprague-Dawley rats exposed to naphthalene by inhalation for 6 hours (Dodd et al. 2010). The BMCL_HEC_ was divided by a total uncertainty factor of 30 (10 for human variability and 3 for extrapolation from animals to humans when a dosimetric adjustment is used).

Selection of the Critical Effect: Most acute-duration inhalation studies of naphthalene focused on effects in the respiratory tract, a well-known target organ for inhaled naphthalene. Effects seen at the lowest exposure concentrations consisted of nasal lesions in rats. Table A-1 shows the lowest effect levels for acute-duration inhalation studies of naphthalene. As Table A-1 shows, the lowest LOAELs were for nasal olfactory lesions in rats.

Table A-1 Summary of Lowest NOAEL and LOAEL Values for Sensitive Targets of Acute Inhalation Exposure to Naphthalene^a^

Species | Duration | NOAEL (ppm) | LOAEL (ppm) | NOAEL_ADJ_ (ppm) | LOAEL_ADJ_ (ppm) | Effect | Reference
Rat; (Sprague-Dawley) | Once, 6 hours | ND | 0.1 | ND | 0.025 | Minimal severity necrosis of the nasal olfactory epithelium | Dodd et al. 2010
Rat; (F344) | Once, 6 hours | 0.3 | 1.0 | 0.075 | 0.25 | Minimal severity necrosis of the nasal olfactory epithelium | Dodd et al. 2010
Rat; (Sprague-Dawley) | 5 days, 6 hours/day | | 0.1 | | 0.025 | Minimal severity necrosis of the nasal olfactory epithelium in females | Dodd et al. 2010
Rat; (F344) | 5 days, 6 hours/day | 0.1 | 1.0 | 0.025 | 0.25 | Minimal severity necrosis of the nasal olfactory epithelium and nasopharyngeal goblet cell hyperplasia | Dodd et al. 2010
Mouse; (Swiss) | Once, 2 hours | ND | 1.5 | ND | 0.13 | Mild cell loss in nasal olfactory epithelium | Phimister et al. 2004
Rat; (Sprague-Dawley) | Once, 4 hours | ND | 3.4 | ND | 0.57 | Necrosis, vacuolation, and exfoliation of the nasal olfactory epithelium | Lee et al. 2005
Mouse; (B6:129) | Once, 4 hours | ND | 5 | ND | 0.83 | Epithelial damage (vacuolization and swelling) in proximal airways | Carratt et al. 2016
Mouse; (C57BL/6) | Once, 4 hours | ND | 5 | ND | 0.83 | Epithelial damage (vacuolization and swelling) in proximal airways | Carratt et al. 2019b

a Green shading shows principal study for MRL derivation.

ADJ = adjusted; ND = not determined; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level

Selection of the Principal Study: The study by Dodd et al. (2010) identified the lowest LOAEL (0.1 ppm) and was selected as the principal study.

Summary of the Principal Study:

Dodd DE, Gross EA, Miller RA, . 2010. Nasal olfactory epithelial lesions in F344 and SD rats following 1- and 5-day inhalation exposure to naphthalene vapor. Int J Toxicol 29(2):175–184.20086191

Sprague-Dawley and Fischer-344 rats (5/sex/strain/group) were exposed whole body to naphthalene vapor at concentrations of 0, 0.1, 0.3, 1, 10, and 30 ppm for 6 hours. During exposure, animals were monitored for mortality, clinical signs of toxicity, and body weight. One day following the exposure, animals were sacrificed for gross necropsy and histopathology of nasal tissues. No mortality or clinical signs occurred, and no effects on body weight or gross necropsy findings were observed. Necrosis of the nasal olfactory epithelium was observed at all concentrations in Sprague-Dawley rats and at concentrations ≥1 ppm in F344 rats; incidences are summarized in Table A-2. Mean severity scores for each exposure level were not reported; however, in a later publication, Dodd et al. (2012) reported that the severity of this effect at 1 ppm in the 1-day experiment was minimal. Necrosis of the nasal respiratory epithelium was observed in all rats of both strains and sexes at 10 and 30 ppm; controls and animals of lower exposure groups did not show this effect (apart from one of five male Sprague-Dawley rats at 1 ppm). Severity scores for necrosis of the nasal respiratory epithelium were not reported qualitatively or quantitatively.

Table A-2 Incidence of Selected Nasal Lesions in Sprague-Dawley and Fischer-344 Rats Exposed to Naphthalene for 6 Hours (Once) or 5 Days (6 Hours/Day)

Strain | Sex | Exposure concentration (ppm)
Strain | Sex | 0 | 0.1 | 0.3 | 1 | 10 | 30
Nasal olfactory epithelium necrosis (Level 3), 6-hour exposure
Sprague-Dawley | M; F | 0/5; 1/5 | 2/5; 1/5 | 3/5; 2/5 | 4/5; 4/5 | 5/5; 5/5 | 5/5; 5/5
F344 | M; F | 0/5; 0/5 | 0/5; 0/5 | 0/5; 0/5 | 5/5; 4/5 | 5/5; 5/5 | 5/5; 5/5
Nasal olfactory epithelium degeneration (Level 3), 5-day exposure
Sprague-Dawley | M; F | 0/5; 0/5 | 0/10; 2/10 | | 9/10; 10/10 | 10/10; 10/10
F344 | M; F | 0/5; 0/5 | 0/10; 0/10 | | 8/10; 10/10 | 10/10; 10/10

Source: Dodd et al. 2010

Selection of the Point of Departure for the MRL: Necrosis of the olfactory epithelium occurred at a lower exposure level in Sprague-Dawley rats than in F344 rats, so the data for Sprague-Dawley rats were selected as the basis for the MRL derivation. BMD modeling was conducted to identify a POD using the data for necrosis of the olfactory epithelium in male and female Sprague-Dawley rats administered naphthalene via inhalation for 6 hours. The data were fit to all available dichotomous models in EPA’s Benchmark Dose Software (BMDS, version 3.2.0.1) using a benchmark response (BMR) of 10% extra risk. Adequate model fit was judged by four criteria: goodness-of-fit statistics (p-value >0.1), visual inspection of the dose-response curve, a 95% confidence limit on the BMC (BMCL) that is not 10 times lower than the lowest non-zero dose, and scaled residual within ±2 units at the data point (except the control) closest to the predefined BMR. Among all of the models providing adequate fit to the data, the lowest BMCL was selected as the POD when the difference between the BMCLs estimated from these models was >3-fold; otherwise, the BMCL from the model with the lowest Akaike information criterion (AIC) was chosen. BMDS recommended the frequentist restricted log-logistic model for the data, and after verifying the model fit by the four criteria listed above, this model was selected as the basis for estimating this MRL. The BMC/BMCL values considered for MRL derivation are presented in Table A-3 and the fit of the selected model is presented in Figure A-1.

Table A-3 Model Predictions for Increased Incidence of Necrosis of the Olfactory Epithelium in Male and Female Sprague-Dawley Rats Exposed to Naphthalene via Inhalation for 6 Hours (Dodd et al. 2010)

Model | BMC_10_^a^ (ppm) | BMCL_10_^a^ (ppm) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMC_10_^a^ (ppm) | BMCL_10_^a^ (ppm) | p-Value^b^ | AIC | Dose below BMC | Dose above BMC
Dichotomous Hill | 0.062 | 0.017 | 0.87 | 51.00 | −0.10 | 0.27
Gamma^d^ | 0.064 | 0.037 | 0.99 | 46.85 | −0.24 | 0.31
Log-Logistic ^e^ ^,^ ^f^ | 0.062 | 0.017 | 0.96 | 49.00 | −0.10 | 0.27
Multistage Degree 5^g^ | 0.064 | 0.037 | 0.97 | 48.85 | −0.24 | 0.31
Multistage Degree 4^g^ | 0.064 | 0.037 | 0.97 | 48.85 | −0.24 | 0.31
Multistage Degree 3^g^ | 0.064 | 0.037 | 0.99 | 46.85 | −0.24 | 0.31
Multistage Degree 2^g^ | 0.064 | 0.037 | 0.99 | 46.85 | −0.24 | 0.31
Multistage Degree 1^g^ | 0.064 | 0.034 | 0.99 | 46.85 | −0.24 | 0.31
Weibull^d^ | 0.064 | 0.037 | 0.99 | 46.85 | −0.24 | 0.31
Logistic | 0.144 | 0.094 | 0.85 | 48.09 | 0.27 | 0.70
Log-Probit | | | 0.99 | 48.78 | −0.06 | 0.20
Probit | 0.289 | 0.221 | 0.40 | 50.52 | −1.62 | −0.43

a BMC and BMCLs values for models that do not provide adequate fit or yield BMCLs more than 10-fold lower than the lowest nonzero exposure concentration are not included in this table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the BMC.

d Power restricted to ≥1.

e Slope restricted to ≥1.

f All models provided an adequate fit to the data. BMCLs were not sufficiently close (differed by >3-fold). Therefore, the model with the lowest BMCL was selected (Log-Logistic).

g Betas restricted to ≥0.

AIC = Akaike Information Criterion; BMC = benchmark concentration (maximum likelihood estimate of the concentration associated with the selected benchmark response); BMCL_10_ = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., 10 = dose associated with 10% extra risk)

Figure A-1 Fit of the Log-logistic Model to Data for Naphthalene, Necrosis Olfactory Epithelium in Male and Female Sprague-Dawley Rats (Dodd et al. 2010)

Calculations

Adjustment for Intermittent Exposure: Dodd et al. (2010) exposed rats to naphthalene for 6 hours of 1 day. Therefore, the BMCL_10_ was adjusted for intermittent exposure as follows:

B M C L_A D J_ = B M C L × (6 h o u r s)/(24 h o u r s) = 0.017 p p m × (6 h o u r s)/(24 h o u r s) = 0.0043 p p m

Human Equivalent Concentration: The critical effect was nasal olfactory epithelium necrosis in the respiratory system. PBPK modeling was considered for interspecies extrapolation. There are hybrid computational fluid dynamics-PBPK models that predict nasal tissue concentrations of naphthalene metabolites in rats and humans exposed by inhalation, namely Campbell et al. (2014) and Kapraun et al. (2020). However, there has been no direct evaluation of the Campbell et al. (2014) or Kapraun et al. (2020) models for predicting nasal tissue doses in human. The calibration of the Kapraun et al. (2020) model was limited to observations of blood naphthalene levels following dermal exposures to JP-8. While the calibrated model performed well for predicting observed blood naphthalene levels, the predicted blood naphthalene levels were relatively insensitive to nasal cavity parameter values and highly sensitive to dermal and systemic parameters (e.g., blood flow to liver, skin exposure surface area, partition coefficients for skin and systemic tissues). Therefore, the model could perform well for predicting blood naphthalene following dermal exposures but perform poorly at predicting nasal cavity doses following inhalation. For this reason, the models were not used.

The BMCL_ADJ_ was converted to a BMCL_HEC_ using guidance from EPA (1994) on dosimetric adjustments for respiratory effects using the RGDR for extrathoracic effects (RGDR_ET_). This RGDR_ET_ is calculated using the following equation as defined by EPA (1994):

R G D R_E T_ = (V_E_a__)/(S A_a_) ÷ (V_E_h__)/(S A_h_) = (0.413)/(15) ÷ (13.8)/(200) = 0.40

where:

- V_E_a__ = ventilation rate for male and female Sprague-Dawley rats = 0.413 L/minute (EPA 2012)
- SA_a_ = surface area of the extrathoracic region in rats = 15 cm^2^ (EPA 1994)
- V_E_h__ = ventilation rate for humans = 13.8 L/minute (EPA 1994)
- SA_h_ = surface area of the extrathoracic region in humans = 200 cm^2^ (EPA 1994)

Applying this equation results in an RGDR of 0.40 for extrathoracic effects in rats, and the HEC is calculated as:

B M C L_10 H E C_ = B M C L_10 A D J_ × R G D R = 0.0043 p p m × 0.40 = 0.0017 p p m

Uncertainty Factor: The BMCL_HEC_ was divided by a composite uncertainty factor of 30:

- 10 for human variability
- 3 for animal to human extrapolation after dosimetric adjustment.

This results in the following MRL:

M R L = (B M C L_H E C_)/(U F s) = (0.0017 p p m)/(30) ≈ 0.00006 p p m ( 6 × 10^− 5^ p p m )

Other Additional Studies or Pertinent Information that Lend Support to this MRL: The respiratory tract is a well-established target of naphthalene exposure. In humans exposed occupationally, effects of naphthalene on the respiratory system include inflammation and irritation of the nasal tissue (Sucker et al. 2021). Studies in rats and mice exposed to naphthalene by inhalation consistently demonstrate adverse effects on the olfactory and respiratory epithelium of the nasal cavity. Acute-duration exposures typically result in nasal tissue injury (necrosis, vacuolation, swelling, and exfoliation) (Carratt et al. 2016, 2019a; Cichocki et al. 2014; Dodd et al. 2010; Lee et al. 2005; Li et al. 2017; Phimister et al. 2004). With longer exposure durations, regenerative changes consisting of hyperplasia and metaplasia and lesions deeper in the nasal cavity are seen (Abdo et al. 2001; Dodd et al. 2012; NTP 1992a, 2000). Available data suggest that rats may be more sensitive to the nasal effects of naphthalene than mice, and that Sprague-Dawley rats may be more sensitive than F344 rats. However, the only studies using exposure concentrations <1 ppm were those by Dodd et al. (2010, 2012). These studies tested only rats, and Sprague-Dawley rats were tested only in the acute-duration experiments (Dodd et al. 2010).

The odor threshold for naphthalene in air is 0.44 mg/m^3^ or 0.084 ppm (see Section 4.2).

Agency Contacts (Chemical Managers): Gaston Casillas, Ph.D.

## Naphthalene Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Naphthalene
CAS Numbers: | 91-20-3
Date: | March 2025
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: An intermediate-duration inhalation MRL was not derived for naphthalene. The one available intermediate-duration study (Dodd et al. 2012) identified a NOAEL for nasal lesions in F344 rats at the same concentration (0.1 ppm) as the LOAEL for nasal lesions after acute-duration exposure in Sprague-Dawley rats, precluding use of the intermediate-duration study for deriving an MRL. No intermediate-duration inhalation studies using Sprague-Dawley rats were located. Based on current information, it is possible that the acute-duration inhalation MRL may be protective for intermediate-duration exposure, but this cannot be known with certainty without intermediate-duration studies using Sprague-Dawley rats. Nevertheless, a health-protective option available at present would be to use the acute-duration MRL to assess intermediate-duration exposure. This option is considered to be health-protective because studies conducted in F344 rats have found that the LOAELs for acute-duration and subchronic-duration studies are similar (1 ppm), which suggests that adverse effects on the nasal cavity in rats may be independent of exposure duration.

Rationale for Not Deriving an MRL: There is one intermediate-duration inhalation study of naphthalene in laboratory animals: a 13-week study in rats (Dodd et al. 2012). In this study, groups of F344 rats (10/sex/group) were exposed, whole body, to naphthalene vapor at concentrations of 0 (air control), 0.1, 1, 10 or 30 ppm for 6 hours/day, 5 days/week for 90 days. At the LOAEL of 1 ppm, effects included reduced absolute (but not relative to body weight) thymus weights in females and minimal hyperplasia of the transitional/respiratory epithelium at Level 2 of the nasal cavity (in all exposed males; incidence not reported for females). At higher concentrations, transitional/respiratory epithelium metaplasia was seen at Level 2, and olfactory epithelium degeneration/necrosis and basal cell hyperplasia were observed at Levels 2–5. In males, severity scores for olfactory epithelial degeneration/necrosis were minimal to mild at 10 ppm and mild to moderate at 30 ppm; severity scores for basal cell hyperplasia were minimal at 10 ppm and mild at 30 ppm. Severity in females was not reported. Minimal severity goblet cell hyperplasia of the nasopharyngeal duct was noted at Level 5.

The nasal lesions seen in F344 rats exposed for 90 days are consistent with the effects seen in acute-duration (1- and 5-day) exposures and with those seen in the 2-year study (Abdo et al. 2001; NTP 2000). Acute-duration exposures are associated with necrosis of the olfactory and respiratory epithelia in the anterior portions of the nose. With longer exposure durations, regenerative changes consisting of hyperplasia and metaplasia and lesions deeper in the nasal cavity are seen. Table A-4 provides an overview of the progression of nasal lesions with time and exposure concentration. As the table shows, Sprague-Dawley rats appear to be more sensitive than F344 rats to naphthalene at the 6-hour exposure duration. With a 5-day exposure, the two strains respond differently but do not appear to differ in sensitivity. There are no 90-day or 2-year studies in Sprague-Dawley rats. The table also demonstrates that the NOAEL for F344 rats in the 90-day study is the same concentration as the LOAEL for Sprague-Dawley rats in the 1-day study. Thus, the one available intermediate-duration study is not suitable for use in deriving an MRL.

Table A-4 Treatment-related Nasal Lesions in Male and Female Rats exposed to Naphthalene by Inhalation

Duration | Rat strain | Exposure concentration^a^ (ppm)
Duration | Rat strain | 0.1 | 0.3 | 1 | 10 | 30 | 60
1 Day, 6 hours | Sprague-Dawley | OE necrosis in 3/10 (L3) | OE necrosis in 5/10 (L3) | OE necrosis (L3) | OE necrosis (L3) | OE necrosis (L3)
1 Day, 6 hours | Sprague-Dawley | OE necrosis in 3/10 (L3) | OE necrosis in 5/10 (L3) | RE necrosis in 1/10 | RE necrosis (tip to L3) | RE necrosis (tip to L3)
1 Day, 6 hours | F344 | None | None | OE necrosis (L3) | OE necrosis (L3) | OE necrosis (L3)
1 Day, 6 hours | F344 | None | None | | RE necrosis (tip to L3) | RE necrosis (tip to L3)
5 Days, 6 hours/day | Sprague-Dawley | OE degeneration in 2/10 (L3) | | OE degeneration (L3) | OE degeneration (L3–5); Goblet cell hyperplasia (L4 and L5)
5 Days, 6 hours/day | F344 | Goblet cell hyperplasia in 2/10 (L5) | | OE degeneration (L3) | OE degeneration (L3–5)
5 Days, 6 hours/day | F344 | Goblet cell hyperplasia in 2/10 (L5) | | Goblet cell hyperplasia in 3/10 (L5) | Goblet cell hyperplasia (L4 and L5)
90 Days, 5 days/week, 6 hours/day | F344 | None | | T/RE hyperplasia (L2) | T/RE squamous metaplasia (L2) | T/RE squamous metaplasia (L2)
90 Days, 5 days/week, 6 hours/day | F344 | None | | | OE necrosis and hyperplasia (L2–L5) | OE necrosis and hyperplasia (L2–L5)
90 Days, 5 days/week, 6 hours/day | F344 | None | | | | Goblet cell hyperplasia (NPD)
2 Years, 5 days/week, 6 hours/day | F344 | | | | OE hyperplasia, atrophy, inflammation, hyaline degeneration; | OE hyperplasia, atrophy, inflammation, hyaline degeneration; | OE hyperplasia, atrophy, inflammation, hyaline degeneration;
2 Years, 5 days/week, 6 hours/day | F344 | | | | RE hyperplasia, squamous metaplasia, hyaline degeneration, goblet cell hyperplasia, glandular hyperplasia and squamous metaplasia; nasal tumors | RE hyperplasia, squamous metaplasia, hyaline degeneration, goblet cell hyperplasia, glandular hyperplasia and squamous metaplasia; nasal tumors | RE hyperplasia, squamous metaplasia, hyaline degeneration, goblet cell hyperplasia, glandular hyperplasia and squamous metaplasia; nasal tumors

a Gray shading shows exposure concentrations that were not tested for the corresponding duration. Bold indicates lesions observed in most animals at this exposure level.

L1–L5 Nasal cavity levels 1–5; NPD = nasopharyngeal duct; OE = olfactory epithelium; RE = respiratory epithelium (of the nasal cavity); T/RE = transitional/respiratory epithelium (of the nasal cavity)

Sources: Abdo et al. 2001; Dodd et al. 2010, 2012; NTP 2000

Agency Contacts (Chemical Managers): Gaston Casillas, Ph.D.

## Naphthalene Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Naphthalene
CAS Numbers: | 91-20-3
Date: | March 2025
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: A chronic-duration inhalation MRL was not derived for naphthalene. Available chronic-duration studies identified LOAELs without NOAELs at a concentration (10 ppm) 2 orders of magnitude higher than the LOAEL for acute-duration exposure (0.1 ppm), precluding their use in deriving an MRL. Consistent with acute- and intermediate-duration inhalation studies of naphthalene, the available chronic-duration inhalation studies of naphthalene also identified nasal lesions as the critical effect. In the absence of chronic-duration inhalation studies at lower concentrations, a chronic-duration MRL could not be derived. Based on current information, it is possible that the acute-duration inhalation MRL may be protective for chronic-duration exposures, but this cannot be known with certainty without chronic-duration inhalation studies at lower concentrations. Nevertheless, a health-protective option available at present would be to use the acute-duration MRL to assess chronic-duration exposures. This option is considered to be health-protective because a chronic MRL based on the LOAEL from the NTP (2000) chronic study would be higher (less health-protective) than the acute-duration MRL, and because studies conducted in F344 rats have found that the LOAELs for acute- and subchronic-duration studies are similar (1 ppm), which suggests that adverse effects on the nasal cavity in rats may be independent of exposure duration.

Rationale for Not Deriving an MRL: The NTP (Abdo et al. 2001; NTP 1992a, 2000) conducted 2-year bioassays in B6C3F1 mice and F344/N rats exposed to naphthalene by inhalation at concentrations of 0, 10, or 30 ppm. The lowest exposure level was a LOAEL in both sexes of both species for nonneoplastic lesions in the olfactory and respiratory epithelium of the nasal cavity affecting essentially all of the animals. Mice also exhibited increased incidences of lung inflammation at the LOAEL (NTP 1992a), and an increased incidence of nasal respiratory epithelial adenomas was seen in male rats at the LOAEL (NTP 2000; Abdo et al. 2001); see Table A-3.

The LOAEL of 10 ppm for both mice and rats in the available chronic-duration inhalation studies is 100-fold higher than the LOAEL of 0.1 ppm for nasal lesions in Sprague-Dawley rats in the 1-day exposure study (Dodd et al. 2010) that was used for the acute-duration inhalation MRL. In the absence of chronic-duration studies using lower exposure concentrations, a chronic-duration inhalation MRL could not be derived.

Agency Contacts (Chemical Managers): Gaston Casillas, Ph.D.

## Naphthalene Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Naphthalene
CAS Numbers: | 91-20-3
Date: | March 2025
Profile Status: | Final
Route: | Oral
Duration: | Acute
MRL: | 0.2 mg/kg/day
Critical Effect: | Clinical signs of neurotoxicity (slow respiration, lethargy, or prone body posture)
Reference: | NTP 1991
Point of Departure: | LOAEL of 50 mg/kg/day
Uncertainty Factor: | 300
LSE Graph Key: | 3
Species: | Rat

MRL Summary: An acute-duration oral MRL of 0.2 mg/kg/day was derived for naphthalene based on a LOAEL of 50 mg/kg/day for clinical signs of neurotoxicity (slow respiration, lethargy, and pronation) in rats administered naphthalene via gavage during gestation (NTP 1991). The LOAEL was divided by a total uncertainty factor of 300 (10 for extrapolation from animals to humans, 3 for use of a minimal LOAEL, and 10 for human variability).

Selection of the Critical Effect: A number of studies have evaluated the toxicity of naphthalene following acute-duration oral exposure; these studies examined a variety of endpoints including developmental (NTP 1991, 1992a, 1992b; Plasterer et al. 1985; Texaco 1985d, 1986), hepatic (Rao and Pandya 1981; Zhang et al. 2016), respiratory (Kelty et al. 2020; Shopp et al. 1984; Zhang et al. 2015, 2016), and neurological (NTP 1991). The lowest LOAELs for these studies range from 50 to 300 mg/kg/day and are shown in Table A-5. The available data indicate that clinical signs of neurotoxicity were the most sensitive endpoint following acute-duration oral exposure. In pregnant female Sprague-Dawley rats exposed to naphthalene via gavage during GDs 6–15, a LOAEL of 50 mg/kg/day was determined based on clinical signs of neurotoxicity including slowed respiration, lethargy, and pronation (NTP 1991). The next highest LOAEL was 100 mg/kg/day, which was a serious LOAEL for respiratory effects (Zhang et al. 2016, 2017).

Table A-5 Summary of Lowest NOAEL and LOAEL Values for Sensitive Targets of Acute Oral Exposure to Naphthalene^a^

Species | Duration | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Neurological effects
Sprague-Dawley rat | GDs 6–15 | ND | 50 | Transient clinical signs of toxicity (lethargy) in dams; at higher exposure levels, signs were more persistent | NTP 1991
New Zealand rabbit | GDs 6–18 | 40 | 200 | Maternal body drop and hypoactivity with no pathological changes | Texaco 1985d, 1986
Respiratory effects
Kunming mouse | Once | ND | 100 (SLOAEL) | Lung histopathology including structural degeneration, vasocongestion, edema, inflammatory cell infiltration and destroyed interalveolar septa with large, irregular alveolar space | Zhang et al. 2015
Kunming mouse | Once | ND | 100 (SLOAEL) | Lung structural degeneration, inflammatory cell infiltrate, vasocongestion, edema, alterations of alveoli and alveolar septa | Zhang et al. 2016
B6C3F1 mouse | Once | ND | 150 | Respiratory epithelial cytotoxicity | Kelty et al. 2020
New Zealand rabbit | GDs 6–18 | 40 | 200 (SLOAEL) | Maternal dyspnea, cyanosis | Texaco 1985d, 1986
Hepatic effects
Kunming mouse | Once | ND | 100 (SLOAEL) | Increased serum levels of AST (>5-fold) and ALT (>13-fold), extensive hepatocellular necrosis, moderate inflammatory cell infiltration, massive fatty degeneration, and structural degeneration | Zhang et al. 2016
Death
CD-1 mouse | 14 days | NA | 267 (SLOAEL) | 10/96 male and 3/60 females died | Shopp et al. 1984
CD-1 mouse | GDs 7–4 | NA | 300 (SLOAEL) | 5/33 dams died | Plasterer et al. 1985

a Green shading shows principal study for MRL derivation.

ALT = alanine aminotransferase; AST = aspartate aminotransferase; GD = gestation day; LOAEL = lowest-observed-adverse-effect level; M = male(s); NOAEL = no-observed-adverse-effect level; SLOAEL = serious lowest-observed-adverse-effect level

Selection of the Principal Study: The lowest LOAEL was 50 mg/kg/day based on clinical signs of toxicity in rats in the developmental study by NTP (1991); the next highest LOAEL was a serious LOAEL of 100 mg/kg/day for respiratory effects in mice (Zhang et al. 2015, 2016). Therefore, the study by NTP (1991) was selected as the principal study.

Summary of the Principal Study:

NTP. 1991. Developmental toxicity of naphthalene (CAS No. 91-20-3) administered by gavage to Sprague-Dawley (CD) rats on gestational days 6 through 15. Research Triangle Park, NC: National Toxicology Program, National Institute of Environmental Health Sciences, U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. TER91006.

Groups of 25 pregnant female Sprague-Dawley rats were administered naphthalene in corn oil at doses of 0, 50, 150, and 450 mg/kg/day during GDs 6–15. Dams were monitored for death and clinical signs of toxicity daily. Body weights were measured. Dams were sacrificed on GD 20 for necropsy. Uteruses were weighed and uterine contents were examined for number of implantation sites, resorptions, dead and live fetuses, fetal body weights, and external and visceral malformations.

There were no treatment-related mortalities. Rat dams in exposed groups showed one or more of several clinical signs of toxicity (slow respiration, lethargy, or prone body posture) on the first day of dosing (81, 96, and 96% of rats in the 50-, 150-, and 450-mg/kg/day groups, respectively). By the third day of dosing, these signs did not occur in any of the 50-mg/kg/day rats. A similar trend was noted in the 150-mg/kg/day group, but apparent tolerance did not develop until the sixth day of dosing. In the 450-mg/kg/day group, the incidence of rats exhibiting these signs of toxicity also declined during the exposure period but did not fall below 15%. With the development of “tolerance,” the slow respiration, lethargy, and prone body posture were replaced with rooting behavior, a common behavior of rodents following gavage administration of chemicals with strong odors or irritant properties. At the end of the exposure period (GD 15), incidence of rats showing rooting behavior was 0% for the control and 50-mg/kg/day groups, compared with 24 and 92% of dams in the 150- and 450-mg/kg/day groups, respectively. Weight gain during exposure (GDs 6–15) was similar between the control and 50-mg/kg/day group but was decreased by 31 and 53% in the 150- and 450-mg/kg/day groups, compared with controls. From these results, 50 mg/kg/day was judged to be a minimal less serious LOAEL for transient clinical signs of maternal toxicity in pregnant rat dams. At higher doses (150 and 450 mg/kg/day), these effects were more persistent and were accompanied by decreased weight gain. No effects were observed on uterus weights, pregnancy rate, number of implantation sites, resorptions, dead and live fetuses, or fetal body weights. At 0, 50, 150, and 450 mg/kg/day, the percentages of malformed fetuses per litter were 4, 4, 7, and 10%, respectively, and the percentages of litters with malformed fetuses were 23, 27, 33, and 50%, respectively. Both effects were statistically significant by trend test, but pairwise comparisons between individual exposure groups and the control were not statistically significant.

Selection of the Point of Departure for the MRL: The lowest LOAEL was 50 mg/kg/day based on transient clinical signs of toxicity in rats exposed during gestation. As the data were not amenable to BMD modeling, a LOAEL approach was used.

Calculations

Adjustment for Intermittent Exposure: Not applicable.

Uncertainty Factor: The LOAEL of 50 mg/kg/day was divided by a total uncertainty factor of 300 (10 for extrapolation from animals to humans, 10 for human variability, and 3 for use of a minimal LOAEL), resulting in an MRL of 0.2 mg/kg/day.

- 10 for extrapolation from animals to humans
- 10 for human variability
- An uncertainty factor of 3 was selected for the use of a minimal LOAEL of 50 mg/kg/day. At this dose level, the only adverse effects observed in the pregnant rat dams were signs of maternal toxicity, which were only observed on the first 2 days of exposure.

MRL = LOAEL ÷ UF = 50 mg / kg / day ÷ ( 10 × 10 × 3 ) = 0.16 mg / kg / day, rounded to 0.2 mg / kg / day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Neurologic symptoms have been reported in humans following ingestion of naphthalene at unknown, but presumably high dose levels. These include confusion (Ojwang et al. 1985) and listlessness and lethargy (Bregman 1954; Chusid and Fried 1955; Kurz 1987; MacGregor 1954; Zuelzer and Apt 1949), as well as decreased responses to painful stimuli and coma prior to death (Gupta et al. 1979; Kurz 1987). Persistent neurologic symptoms were not recorded in 13-week studies with rats or mice exposed to doses as high as 200 mg/kg/day (NTP 1980a, 1980b), but the highest exposure level tested in these studies, 400 mg/kg/day, produced lethargy in exposed rats (only rats were exposed to 400 mg/kg/day).

Hemolytic anemia has been identified in many human cases of acute accidental or intentional ingestion of naphthalene (e.g., Gidron and Leurer 1956; MacGregor 1954). Estimations of dose levels involved in these cases, however, are limited to a report (Gidron and Leurer 1956) of hemolytic anemia in a 16-year-old girl who swallowed 6 g of naphthalene (estimated dose=109 mg/kg, assuming body weight of 55 kg). Laboratory animals do not appear to be susceptible to the hemolytic activity of naphthalene. No pronounced changes in red-cell-related hematologic parameters were observed following 13-week oral exposures to doses up to 200 mg/kg/day in mice (NTP 1980a) and 400 mg/kg/day in rats (NTP 1980b), or in mice exposed by inhalation for 14 days to air concentrations as high as 30 ppm (NTP 1992a). Naphthalene-induced hemolytic anemia has been observed in dogs exposed to a single dose of 1,525 mg/kg or 263 mg/kg/day for 7 days (Zuelzer and Apt 1949), but more information on the dose-response relationship for hemolytic anemia in humans or animals acutely exposed to naphthalene is not available.

Development of cataracts is also associated with acute or repeated oral exposure to naphthalene in animals (Kojima 1992; Murano et al. 1993; van Heyningen and Pirie 1967; Xu et al. 1992b). These ocular effects, however, appear to occur at dose levels (in the range of 500–1,000 mg/kg/day) much higher than the lowest dose level (50 mg/kg/day) producing clinical signs of toxicity in pregnant rats.

Agency Contacts (Chemical Managers): Gaston Casillas, Ph.D.

## Naphthalene Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Naphthalene
CAS Numbers: | 91-20-3
Date: | March 2025
Profile Status: | Final
Route: | Oral
Duration: | Intermediate
MRL: | 0.2 mg/kg/day (based on the acute-duration oral MRL)
Critical Effect: | Clinical signs of neurotoxicity (slow respiration, lethargy, or prone body posture)
Reference: | NTP 1991 (see acute-duration oral MRL)
Point of Departure: | LOAEL of 50 mg/kg/day
Uncertainty Factor: | 300
LSE Graph Key: | 3
Species: | Rat

MRL Summary: The acute-duration oral MRL of 0.2 mg/kg/day based on a LOAEL of 50 mg/kg/day for clinical signs of slow respiration, lethargy, and pronation in rats administered naphthalene via gavage during gestation (NTP 1991) was adopted as the intermediate-duration oral MRL. Three intermediate-duration oral toxicity studies in rats and mice that included comprehensive toxicological evaluations provide support for the use of the acute-duration oral MRL for the intermediate duration.

Selection of the Critical Effect: See worksheet for acute-duration oral MRL.

Selection of the Principal Study: See worksheet for acute-duration oral MRL.

Summary of the Principal Study: See worksheet for acute-duration oral MRL.

Selection of the Point of Departure for the MRL: See worksheet for acute-duration oral MRL.

Calculations: See worksheet for acute-duration oral MRL.

Uncertainty Factor: See worksheet for acute-duration oral MRL.

Other Additional Studies or Pertinent Information that Lend Support to this MRL: A number of studies have evaluated the toxicity of naphthalene following intermediate-duration oral exposure. The majority of these studies used naphthalene to induce cataracts and used only high doses known to give this result (Chen et al. 2010a, 2010b, 2012; Holmén et al. 1999; Kojima 1992; Murano et al. 1993; Orzalesi et al. 1994; Patel and Patel 2018; Rathbun et al. 1990; Rossa and Pau 1988; Siddiqui et al. 2002; Singh and Bodakhe 2020; Tao et al. 1991; van Heyningen and Pirie 1967; Xu et al. 1992b; Yamauchi et al. 1986).

Apart from the studies of cataracts, there are three single dose studies of limited endpoints (Darious et al. 2020; Germansky and Jamall 1988; Katsnelson et al. 2014) and three comprehensive intermediate-duration oral toxicity studies in laboratory animals (NTP 1980a, 1980b; Shopp et al. 1984). A 13-week oral toxicity study in Fischer 344 rats found no adverse exposure-related effects other than decreased body weight (NTP 1980b). This study identified a LOAEL of 200 mg/kg/day based on decreased body weights and a NOAEL of 100 mg/kg/day. A 13-week oral toxicity study in B6C3F1 mice found no adverse effects in mice exposed to doses as high as 200 mg/kg/day (NTP 1980a). A 90-day gavage study in mice that focused on immune toxicity identified 133 mg/kg/day as a LOAEL for weight decreases in several organs (brain, liver, and spleen) and 53 mg/kg/day as a NOAEL but found no biologically significant exposure-related changes in other endpoints evaluated (Shopp et al. 1984). This study, however, did not include histopathological examination of tissues.

In the three comprehensive toxicity studies, the most sensitive effects were decreased spleen and liver weights in mice exposed to 133 mg/kg/day; the NOAEL for these effects was 53 mg/kg/day (Shopp et al. 1984). Considering that the NOAEL for the lowest LOAEL in intermediate-duration studies was greater than the LOAEL (50 mg/kg/day) used as the POD for the acute-duration MRL, the acute-duration oral MRL of 0.2 mg/kg/day is expected to be protective for intermediate-duration exposure scenarios and was adopted as the intermediate-duration oral MRL.

Summaries of the three comprehensive studies of intermediate-duration exposure are provided below as support for the adopting the acute-duration oral MRL for intermediate durations:

1 NTP. 1980b. Subchronic toxicity study: Naphthalene (C52904), Fischer 344 rats. Research Triangle Park, NC: U.S. Department of Health and Human Services, National Toxicology Program.

Naphthalene (>99% pure) in corn oil was administered by gavage to groups of 10 male and 10 female Fischer 344 rats at dose levels of 0, 25, 50, 100, 200, or 400 mg/kg/day, 5 days/week for 13 weeks (NTP 1980b). Endpoints included weekly measurement of food consumption and body weight, twice daily observation for clinical signs of toxicity, measurement of hematological parameters for blood collected at termination (hemoglobin, hematocrit, total and differential white blood cell count, red blood cell count, mean cell volume, mean cell hemoglobin concentration), necropsy of all rats in the study, and complete histopathological examination of 27 organs and tissues (including the eyes, lungs, stomach, liver, reproductive organs, thymus, and kidneys) from all control and 400 mg/kg/day rats. Male kidneys and female thymuses from the 200 mg/kg/day group were also examined histopathologically (according to the histopathology tables; however, the report text states that the 100 mg/kg group was examined). Organ weight data were not reported.

At the highest dose level, two male rats died during the last week of treatment, and rats of both sexes displayed diarrhea, lethargy, hunched posture, and rough coats at intermittent intervals throughout the study. Food consumption was not affected by exposure. Mean terminal body weights were decreased by more than 10% relative to the controls in several groups (28 and 12% decrease in the 400- and 200-mg/kg/day males, respectively and 23% decrease in 400-mg/kg females). The terminal body weights at 13 weeks of exposure were 250.6, 306.7, 333.4, 351.2, 353.4, and 348.9 g for males and 156.7, 190.5, 197.2, 203.5, 197.8, and 203.4 g for females for the 400, 200, 100, 50, 25, and 0 mg/kg/day dose groups, respectively. Differences between mean values of hematological parameters in exposed groups and those in control groups were <10% of control values, except for a 94% increase in numbers of mature neutrophils and a 25.1% decrease in numbers of lymphocytes in male 400 mg/kg rats and a 37.2% increase in mature neutrophils in 400 mg/kg females. Due to a lack of a consistent pattern of change in the hematologic parameters, the observed changes are not considered adverse. Histological examinations revealed low incidences of lesions in exposed male kidneys and exposed female thymuses; no lesions were observed in respective control kidneys or thymuses. Focal cortical lymphocytic infiltration or focal tubular regeneration were observed in kidneys in 2/10 male rats exposed to 200 mg/kg/day naphthalene, and diffuse renal tubular degeneration occurred in 1/10 male rats exposed to 400 mg/kg/day. Lymphoid depletion of the thymus occurred in 2/10 females exposed to 400 mg/kg/day, but not in any other females or in males. No other tissue lesions were detected. In this study, 100 mg/kg/day was a NOAEL, 200 mg/kg/day was a LOAEL, and 400 mg/kg/day was a serious LOAEL for decreased body weight in rats orally exposed to naphthalene for 13 weeks.

2 NTP. 1980a. Subchronic toxicity study: Naphthalene (C52904), B6C3F1 mice. Research Triangle Park, NC: U.S. Department of Health and Human Services, National Toxicology Program.

Ten male and 10 female B6C3F1 mice were administered gavage doses of naphthalene in corn oil at levels of 0, 12.5, 25, 50, 100, or 200 mg/kg/day, 5 days/week for 13 weeks (NTP 1980a). Seven mice (three males and two females of the 200 mg/kg/day group, one female of the 25 mg/kg/day group, and one control male) died during the second, third, and fourth weeks from gavage trauma or accident. Transient signs of toxicity (lethargy, rough hair coats, and decreased food consumption) occurred between weeks 3 and 5 in the 200 mg/kg/day groups. Due to their transient nature, these effects are not considered to be adverse. All exposed male mice gained more weight during the study than did control males (weight gains expressed as a percentage of control weight gain were 154.3, 116.0, 125.9, 122.2, and 107.4% for the 12.5–200 mg/kg/day groups, respectively). Exposed female mice displayed decreased weight gain compared with controls (weight gains expressed as a percentage of control weight gain were 97.5, 81.5, 81.5, 77.8, and 76.5% for the 12.5–200 mg/kg/day groups, respectively). The average change in body weight between day 0 and the 13^th^ week was 6.2 g/mouse for the 200 mg/kg/day female mice compared with 8.1 g/mouse for the control females. The study authors believed that a difference in weight gain of 1.9 g over a 13-week period “was not large enough to conclusively indicate a toxic effect.” Respective mean terminal body weights for control through the 200 mg/kg/day group were: 33.2, 37.7, 34.7, 34.7, 36.0, and 34.7 g for males, and 26.7, 26.8, 25.4, 26.0, 26.1, and 25.6 g for females. Mean terminal body weight values in exposed females were ≥95% of control values.

All mice were necropsied, and 27 organs (including the eyes, thymus, reproductive organs, and lungs) from the mice in the control and high-dose groups were examined histologically. No exposure-related lesions were observed in any organs. The highest incidence of lesions observed was for minimal to mild, focal or multifocal, subacute pneumonia in both controls (4/10 males and 2/10 females) and high-dose mice (4/10 males and 5/10 females). Organ weight data were not reported. Hematological analyses were performed on all groups. Exposed groups displayed mean values that were within 10% of the control means for the following parameters: hemoglobin, hematocrit, total white blood cells, and total red blood cells. An increase in lymphocytes (18% increase) and a decrease in segmented neutrophils (38.8% decrease) in high-dose males were not considered biologically significant by the study authors. The highest dose in this study, 200 mg/kg/day, is judged to be a NOAEL for nonneoplastic lesions, hematologic changes, and adverse neurologic symptoms.

3 Shopp GM, White KL JR, Holsapple MP, . 1984. Naphthalene toxicity in CD-1 mice: General toxicology and immunotoxicology. Fundam Appl Toxicol 4:406–419.6745531

Groups of male and female albino CD-1 mice (approximately 6 weeks old at the start) were administered gavage doses of 0, 5.3, 53, or 133 mg/kg naphthalene (99.3% pure) in corn oil for 90 consecutive days (Shopp et al. 1984). A naive control group and the 5.3 and 53 mg/kg/day dose groups each contained 76 male mice and 40 female mice. The vehicle control group contained 112 male mice and 76 female mice. The high-dose group contained 96 male mice and 60 female mice. Statistical analysis consisted of a one-way analysis of variance of means and Dunnett’s t-test to compare control and treatment means using a significance level of p<0.05. Statistically significant chemical-related decreases in terminal body weights or survival were not observed in either sex. Respective mean terminal body weight values were (naïve, vehicle, 5.3, 53, and 133 mg/kg/day groups): 39.3, 37.3, 37.2, 36.2, and 36.8 g for male mice and 29.2, 29.0, 27.9, 27.0, and 27.1 g for female mice. No significant alterations in absolute or relative organ weights occurred in exposed male mice. Significant decreases in absolute weights of brain (9%), liver (18%), and spleen (28%) and relative weight of spleen (24%) occurred in high-dose females compared with controls. Histopathological examination of organs was not conducted, but the study authors noted that cataracts were not formed in exposed mice (methods used to assess the presence of cataracts were not specified).

Examination of hematological parameters (including numbers of leucocytes, erythrocytes, and platelets and determination of hematocrit and hemoglobin) at termination revealed only slight, but statistically significant, increases in hemoglobin in high-dose females only; however, the hematological data were not shown in the available report. Chemical analysis of serum showed statistically significant decreased BUN in all exposed female groups. Compared with vehicle controls, the percent decreases in BUN were 16, 20, and 34% for the 5.3, 53, and 133 mg/kg/day groups, respectively. Increased serum globulin (about 55%) and protein (about 40%) occurred in the two highest female dose groups compared with vehicle control values. Hepatic microsomal activities of aniline hydroxylase and aminopyrine N-demethylases were not statistically significantly changed in exposed versus control mice, but benzo[a]pyrene hydroxylase activities were statistically significantly decreased in exposed groups compared with control values (0.8, 0.62*, 0.55* and 0.41* nmol/minute/mg protein for males in the control through high-dose group, and 1.40, 1.24, 1.13*, and 0.89* nmol/minute/mg protein for females; statistically significant differences from control noted with *). The toxicological significance of the statistically significant changes in hematological parameters, hepatic enzyme activities, and serum chemical parameters is not clear, and these changes are not considered to be adverse.

No exposure-related responses were found in a battery of immunological assays (humoral immune response, lymphocyte responsiveness, delayed-type hypersensitivity response, popliteal lymph node response, and bone marrow function); immunotoxic responses were observed in positive controls given i.p. injections of 50 mg/kg cyclophosphamide on days 87, 88, 89, and 90. The study identified a LOAEL of 133 mg/kg/day and a NOAEL of 53 mg/kg/day for statistically significant decreases in absolute weight of brain, liver, and spleen and relative weight of spleen in female mice, but not male mice. The effects were only observed in female mice, and histological changes in these organs were not observed in Fischer 344 rats (NTP 1980b) or B6C3F1 mice (NTP 1980a) exposed to naphthalene for 13 weeks.

Agency Contacts (Chemical Managers): Gaston Casillas, Ph.D.

## Naphthalene Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Naphthalene
CAS Numbers: | 91-20-3
Date: | March 2025
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: Chronic-duration toxicity studies of oral exposure to naphthalene were not located, precluding derivation of a chronic-duration oral MRL.

Rationale for Not Deriving an MRL: Chronic-duration toxicity studies of oral exposure to naphthalene were not located.

Agency Contacts (Chemical Managers): Gaston Casillas, Ph.D.

## 1-Methylnaphthalene Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1-Methylnaphthalene
CAS Numbers: | 90-12-0
Date: | March 2025
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: The available data are not sufficient for derivation of an acute-duration inhalation MRL for 1-methylnaphthalene.

Rationale for Not Deriving an MRL: The database of acute-duration inhalation toxicity studies of 1-methylnaphthalene is limited, consisting of only two animal studies (Korsak et al. 1998; Świercz and Stępnik 2020). Korsak et al. (1998) evaluated neurological endpoints of pain sensitivity (hotplate) and rotarod performance in rats following a single 4-hour exposure to 0, 26, 44, or 70 ppm. No other endpoints were assessed. The other study (Świercz and Stępnik 2020) was focused on assessment of serum corticosterone levels. Rats were exposed to concentrations of 0, 9.54, and 38.15 ppm 1-methylnaphthalene on 6 hours/day for 5 days and endpoints were limited to body weights, food and water consumption, and serum corticosterone levels. The limited endpoints evaluated in these studies do not provide enough information on the toxicity of 1-methylnaphthalene after acute-duration inhalation exposure. Thus, an acute-duration inhalation MRL was not derived.

Agency Contacts (Chemical Managers): Gaston Casillas, Ph.D.

## 1-Methylnaphthalene Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1-Methylnaphthalene
CAS Numbers: | 90-12-0
Date: | March 2025
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate
MRL: | 9×10^−5^ ppm (5×10^−4^ mg/m^3^)
Critical Effect: | Nasal mucous cell hyperplasia
Reference: | Kim et al. 2020
Point of Departure: | BMCL of 0.06 ppm; (BMCL_HEC_ of 0.0027 ppm)
Uncertainty Factor: | 30
LSE Graph Key: | 4
Species: | Rat

MRL Summary: An intermediate-duration inhalation MRL of 9×10^−5^ ppm was derived for 1-methylnaphthalene based on mucous cell hyperplasia in male F344 rats following exposure for 6 hours/day, 5 days/week for 13 weeks (Kim et al. 2020). The MRL is based on a BMCL_10_ of 0.06 ppm, which was adjusted for continuous duration exposure and converted to a BMCL_HEC_ of 0.0027 ppm. The BMCL_HEC_ was divided by a total uncertainty factor of 30 (10 for human variability and 3 for animal to human extrapolation after applying dosimetric adjustment).

Selection of the Critical Effect: The database of intermediate-duration inhalation toxicity studies for 1-methylnaphthalene is limited to a single 13-week study in male and female F344 rats (Kim et al. 2020). The effects observed at the lowest exposure concentrations in male (0.5 ppm) and female (4 ppm) rats include effects on the respiratory tract (nasal lesions).

Selection of the Principal Study: Only one intermediate-duration inhalation study of 1-methylnaphthalene was located (Kim et al. 2020). In this study, male and female F344 rats were exposed by inhalation for 13 weeks and comprehensive toxicological endpoints were evaluated. This study was selected as the primary study for derivation of an intermediate-duration inhalation MRL.

Summary of the Principal Study:

Kim YS, Lee MJ, Seo DS, . 2020. Thirteen-week inhalation toxicity study of 1-methylnaphthalene in F344 rats. Toxicol Res 36:13–20.32042710

Kim et al. (2020) evaluated intermediate-duration toxicity of inhaled 1-methylnaphthalene. Groups of F344 rats (10/sex/group) were exposed, whole body, to 1-methylnaphthalene (purity 97.3%) vapor at concentrations of 0, 0.52, 4.08, or 30.83 ppm (analytical) for 6 hours/day, 5 days/week, for 13 weeks. Mortality and clinical signs were recorded daily during the exposure period and body weights were measured twice a week for 4 weeks and weekly thereafter. Food consumption was measured with unknown frequency. After the exposure period, rats were sacrificed, and blood was collected for analysis of hematological parameters (including differential white blood counts and clotting parameters) and serum chemistry. Bronchoalveolar lavage (BAL) fluid was collected from 5/sex/group and examined for differential cell counts and LDH. Rats then underwent necropsy followed by excision of organs for organ weights (adrenal glands, brain, heart, kidneys, liver, spleen, testes, thymus, epididymides, lungs, ovaries, and uterus) and comprehensive histopathology including gonads, lungs, and nasopharyngeal tissue.

Histological analysis was performed on fixed tissues from the control and high-exposure animals only, except for nasopharyngeal tissue, which was examined from animals from all exposure groups.

No mortality occurred, and no clinical signs of toxicity were observed. Body weights were comparable to controls throughout the study. No statistically significant changes were found in differential cell counts or LDH in BAL. At 30.83 ppm, activated partial thromboplastin time (APTT) and prothrombin time (PT) were significantly increased in males by 8 and 10%, respectively, and PT was significantly increased in females by 8%. Serum chemistry changes included significantly increased albumin (4%) and sodium (1%) in males at 30 ppm. No significant changes in organ weights were observed. Histopathological changes in nasopharyngeal tissue of both sexes included mucous cell hyperplasia; males also exhibited transitional epithelial cell hyperplasia. Table A-6 shows the incidences and severities of these changes. No other treatment-related histopathology changes were noted.

Table A-6 Incidence of Nasal Lesions in Rats Exposed to 1-Methylnaphthalene via Inhalation for 13 Weeks

Nasal lesion | Exposure concentration (ppm)
Nasal lesion | 0 | 0.52 | 4.08 | 30.83
Males
Mucous cell hyperplasia, minimal | 0/10 | 4/10 | 4/10 | 0/10
Mucous cell hyperplasia, mild | 0/10 | 0/10 | 6/10 | 0/10
Mucous cell hyperplasia, moderate | 0/10 | 0/10 | 0/10 | 10/10
Mucous cell hyperplasia (total) | 0/10 | 4/10 | 10/10 | 10/10
Transitional epithelial cell hyperplasia, mild | 0/10 | 0/10 | 5/10 | 5/10
Females
Mucous cell hyperplasia, minimal | 0/10 | 0/10 | 3/10 | 2/10
Mucous cell hyperplasia, mild | 0/10 | 0/10 | 0/10 | 6/10
Mucous cell hyperplasia, moderate | 0/10 | 0/10 | 0/10 | 2/10
Mucous cell hyperplasia (total) | 0/10 | 0/10 | 3/10 | 10/10

Bold indicates dataset selected for benchmark dose modeling.

Source: Kim et al. 2020

Selection of the Point of Departure for the MRL: BMD modeling was conducted to identify a POD using the data for mucous cell hyperplasia (all severity levels) in male rats administered 1-methylnaphthalene via inhalation for 6 hours/day, 5 days/week for 13 weeks. The data modeled are shown in bold in Table A-6. Male rat incidence data were selected because the males exhibited effects at the lowest concentration, while females did not. The data were fit to all available dichotomous models in EPA’s BMDS (version 3.2) using a BMR of 10% extra risk. Adequate model fit was judged by four criteria: goodness-of-fit statistics (p-value >0.1), visual inspection of the dose-response curve, a 95% confidence limit on the BMC (BMCL) that is not 10 times lower than the lowest non-zero dose, and scaled residual within ±2 units at the data point (except the control) closest to the predefined BMR. Among all of the models providing adequate fit to the data, the lowest BMCL was selected as the POD when the difference between the BMCLs estimated from these models was >3-fold; otherwise, the BMCL from the model with the lowest AIC was chosen. BMDS recommended the frequentist dichotomous Hill model for mucous cell hyperplasia, and after verifying the model fit by the four criteria listed above, this model was selected as the basis for estimating this MRL. The model predictions are presented in Table A-7 and the fit of the selected model is presented in Figure A-2.

Table A-7 Model Predictions for Increased Incidence of Nasal Mucous Cell Hyperplasia in Male Rats Exposed to 1-Methylnaphthalene via Inhalation (Kim et al. 2020)

Model | BMC_10_^a^ (ppm) | BMCL_10_^a^ (ppm) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMC_10_^a^ (ppm) | BMCL_10_^a^ (ppm) | p-Value^b^ | AIC | Dose below BMC | Dose above BMC
Dichotomous Hill ^d^ | 0.35 | 0.06 | 0.9993 | 17.46 | −0.0004 | −0.0005
Gamma^e^ | | | 1.0000 | 17.46 | −0.0007 | −0.0007
Log-Logistic^f^ | 0.35 | 0.06 | 0.9993 | 17.46 | −0.0004 | −0.0004
Multistage Degree 3^g^ | | | 0.9969 | 19.46 | −0.0004 | −0.0004
Multistage Degree 2^g^ | | | 1.0000 | 17.46 | −0.0004 | −0.0004
Multistage Degree 1^g^ | | | 0.9825 | 15.74 | −0.0004 | −0.0004
Weibull^e^ | | | 0.9967 | 17.47 | −0.0004 | −0.0004
Logistic | 0.27 | 0.15 | 0.7612 | 17.41 | −0.9332 | 0.5430
Log-Probit | | | 1.0000 | 17.46 | −0.0004 | −4.5×10^−10^
Probit | 0.46 | 0.30 | 0.2916 | 21.68 | −1.5295 | 0.83

a BMC and BMCLs values for models that do not provide adequate fit or yield BMCLs more than 10-fold lower than the lowest nonzero exposure concentration are not included in this table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the BMC.

d All models provided an adequate fit to the data. BMCLs were not sufficiently close (differed by >3-fold). Therefore, the model with the lowest BMCL was selected (Dichotomous Hill).

e Power restricted to ≥1.

f Slope restricted to ≥1.

g Betas restricted to ≥0.

AIC = Akaike Information Criterion; BMC = benchmark concentration (maximum likelihood estimate of the concentration associated with the selected benchmark response); BMCL_10_ = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., 10 = dose associated with 10% extra risk)

Figure A-2 Fit of the Dichotomous Hill Model to Data for 1-Methylnaphthalene, Mucous Cell Hyperplasia in Male Rats (Kim et al. 2020)

Calculations

Adjustment for Intermittent Exposure: The animals in the study by Kim et al. (2020) were exposed 6 hours/day, 5 days/week. Therefore, the BMCL of 0.06 ppm was adjusted for intermittent exposure as follows:

B M C L_A D J_ = B M C L × (6 h o u r s)/(24 h o u r s) × (5 d a y s)/(7 d a y s) = 0.06 p p m × (6 h o u r s)/(24 h o u r s) × (5 d a y s)/(7 d a y s) = 0.011 p p m

Human Equivalent Concentration: The critical effects of 1-methylnaphthalene were nasal lesions, therefore, the BMCL_10ADJ_ was converted to a HEC by multiplying the BMCL_10_ by the rat-specific regional gas dose ratio that corresponds with the extrathoracic region (RGDR_ET_). This RGDR_ET_ is calculated using the following equation as defined by EPA (1994):

R G D R_E T_ = (V_E_a__)/(S A_a_) ÷ (V_E_h__)/(S A_h_) = (0.254)/(15) ÷ (13.8)/(200) = 0.25

where:

- V_E_a__ = ventilation rate for male F344 rats = 0.254 L/minute (EPA 2012)
- SA_a_ = surface area of the extrathoracic region in rats = 15 cm^2^ (EPA 1994)
- V_E_h__ = ventilation rate for humans = 13.8 L/minute (EPA 1994)
- SA_h_ = surface area of the extrathoracic region in humans = 200 cm^2^ (EPA 1994)

Applying this equation results in an RGDR of 0.25 for extrathoracic effects in rats, and the HEC is calculated as:

B M C L_10 H E C_ = B M C L_10 A D J_ × R G D R = 0.011 p p m × 0.25 = 0.0027 p p m

Uncertainty Factor: The BMCL_HEC_ of 0.0027 ppm is divided by a total UF of 30:

- 10 for human variability
- 3 for animal to human extrapolation after dosimetric adjustment

MRL = BMCL_HEC_ ÷ UFs MRL = 0.0027 ppm ÷ ( 3 × 10 ) = 0.00009 ppm ( 9 × 10^− 5^ ppm )

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Significantly increased incidences of pulmonary alveolar proteinosis were observed in mice exposed chronically by dietary administration (Murata et al. 1993). In addition, the association between 1-methylnaphthalene exposure and respiratory effects is supported by findings of pulmonary alveolar proteinosis in mice exposed to the structurally related compound 2-methylnaphthalene in the diet (Murata et al. 1997) and in mice exposed by dermal application to a mixture of methylnaphthalenes (Emi and Konishi 1985; Murata et al. 1992).

The odor threshold for 1-methylnaphthalene in air is 0.12 mg/m^3^ or 0.02 ppm (see Section 4.2).

Agency Contacts (Chemical Managers): Gaston Casillas, Ph.D.

## 1-Methylnaphthalene Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1-Methylnaphthalene
CAS Numbers: | 90-12-0
Date: | March 2025
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: Chronic-duration toxicity studies of inhaled 1-methylnaphthalene were not located, precluding derivation of a chronic-duration inhalation MRL.

Rationale for Not Deriving an MRL: Chronic-duration toxicity studies of inhaled 1-methylnaphthalene were not located.

Agency Contacts (Chemical Managers): Gaston Casillas, Ph.D.

## 1-Methylnaphthalene Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1-Methylnaphthalene
CAS Numbers: | 90-12-0
Date: | March 2025
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: Acute-duration oral toxicity studies of 1-methylnaphthalene were not located, precluding derivation of an acute-duration oral MRL.

Rationale for Not Deriving an MRL: Acute-duration toxicity studies of orally-administered 1-methylnaphthalene were not located.

Agency Contacts (Chemical Managers): Gaston Casillas, Ph.D.

## 1-Methylnaphthalene Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1-Methylnaphthalene
CAS Numbers: | 90-12-0
Date: | March 2025
Profile Status: | Final
Route: | Oral
Duration: | Intermediate
MRL | 0.6 mg/kg/day
Critical Effect: | Increased liver weight
Reference: | NITE 2009
Point of Departure: | BMDL_1SD_ of 64 mg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 1
Species: | Rat

MRL Summary: An intermediate-duration oral MRL of 0.6 mg/kg/day was derived for 1-methylnaphthalene based on a BMDL_1SD_ of 64 mg/kg/day for increased relative liver weights in male Sprague-Dawley rats (NITE 2009). An uncertainty factor of 100 (10 for human variability and 10 for extrapolation from animals to humans) was applied to the BMDL_1SD._

Selection of the Critical Effect: There is one study that evaluated intermediate-duration oral exposure to 1-methylnaphthalene (NITE 2009). NITE (2009) was a combined repeat-dose and reproductive/developmental screening study in rats that followed OECD 422 guidelines. Treatment-related effects observed in the study consisted of increased absolute and relative liver weights and increased relative kidney weights in males, and increased relative liver weights in females, all occurring at the highest dose (250 mg/kg/day). Liver effects were selected as the critical effect because liver weights were affected in both sexes, both absolute and relative liver weights were affected in males, and the magnitude of liver weight change was larger than the magnitude of kidney weight change.

Selection of the Principal Study: NITE 2009 is the only available intermediate-duration oral exposure study. This study evaluated a comprehensive set of endpoints and identified both NOAEL and LOAEL values, so it was selected as the principal study.

Summary of the Principal Study:

NITE. 2009. 1-Methylnaphthalene summary: [Combined repeat dose and reproductive/developmental toxicity screening test of 1-methylnaphthalene by oral administration in rats]. Japanese National Institute of Technology and Evaluation. https://www.nite.go.jp/chem/jcheck/tempfile_list.action?tpk=23402&ppk=7239&kinou=100&type=ja. (Japanese)

In a combined repeated dose reproduction/developmental toxicity screening study, groups of Sprague-Dawley rats (12/sex/group) were housed as breeding pairs and administered 1-methylnaphthalene via gavage in olive oil at doses of 0, 10, 50, 250 mg/kg/day for approximately 42 days. Animals were administered the test substance starting during premating (14 days), throughout mating, and gestation until lactation day (LD) 4 in females and from premating through sacrifice (42 days) in males. A group of five per sex in the control and high dose groups were included in a 14-day untreated recovery period. An additional satellite group of five unmated females were treated with the control and high dose groups.

During treatment, rats were observed for mortality and clinical signs of toxicity twice daily. Neurobehavioral observations were evaluated weekly including open field test (rises, clonic and tonic involuntary movements, pace, mobility, wakefulness, behavior, defecations, and urinations) and FOB tests were performed on 5/sex/group during the last week of treatment. Body weights and food consumption were evaluated throughout the study (unknown intervals). At sacrifice, endpoints evaluated included hematology, clinical chemistry (including globulin differentiation), urinalysis (control and high dose only), gross necropsy, organ weights, and histopathology. Reproductive (fertility index, estrous length, days to copulation, conception rate, numbers pregnant, corpora lutea, implantation index, gestation period, pre- and post-implantation loss, delivery and birth indices, and nursing status) and developmental endpoints (pup survival rate at birth, sex ratio, pup body weight, and number of live/dead pups on postnatal days [PNDs] 0 and 4, and examination of pups at sacrifice on PND 4 for external abnormalities) were evaluated.

No treatment-related adverse effects were observed on mortality, clinical signs of toxicity, body weights, food consumption, hematology, urinalysis, reproduction, or development. There were no significant differences between treated and control groups in the behavioral observations in the open field or FOB. Organ weight changes were observed at the highest dose, as shown in Table A-8. Males in the 250 mg/kg/day group had increases in absolute and relative liver weights and relative kidney weights at the end of exposure. Females of the 250 mg/kg/day group had increased relative liver weights, but no change in absolute liver weights. Histopathology evaluations did not show any treatment-related changes.

Table A-8 Significant Organ Weight Changes in Rats Exposed to 1-Methylnaphthalene via Gavage for 42 Days

Nasal lesion | Dose (mg/kg/day)
Nasal lesion | 0 | 10 | 50 | 250
Males
Relative liver weight (g%) | 2.628±0.233 | 2.678±0.223 (+2%) | 2.685±0.17 (+2%) | 3.309±0.416 (+26%) ^a^
Absolute liver weight (g) | 12.94±1.905 | 12.895±1.604 (−0%) | 13.043±1.272 (+1%) | 15.159±1.934 (+17%)^a^
Relative kidney weight (g%) | 0.593±0.057 | 0.626±0.053 (+6%) | 0.62±0.053 (+5%) | 0.683±0.06 (+15%)^a^
Mated females
Relative liver weight (g%) | 3.193±0.227 | 3.148±0.275 (−1%) | 3.188±0.169 (−0%) | 3.521±0.373 (+10%) ^a^
Unmated females
Relative liver weight (g%) | 2.368±0.138 | Not tested | Not tested | 2.663±0.106 (+12%)^a^

a Significantly different from control at p<0.05 by Student’s t-test or Dunnett’s test performed by the study authors.

Bold indicates datasets selected for benchmark dose modeling.

Source: NITE 2009

Selection of the Point of Departure for the MRL: BMD modeling was conducted to identify a POD using the data for relative liver weight in male and female rats given 1-methylnaphthalene by gavage in a repeated dose toxicity and reproduction/developmental study. BMD modeling of continuous data (relative liver weight) was conducted with the EPA’s BMDS (version 3.2.0.1). For these data, the Exponential, Hill, Linear, Polynomial, and Power continuous models available within the software were fit employing a BMR of 1 SD. An adequate fit was judged based on the χ2 goodness-of-fit p-value (p>0.1), magnitude of the scaled residuals in the vicinity of the BMR, and visual inspection of the model fit. In addition to these three criteria for judging adequacy of model fit, a determination was made as to whether the variance across dose groups was constant. If a constant variance model was deemed appropriate based on the statistical test provided in BMDS (i.e., Test 2; p-value >0.1), the final BMD results were estimated from a constant variance model. If the test for homogeneity of variance was rejected (p-value <0.1), the model was run again while modeling the variance as a power function of the mean to account for this nonconstant variance. If this nonconstant variance model did not adequately fit the data (i.e., Test 3; p-value <0.1), the data set was considered unsuitable for BMD modeling. Among all models providing adequate fit, the lowest BMDL was selected if the BMDLs estimated from different models varied >3-fold; otherwise, the BMDL from the model with the lowest AIC was selected.

For both the male and female rat relative liver weight data, the constant variance model did not provide an adequate fit to the data (Test 2; p-value < 0.1); however, the nonconstant variance model did provide an adequate fit. With the nonconstant variance model applied, all models except for the Exponential 5 and Hill models provided adequate fit to the means for both datasets. For both datasets, the BMDLs were sufficiently close (<3-fold); therefore, the model with the lowest AIC was selected: this was the Polynomial 3-degree model for both datasets. Predicted BMD_1SD_ and BMDL_1SD_ values for male rat relative liver weight data were 166 and 64 mg/kg/day, respectively. Predicted BMD_1SD_ and BMDL_1SD_ values for female rat relative liver weight data were 212 and 109 mg/kg/day, respectively. The BMD/BMDL values considered for MRL derivation are presented in Tables A-9 and A-10 (males and females, respectively) and the fits of the selected models are presented in Figures A-3 and A-4 (males and females, respectively). The BMDL_1SD_ of 64 mg/kg/day from modeling of the male rat data was lower than the BMDL_1SD_ for females and was selected as the POD for MRL derivation.

Table A-9 Results from Benchmark Dose (BMD) Analysis (Nonconstant Variance) of Increased Relative Liver Weight in Male Rats Following Oral Exposure to 1-Methylnaphthalene (NITE 2009)

Model | BMD_1SD_^a^ (mg/kg/day) | BMDL_1SD_^a^ (mg/kg/day) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMD_1SD_^a^ (mg/kg/day) | BMDL_1SD_^a^ (mg/kg/day) | p-Value^b^ | AIC | Dose below BMD | Dose above BMD
Exponential (model 2)^d^ | 80.41 | 56.62 | 0.35 | 3.69 | −0.8605 | 0.2692
Exponential (model 3)^d^ | 188.61 | 65.54 | 0.62 | 3.85 | 0.2628 | −0.0030
Exponential (model 4)^d^ | 75.67 | 75.31 | 0.29 | 4.05 | −0.9530 | 0.3611
Exponential (model 5)^d^ | | | NA | 5.85 | 0.2542 | −0.0012
Hill^d^ | | | NA | 5.85 | 0.2520 | −0.0013
Polynomial (3-degree) ^d^ ^,^ ^e^ | 165.80 | 63.73 | 0.89 | 1.85 | 0.1818 | −0.0194
Polynomial (2-degree)^d^ | 137.23 | 62.66 | 0.84 | 1.94 | 0.0009 | 0.0012
Power^d^ | 178.39 | 63.63 | 0.62 | 3.85 | 0.2494 | −0.0036
Linear | 75.67 | 51.57 | 0.29 | 4.05 | −0.9530 | 0.3615

a BMD and BMDL values for models that do not provide adequate fit or yield BMDLs more than 10-fold lower than the lowest nonzero dose are not included in this table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the BMD.

d Restricted model.

e Recommended model (lowest AIC). The constant variance model did not provide an adequate fit to the data (Test 2; p-value < 0.1); however, the nonconstant variance model did provide an adequate fit. With the nonconstant variance model applied, all models except for the Exponential 5 and Hill models, provided adequate fit to the means. Of these models, the BMDLs were sufficiently close (<3-fold); therefore, the model with the lowest AIC was selected (Polynomial 3-degree model).

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _1SD_ = exposure dose associated with a change of 1 standard deviation from the control)

Figure A-3 Fit of the 3-Degree Polynomial Model (Nonconstant Variance) to Data for 1-Methylnaphthalene, Relative Liver Weight in Male Rats (NITE 2009)

Table A-10 Results from Benchmark Dose (BMD) Analysis (Nonconstant Variance) of Increased Relative Liver Weight in Female Rats Following Oral Exposure to 1-Methylnaphthalene (NITE 2009)

Model | BMD_1SD_^a^ (mg/kg/day) | BMDL_1SD_^a^ (mg/kg/day) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMD_1SD_^a^ (mg/kg/day) | BMDL_1SD_^a^ (mg/kg/day) | p-Value^b^ | AIC | Dose below BMD | Dose above BMD
Exponential (model 2)^d^ | 152.66 | 124.78 | 0.45 | 9.18 | −0.51 | 0.16
Exponential (model 3)^d^ | 235.64 | 109.65 | 0.68 | 9.74 | 0.14 | −2.6×10^−5^
Exponential (model 4)^d^ | 150.40 | 92.52 | 0.19 | 11.28 | −0.54 | 0.19
Exponential (model 5)^d^ | | | NA | 11.74 | 0.14 | 0.0008
Hill^d^ | | | NA | 11.74 | 0.14 | −0.001
Polynomial (3-degree) ^d^ ^,^ ^e^ | 212.35 | 108.64 | 0.98 | 5.78 | 0.11 | −0.001
Polynomial (2-degree)^d^ | 194.57 | 105.04 | 0.84 | 7.93 | 0.00 | 0.007
Power^d^ | 245.04 | 107.35 | 0.68 | 9.74 | 0.14 | −0.002
Linear | 150.34 | 92.29 | 0.43 | 9.27 | −0.54 | 0.18

a BMD and BMDL values for models that do not provide adequate fit or yield BMDLs more than 10-fold lower than the lowest nonzero dose are not included in this table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the BMD.

d Restricted model.

e Recommended model (lowest AIC). The constant variance model did not provide an adequate fit to the data (Test 2; p-value < 0.1); however, the nonconstant variance model did provide an adequate fit. With the nonconstant variance model applied, all models except for the Exponential 5 and Hill models, provided adequate fit to the means. Of these models, the BMDLs were sufficiently close (<3-fold); therefore, the model with the lowest AIC was selected (Polynomial 3-degree model).

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _1SD_ = exposure dose associated with a change of 1 standard deviation from the control)

Figure A-4 Fit of the 3-Degree Polynomial Model (Nonconstant Variance) to Data for 1-Methylnaphthalene, Relative Liver Weight in Female Rats (NITE 2009)

Calculations

Adjustment for Intermittent Exposure: Not applicable.

Uncertainty Factor: The BMDL_1SD_ of 64 mg/kg/day was divided by a composite UF of 100:

- 10 for human variability
- 10 for animal to human extrapolation

This results in the following MRL:

M R L = (B M D L)/(U F) = (64)/(100) ≈ 0.6 mg / kg / day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: No liver effects were reported in the chronic-duration dietary study of 1-methylnaphthalene (Murata et al. 1993), but the estimated doses were lower, and there is uncertainty in the dose estimates for Murata et al. (1993) due to potential for volatilization of the test material from the diet. The association between 1-methylnaphthalene exposure and adverse liver effects is supported by observations of liver changes (increased liver weights and serum enzyme levels, and/or histopathology changes) in animals exposed to the structurally related compounds, 2-methylnaphthalene (Świercz et al. 2011) and naphthalene (Chen et al. 2012; Katsnelson et al. 2014; Zhang et al. 2016).

Agency Contacts (Chemical Managers): Gaston Casillas, Ph.D.

## 1-Methylnaphthalene Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 1-Methylnaphthalene
CAS Numbers: | 90-12-0
Date: | March 2025
Profile Status: | Final
Route: | Oral
Duration: | Chronic
MRL: | 0.07 mg/kg/day
Critical Effect: | Increased pulmonary alveolar proteinosis
Reference: | Murata et al. 1993
Point of Departure: | LOAEL of 71.6
Uncertainty Factor: | 1,000
LSE Graph Key: | 2
Species: | Mice

MRL Summary: A chronic-duration oral MRL of 0.07 mg/kg/day was derived for 1-methylnaphthalene based on a LOAEL of 71.6 mg/kg/day for increased incidences of pulmonary alveolar proteinosis in male and female mice administered 1-methylnaphthalene in the diet for 81 weeks (Murata et al. 1993). The LOAEL was divided by a total uncertainty factor of 1,000 (10 for use of a LOAEL, 10 for extrapolation from animals to humans, and 10 for human variability).

Selection of the Critical Effect: There is one chronic-duration study that evaluated the effects of 1-methylnaphthalene (Murata et al. 1993). The only noncancer effect observed was pulmonary alveolar proteinosis at both doses and in both sexes.

Selection of the Principal Study: The only study of chronic-duration oral exposure to 1-methylnaphthalene was the 81-week dietary study by Murata et al. (1993). This study evaluated a comprehensive list of endpoints and was selected as the principal study.

Summary of the Principal Study:

Murata Y, Denda A, Maruyama H, . 1993. Chronic toxicity and carcinogenicity studies of 1-methylnaphthalene in B6C3F1 mice. Fundam Appl Toxicol 21:44–51.8365584

Groups of B6C3F1 mice (50/sex/group) were fed a diet of 0, 0.075, or 0.15% 1-methylnaphthalene (>97% purity) for 81 weeks. Doses consumed were estimated to be 0, 71.6, and 140.2 mg/kg/day in males and 0, 75.1 and 143.7 mg/kg/day in females. Mortality and clinical observations were performed daily. Body weights were measured weekly for 16 weeks and biweekly, thereafter. Food consumption was monitored at unknown intervals. After the treatment period, animals were sacrificed, and blood was collected for hematology and serum chemistry. Animals underwent gross necropsy and selected organs were weighed (brain, salivary glands, heart, thymus, lungs, liver, pancreas, spleen, kidneys, and testes) and evaluated histologically (brain, salivary glands, heart, thymus, lungs, liver, pancreas, spleen, kidneys, testes, adrenals, trachea, stomach, small intestine, large intestine, seminal vesicles, ovaries, uterus, vagina, mammary glands, skeletal muscle, eyes, Harderian glands, spinal cord, bone (sternal, rib, vertebral), skin, and gross lesions).

There were no treatment-related mortalities. No effects were observed on clinical signs, body weights, body weight gain, or food consumption. Increased monocytes were noted in treated groups of both sexes; no other treatment-related changes in hematology were observed. No treatment-related changes were noted in serum chemistry or organ weights. Increased incidences of lung lesions characterized as pulmonary alveolar proteinosis were observed at both doses and in both sexes. This lesion was characterized by an accumulation of phospholipids in the alveolar lumens that appeared grossly as white protuberant nodules approximately 1–5 mm in diameter. The incidences of pulmonary alveolar proteinosis in controls, low-dose, and high-dose groups were 4/49, 23/50, and 19/50 in males and 5/50, 23/50, and 17/49 in females, respectively (see Table A-11). In addition to the nonneoplastic lesions, increased incidences of lung tumors were observed in males (but not females) at both doses. No other treatment-related increased incidences of tumors were observed.

Table A-11 Incidences^a^ of Pulmonary Alveolar Proteinosis in Mice Exposed to 1-Methylnaphthalene in the Diet for 81 Weeks

| Dose in mg/kg/day
| 0 | 71.6 | 140.2
Males | 4/49 (8.2%) | 23/50 (46%) | 19/50 (38%)
Females | 5/50 (10%) | 23/50 (46%) | 17/39 (34.7%)

a Number affected/number examined (percent).

Source: Murata et al. 1993

Selection of the Point of Departure for the MRL: The lowest exposure level (71.6 mg/kg/day) was a LOAEL for increased incidence of pulmonary alveolar proteinosis in male and female mice. The incidences of this lesion in male and female mice (see Table A-11) were subjected to BMD modeling to determine a POD for the chronic-duration oral MRL. The data were fit to all available dichotomous models in EPA’s BMDS (version 3.2.0.1) using BMRs of 10% and 5% extra risk. Adequate model fit was judged by four criteria: goodness-of-fit statistics (p-value >0.1), visual inspection of the dose-response curve, a 95% confidence limit on the BMD (BMDL) that is not 10 times lower than the lowest non-zero dose, and scaled residual within ±2 units at the data point (except the control) closest to the predefined BMR. None of the models provided adequate fit for either the male or female data. Therefore, the LOAEL of 71.6 mg/kg/day was selected as the POD for the derivation of the chronic-duration oral MRL.

Calculations: Not applicable

Uncertainty Factor: The LOAEL of 71.6 mg/kg/day was divided by a total uncertainty factor of 1,000:

- 10 for use of a LOAEL
- 10 for extrapolation from animals to humans
- 10 for human variability

This results in the following MRL:

M R L = (L O A E L)/(U F) = (71.6)/(1,000) ≈ 0.07 (m g)/(k g) / d a y

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Increased incidences of pulmonary alveolar proteinosis have also been reported in B6C3F1 mice exposed to the related compound 2-methylnaphthalene in the diet for 81 weeks (Murata et al. 1997), and in mice dermally exposed to a mixture of 1- and 2-methylnaphthalene for 30–61 weeks (Emi and Konishi 1985; Murata et al. 1992).

Agency Contacts (Chemical Managers): Gaston Casillas, Ph.D.

## 2-Methylnaphthalene Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2-Methylnaphthalene
CAS Numbers: | 91-57-6
Date: | March 2025
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: Data are insufficient for derivation of an acute-duration inhalation MRL for 2-methylnaphthalene.

Rationale for Not Deriving an MRL: The only study that evaluated acute-duration toxicity for 2-methylnaphthalene was Korsak et al. (1998). In this study, male mice and rats were exposed to 2-methylnaphthalene for 4 hours for evaluation of neurological endpoints (pain sensitivity using hot plate test and rotarod performance). The limited endpoints evaluated in this study do not provide enough information on the toxicity of 2-methylnaphthalene after acute-duration inhalation exposure. Thus, an acute-duration inhalation MRL was not derived.

Agency Contacts (Chemical Managers): Gaston Casillas, Ph.D.

## 2-Methylnaphthalene Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2-Methylnaphthalene
CAS Numbers: | 91-57-6
Date: | March 2025
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate
MRL: | 3×10^−4^ ppm (0.002 mg/m^3^)
Critical Effect: | Bronchial goblet cell metaplasia
Reference: | Świercz et al. (2011)
Point of Departure: | LOAEL_HEC_ of 0.081 ppm
Uncertainty Factor: | 300
LSE Graph Key: | 5
Species: | Rat

MRL Summary: An intermediate-duration inhalation MRL of 3×10^−4^ ppm was derived for 2-methylnaphthalene based on the LOAEL_HEC_ of 0.081 ppm for increased incidences of respiratory bronchial goblet cell metaplasia in male and female rats exposed to 2-methylnaphthalene 6 hours/day, 5 days/week, for 4 weeks (Świercz et al. 2011). The LOAEL_HEC_ of 0.081 ppm was divided by a total uncertainty factor of 300 (10 for use of a LOAEL, 3 for extrapolation from animals to humans after dosimetric adjustment, and 10 for human variability).

Selection of the Critical Effect: There was only one intermediate-duration inhalation study of 2-methylnaphthalene (Świercz et al. 2011) but this study evaluated a comprehensive list of endpoints. Groups of Wistar rats were exposed to 2-methylnaphthalene for 6 hours/day, 5 days/week, for 4 weeks. The most sensitive effect was metaplasia of goblet cells in the primary and lobar bronchi. A LOAEL of 0.34 ppm was identified at the lowest exposure level and no NOAEL was identified.

Selection of the Principal Study: One study was available for intermediate-duration inhalation exposure to 2-methylnaphthalene (Świercz et al. 2011). This study evaluated a comprehensive list of endpoints and identified a LOAEL for respiratory effects (no NOAEL was identified). Therefore, Świercz et al. (2011) was selected as the study for derivation of the intermediate-duration inhalation MRL.

Summary of the Principal Study:

Świercz R, Wąsowicz W, Stetkiewicz J, . 2011. 4-Week inhalation toxicity of 2-methylnaphthalene in experimental animals. Int J Occup Med and Environ Health 24(4):399–408.22002322

Groups of Wistar rats (5/sex/group) were exposed whole body in dynamic chambers to 2-methylnaphthalene (97% purity) vapor at measured concentrations of 0, 2.0, 11.0, or 51.0 mg/m^3^ (corresponding 0, 0.34, 1.89, and 8.77 ppm) for 6 hours/day, 5 days/week for 4 weeks. Body weights and food consumption were measured weekly. Blood was collected for hematology (including clotting parameters) and clinical chemistry after the end of exposure. Animals were sacrificed and selected organs (lungs with larynx and trachea, liver, kidneys, heart, spleen, adrenals, testes, and ovaries) were collected, weighed, and prepared for histology.

Body weights and food consumption were comparable to controls in all exposure groups. Hematology findings in male rats suggested a trend toward increased reticulocyte counts, but no group was significantly different from the control. Female rats had significantly increased reticulocyte counts at 1.89 and 8.77 ppm. There were no other treatment-related effects on hematology in exposed males or females. In male rats, serum ALP was increased in a concentration-related manner in all exposure groups and serum GGT was increased at 8.77 ppm. In male rats, serum levels of albumin were decreased at 1.89 and 8.77 ppm. In female rats, serum levels of urea were increased at 8.77 ppm. Absolute and relative liver weights were reduced in male rats at all exposure concentrations. In female rats, reduced liver weights were observed at 8.77 ppm. In female rats, heart weights were reduced in a concentration-related manner and kidney weights were decreased at 1.89 and 8.77 ppm.

Histopathology changes related to treatment were observed in the respiratory tract and liver. Incidences of the effects are shown in Table A-12. Respiratory tract lesions included goblet cell metaplasia, hyperplasia of the peribronchial lymphatic tissue, and proteinosis with mononuclear cell infiltration. Increased incidences of goblet cells in the bronchi were observed in both sexes at all exposure levels. The study authors implied that all animals had goblet cells in the bronchi at 8.77 ppm but did not report actual incidences. Hyperplasia of the peribronchial lymphatic tissue was noted at all exposure levels in males and at ≥1.89 ppm in females. Mononuclear cell infiltration and proteinosis were reported in both sexes at ≥1.89 ppm. In the liver, bile duct hyperplasia was observed ≥1.89 ppm in both males and females (see Table A-12).

Table A-12 Incidence of Histopathology Changes in Rats Exposed to 2-Methylnaphthalene via Inhalation for 4 Weeks

Target tissue and lesion | Exposure concentration (ppm)
Target tissue and lesion | 0 | 0.34 | 1.89 | 8.77
Males
Bronchi-goblet cell metaplasia | 0/5 | 2/5 | 4/5 | Not reported
Bronchi-hyperplasia of peribronchial lymphatic tissue | 0/5 | 1/5 | 1/5 | 2/5
Bronchi-proteinosis | 0/5 | 0/5 | 3/5 | 3/5
Liver-bile duct hyperplasia | 0/5 | 0/5 | 2/5 | 5/5
Females
Bronchi-goblet cell metaplasia | 0/5 | 3/5 | 3/5 | Not reported
Bronchi-hyperplasia of peribronchial lymphatic tissue | 0/5 | 0/5 | 4/5 | 3/5
Bronchi-proteinosis | 0/5 | 0/5 | 4/5 | 3/5
Liver-bile duct hyperplasia | 0/5 | 0/5 | 3/5 | 5/5

Source: Świercz et al. 2011

Selection of the Point of Departure for the MRL: As shown in Table A-12, the lowest exposure level (0.34 ppm) was a LOAEL for increased incidences of goblet cell metaplasia in the primary and lobar bronchi in male and female rats. Because the publication did not report the incidences of this effect at the highest exposure level, BMD modeling was not possible for these data. Therefore, the LOAEL was selected as the POD for derivation of the intermediate-duration inhalation MRL.

Adjustment for Intermittent Exposure: The animals in the study by Świercz et al. (2011) were exposed at a frequency of 6 hours/day, 5 days/week. Therefore, the LOAEL of 0.34 ppm was adjusted for intermittent exposure as follows:

L O A E L_A D J_ = L O A E L × (6 h o u r s)/(24 h o u r s) × (5 d a y s)/(7 d a y s) = 0.061 p p m

Human Equivalent Concentration: The critical effect at the LOAEL (bronchus goblet cell metaplasia) was in the tracheobronchial portion of the respiratory tract. Therefore, the LOAEL_ADJ_ was converted to a LOAEL_HEC_ using guidance from EPA (1994) on dosimetric adjustments for tracheobronchial effects. The LOAEL_ADJ_ was converted to a LOAEL_HEC_ using the RGDR for tracheobronchial effects (EPA 1994) calculated as follows:

R G D R_T B_ = (( D o s e_T B_ )_a_)/(( D o s e_T B_ )_h_) = (( (V_E_)/(S A_t b_) )_a_)/(( (V_E_)/(S A_t b_) )_h_) (( e (− S A_e t_)/(V_E_) )_a_)/(( e (− S A_e t_)/(V_E_) )_h_)

where:

- [V_E_]_a_= minute volume for rats = 0.141 L/min
- SA_TB a_ = TB surface area for rats = 22.5 cm^2^
- e^−(SAet/Ve)^_a_ = Fraction of chemical concentration penetrating the ET region and available for uptake in the TB region in rats = 0.899
- [V_E_]_h_= minute volume for humans = 13.8 L/min
- SA_TB h_ = TB surface area for humans = 3200 cm^2^
- e^−(SAet/Ve)^_a_ = Fraction of chemical concentration penetrating the ET region and available for uptake in the TB region in humans = 0.986

Applying this equation results in an RGDR of 1.33 for tracheobronchial effects in rats, and the HEC is calculated as:

L O A E L_H E C_ = L O A E L_A D J_ × R G D R = 0.061 p p m × 1.33 = 0.081 p p m

Uncertainty Factor: The LOAEL_HEC_ is divided by a total uncertainty factor of 300:

- 10 for human variability
- 10 for use of a LOAEL
- 3 for animal to human extrapolation after dosimetric adjustment

MRL = LOAEL_HEC_ ÷ uncertainty factors = 0.081 ppm ÷ ( 3 × 10 × 10 ) ≈ 0.0003 ppm ( 3 × 10^− 4^ ppm )

Other Additional Studies or Pertinent Information that Lend Support to this MRL: The respiratory tract is a clear target for 2-methylnaphthalene and the related compound, 1-methylnaphthalene, after oral exposure. Chronic-duration studies of these compounds in mice exposed via the diet have resulted in increased incidences of pulmonary alveolar proteinosis (Murata et al. 1993, 1997). Exposure to the related compound, naphthalene, via inhalation is also associated with effects on the respiratory tract in both mice and rats (Abdo et al. 2001; Carratt et al. 2016, 2019a; Cichocki et al. 2014; Dodd et al. 2010, 2012; NTP 1992a, 2000).

The odor threshold for 2-methylnaphthalene in air is in the range of 0.0581–0.2905 mg/m^3^ or 0.0099–0.04939 ppm (see Section 4.2).

Agency Contacts (Chemical Managers): Gaston Casillas, Ph.D.

## 2-Methylnaphthalene Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2-Methylnaphthalene
CAS Numbers: | 91-57-6
Date: | March 2025
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: Chronic-duration toxicity studies of inhaled 2-methylnaphthalene were not located, precluding derivation of a chronic-duration inhalation MRL.

Rationale for Not Deriving an MRL: Chronic-duration toxicity studies of inhaled 2-methylnaphthalene were not located.

Agency Contacts (Chemical Managers): Gaston Casillas, Ph.D.

## 2-Methylnaphthalene Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2-Methylnaphthalene
CAS Numbers: | 91-57-6
Date: | March 2025
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: Acute-duration oral toxicity studies of 2-methylnaphthalene were not located, precluding derivation of an acute-duration oral MRL.

Rationale for Not Deriving an MRL: Acute-duration oral toxicity studies of 2-methylnaphthalene were not located.

Agency Contacts (Chemical Managers): Gaston Casillas, Ph.D.

## 2-Methylnaphthalene Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2-Methylnaphthalene
CAS Numbers: | 91-57-6
Date: | March 2025
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: Intermediate-duration oral toxicity studies of 2-methylnaphthalene were not adequate for derivation of an intermediate-duration oral MRL.

Rationale for Not Deriving an MRL: In a range-finding study, groups of B6C3F1 mice (10/sex/group) were fed diets containing 2-methylnaphthalene for 13 weeks delivering approximate average daily doses of 0, 31, 92, 276, 827, or 2,500 mg/kg/day (Murata et al. 1997). No histopathologic lesions were found in tissues and organs of male or female mice exposed to 827 or 2,500 mg/kg/day; tissues from mice in lower dose groups were not examined histologically. Decreased body weights, compared with control values, were seen at the three highest dose levels in both males and females, and were attributed to food refusal (Murata et al. 1997). The limited reporting of experimental details and results from this intermediate-duration study precludes its use as the basis of an intermediate-duration oral MRL for 2-methylnaphthalene.

Agency Contacts (Chemical Managers): Gaston Casillas, Ph.D.

## 2-Methylnaphthalene Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | 2-Methylnaphthalene
CAS Numbers: | 91-57-6
Date: | March 2025
Profile Status: | Final
Route: | Oral
Duration: | Chronic
MRL: | 0.06 mg/kg/day
Critical Effect: | Pulmonary alveolar proteinosis
Reference: | Murata et al. 1997
Point of Departure: | BMDL_05_ of 6.4 mg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 3
Species: | Mouse

MRL Summary: A chronic-duration oral MRL of 0.06 mg/kg/day was derived for 2-methylnaphthalene based on increased incidences of pulmonary alveolar proteinosis in male mice fed 2-methylnaphthalene via diet (Murata et al. 1997). BMD modeling of the incidences yielded a BMDL_05_ of 6.4 mg/kg/day; application of an uncertainty factor of 100 (10 for human variability and 10 for interspecies extrapolation) resulted in the MRL of 0.06 mg/kg/day.

Selection of the Critical Effect: Only one study evaluated the effects of chronic-duration oral exposure to 2-methylnaphthalene. Murata et al. (1997) evaluated a comprehensive list of toxicological endpoints in mice following dietary administration of 2-methylnaphthalene for 81 weeks. The only noncancer effect identified was an increased incidence of pulmonary alveolar proteinosis in both male and female mice. Thus, pulmonary alveolar proteinosis was selected as the critical effect.

Selection of the Principal Study: Murata et al. (1997) conducted the only chronic-duration oral study of 2-methylnaphthalene. This study evaluated comprehensive toxicological endpoints and was selected as the principal study.

Summary of the Principal Study:

Murata Y, Denda A, Maruyama H, . 1997. Chronic toxicity and carcinogenicity studies of 2-methylnaphthalene in B6C3F1 mice. Fundam Appl Toxicol 36(1):90–93.9073471

Groups of B6C3F1 mice (50/sex/group) were fed a diet of 0, 0.075, or 0.15% 2-methylnaphthalene (97% purity) for 81 weeks. Doses consumed were estimated by the study authors to be 0, 54.3, and 113.8 mg/kg/day in males and 0, 50.3 and 107.6 mg/kg/day in females. Observations for mortality and clinical signs were performed daily. Body weights were measured weekly for 16 weeks and biweekly thereafter. Food consumption was monitored at regular intervals. After the treatment period, animals were sacrificed, and blood was collected for hematology and serum chemistry. Animals underwent gross necropsy and selected organs were weighed (brain, salivary glands, heart, thymus, lungs, liver, pancreas, spleen, kidneys, and testes) and evaluated for histopathology (brain, salivary glands, heart, thymus, lungs, liver, pancreas, spleen, kidneys, testes, adrenals, trachea, stomach, small intestine, large intestine, seminal vesicles, ovaries, uterus, vagina, mammary glands, skeletal muscle, eyes, Harderian glands, spinal cord, bone, skin, and gross lesions).

There were no treatment-related mortalities. No effects were observed on clinical signs, body weights, body weight gain, or food consumption. Increased monocytes were noted in treated groups of both sexes.

No other treatment-related changes in hematology, and no effects on serum chemistry or organ weights were observed. Histopathology changes were seen only in the lungs of treated mice and were identified as pulmonary alveolar proteinosis, characterized by an accumulation of phospholipids in the alveolar lumens. The incidences of pulmonary alveolar proteinosis in controls, low-dose, and high-dose groups were 4/49, 21/49, and 23/49 in males and 5/50, 27/49, and 22/48 in females, respectively.

The study authors noted the rarity of pulmonary alveolar proteinosis among historical controls (not found in >5,000 controls) and considered the high incidence found in control animals to be related to potential inhalation of volatilized methylnaphthalene from the diet through improper ventilation in the exposure room.

Selection of the Point of Departure for the MRL: Pulmonary alveolar proteinosis was observed in both sexes at both doses. The incidences of this lesion are summarized in Table A-13.

Table A-13 Incidences^a^ of Pulmonary Alveolar Proteinosis in B6C3F1 Mice Exposed to 2-Methylnaphthalene in the Diet for 81 Weeks

| Dose (mg/kg/day)
| 0 | 54.3 (males); 50.3 (females) | 113.8 (males); 107.6 (females)
Males | 4/49 | 21/49^b^ | 23/49^b^
Females | 5/50 | 27/49^b^ | 22/48^b^

a Incidence reported as number affected/number examined.

b Statistically significantly different from control at p<0.05 as reported by study authors.

Source: Murata et al. 1997

BMD modeling was conducted to identify a POD using pulmonary alveolar proteinosis incidence data from male and female mice in the study by Murata et al. (1997). The data were fit to all available dichotomous models in EPA’s BMDS (version 3.2.0.1) using a BMR of 5% extra risk. A BMR of 5% extra risk was selected over the default value of 10% extra risk due to the potentially severe complications that may result in humans with pulmonary alveolar proteinosis. These complications include opportunistic pulmonary infections including tuberculosis as well as death from respiratory failure (Bush and Pabary 2020). The use of a BMR of 5% is also supported by reports that children with pulmonary alveolar proteinosis (albeit of unknown etiology) experience more severe symptoms of respiratory dysfunction than adults (EPA 2003; Mazzone et al. 2001). For example, in newborns with congenital pulmonary alveolar proteinosis, respiratory distress requiring intubation and mechanical ventilation develops rapidly (Bush and Pabary 2020).

Adequate model fit was judged by four criteria: goodness-of-fit statistics (p-value >0.1), visual inspection of the dose-response curve, a 95% confidence limit on the BMD (BMDL) that is not 10 times lower than the lowest non-zero dose, and scaled residual within ±2 units at the data point (except the control) closest to the predefined BMR. Among the models providing adequate fit to the data, the lowest BMDL was selected as the POD when the difference between the BMDLs estimated from these models was >3-fold; otherwise, the BMDL from the model with the lowest AIC was chosen.

None of the models provided adequate fit to the data in female mice. For male mice, the BMD software recommended the frequentist multi-stage degree 1 model for pulmonary alveolar proteinosis, and after verifying the model fit by the four criteria listed above, this model was selected as the basis for estimating this MRL. The BMD05/BMDL05 values considered for MRL derivation are presented in Table A-14 and the fit of the selected model is presented in Figure A-5.

Table A-14 Model Predictions for Increased Incidence of Pulmonary Alveolar Proteinosis in Male Mice Exposed to 2-Methylnaphthalene in the Diet for 81 Weeks (Murata et al. 1997)

Model | BMD_05_^a^ (mg/kg/day) | BMDL_05_^a^ (mg/kg/day) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMD_05_^a^ (mg/kg/day) | BMDL_05_^a^ (mg/kg/day) | p-Value^b^ | AIC | Dose below BMD | Dose above BMD
Dichotomous Hill | | | NA | 168.38 | −5.9×10^−5^ | 0.00
Gamma^d^ | 8.76 | 6.40 | 0.11 | 168.93 | −0.30 | 1.29
Log-Logistic^e^ | | | 0.23 | 167.81 | −0.13 | 0.90
Multistage Degree 2^f^ | 8.76 | 6.40 | 0.11 | 168.93 | −0.30 | 1.29
Multistage Degree 1 ^f^ ^,^ ^g^ | 8.76 | 6.40 | 0.11 | 168.93 | −0.30 | 1.29
Weibull^d^ | 8.76 | 6.40 | 0.11 | 168.93 | −0.30 | 1.29
Logistic | | | 0.01 | 172.84 | −1.33 | 1.98
Log-Probit | | | NA | 168.38 | 8.95×10^−7^ | 1.69×10^−6^
Probit | | | 0.01 | 172.40 | −1.20 | 1.95

a BMD and BMDLs values for models that do not provide adequate fit or yield BMDLs more than 10-fold lower than the lowest nonzero dose are not included in this table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the BMC.

d Power restricted to ≥1.

e Slope restricted to ≥1.

f Betas restricted to ≥0.

g The Gamma, Log-Logistic, Multistage 1- and 2-degree, and Weibull models provided adequate fit to the data. BMDLs were sufficiently close (differed by <3-fold). The log-logistic model had the lowest AIC; however, at a BMR of 5%, the BMDL for this model was 10 times lower than the lowest non-zero dose. The Gamma, Weibull, and Multistage 2- and 1-degree models converged on the same model; the 1-degree Multistage model was selected as the most parsimonious choice.

AIC = Akaike Information Criterion; BMD = benchmark dose (maximum likelihood estimate of the concentration associated with the selected benchmark response); BMDL_10_ = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., 05 = dose associated with 5% extra risk); BMR = benchmark response

Figure A-5 Fit of the Multistage Degree 1 Model to Data for Increased Incidence of Pulmonary Alveolar Proteinosis in Male Mice Exposed to 2-Methylnaphthalene in the Diet for 81 Weeks (Murata et al. 1997)

Calculations

Adjustment for Intermittent Exposure: Not applicable

Uncertainty Factor: The BMDL of 6.4 mg/kg/day was divided by an uncertainty factor of 100 (10 for human variability, 10 for extrapolation from animals to humans), resulting in an MRL of 0.06 mg/kg/day.

- 10 for extrapolation from animals to humans
- 10 for human variability

MRL = BMDL_05_ ÷ UF = 6.4 mg / kg / day ÷ ( 100 ) ≈ 0.06 mg / kg / day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Increased incidences of pulmonary alveolar proteinosis has also been reported in B6C3F1 mice exposed to 1-methylnaphthalene in the diet for 81 weeks (Murata et al. 1993), and in mice dermally exposed to mixed methylnaphthalenes (a mixture of 1- and 2-methylnaphthalene) for 30–61 weeks (Emi and Konishi 1985; Murata et al. 1992). In a range-finding study, groups of B6C3F1 mice (10/sex/group) were fed diets containing 2-methyl naphthalene for 13 weeks delivering approximate average daily doses of 0, 31, 92, 276, 827, or 2,500 mg/kg/day (Murata et al. 1997). No histopathologic lesions were found in tissues and organs of male or female mice exposed to 827 or 2,500 mg/kg/day; tissues from mice in lower dose groups were not examined histologically (Murata et al. 1997). The absence of pulmonary alveolar proteinosis in the subchronically exposed mice, which were exposed to much higher doses than those experienced by mice with this lesion in the chronic-duration study, suggests that the development of pulmonary alveolar proteinosis from oral exposure to 2-methyl naphthalene requires chronic-duration exposure.

Agency Contacts (Chemical Managers): Gaston Casillas, Ph.D.