# CHAPTER 8 REFERENCES

+ Cited in supplemental document

Ahasan MM. 2004. Assessment of radiation dose in nuclear medicine hot lab. Iran J Radiat Res 2(2):75–78.
Alfa Aesar. 2015. Safety data sheet. Ammonium tetrathiomolybdate. Stock number: 43493. Alfa Aesar. https://www.alfa.com/en/content/msds/USA/43493.pdf. November 13, 2015.
+Allan S. 1996a. Ammonium dimolybdate skin sensitisation in the guinea-pig. London, England: International Molybdenum Association.
+Allan S. 1996b. Molybdenum oxide (pure). Skin sensitisation in the guinea-pig. London, England: International Molybdenum Association.
+Allan S. 1996c. Molybdenum oxide (technical). Skin sensitisation in the guinea-pig. London, England: International Molybdenum Association.
+Allan S. 1996d. Sodium molybdate 241/32. Skin sensitisation in the guinea-pig. London, England: International Molybdenum Association.
Anderson RR. 1992. Comparison of trace elements in milk of four species. J Dairy Sci 75:3050–3055.1460135
APHA. 1989. 3120 B. Inductively coupled plasma (ICP) method. In: Greenberg A, Clesceri L, Eaton A, eds. Standard methods for the examination of water and wastewater. 18^th^ ed. Washington, DC: American Public Health Association, 34–40.
Aquilio E, Spagnoli R, Seri S, 1996. Trace element content in human milk during lactation of preterm newborns. Biol Trace Elem Res 51:63–70.8834381
Archibald JG. 1951. Molybdenum in cows’ milk. J Dairy Sci 34(10):1026–1029.
Arlauskas A, Baker RU, Bonin AM, 1985. Mutagenicity of metal ions in bacteria. Environ Res 36:379–388.3884331
+Arrington LR, Davis GK. 1953. Molybdenum toxicity in the rabbit. J Nutr 51(2):295–304.13097245
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Fed Regist 54(174):37618–37634.
ATSDR. 2017. Molybdenum. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/SPL/resources/index.html. October 6, 2017.
Bailey MR, Ansoborlo E, Guilmette RA, 2007. Updating the ICRP human respiratory tract model. Radiat Prot Dosimetry 127(1–4):31–34.18192668
+Baldrick P, Healing G. 1990a. Acute dermal toxicity to rats of ammonium molybdate. London, England: International Molybdenum Association.
+Baldrick P, Healing G. 1990b. Acute dermal toxicity to rats of pure molybdic oxide. London, England: International Molybdenum Association.
+Baldrick P, Healing G. 1990c. Acute dermal toxicity to rats of sodium molybdate. London, England: International Molybdenum Association.
+Baldrick P, Healing G. 1990d. Acute dermal toxicity to rats of technical molybdic oxide. London, England: International Molybdenum Association.
+Baldrick P, Healing G. 1990e. Acute oral toxicity to rats of ammonium molybdate. London, England: International Molybdenum Association.
+Baldrick P, Healing G. 1990f. Acute oral toxicity to rats of pure molybdic oxide. London, England: International Molybdenum Association.
+Baldrick P, Healing G. 1990g. Acute oral toxicity to rats of sodium molybdate. London, England: International Molybdenum Association.
+Baldrick P, Healing G. 1990h. Acute oral toxicity to rats of technical molybdic oxide. London, England: International Molybdenum Association.
Ballinger JR. 2010. Short- and long-term responses to molybdenum-99 shortages in nuclear medicine. Br J Radiol 83:899–901.20965898
+Bandyopadhyay SK, Chatterjee K, Tiwari RK, 1981. Biochemical studies on molybdenum toxicity in rats: Effects of high protein feeding. Int J Vitam Nutr Res 51(4):401–409.7327862
Barceloux DG. 1999. Molybdenum. J Toxicol Clin Toxicol 37(2):231–237.10382558
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486.3222488
Bayram E, Topcu Y, Karakaya P, 2013. Molybdenum cofactor deficiency: Review of 12 cases (MoCD) and review. Eur J Paediatr Neurol 17:1–6.23122324
Beevers C. 2009. Reverse mutation in five histidine-requiring strains of Salmonella typhimurium. London, England: International Molybdenum Association.
Bell MC, Diggs BG, Lowrey RS, 1964. Comparison of Mo99 metabolism in swine and cattle as affected by stable molybdenum. J Nutr 84:367–372.14242354
+Bersenyi A, Berta E, Kadar I, 2008. Effects of high dietary molybdenum in rabbits. Acta Vet Hung 56(1):41–55. 10.1556/AVet.56.2008.1.5.18401955
Bibr B, Deyl Z, Lener J, 1977. Investigation of the reaction of molybdenum with collagen in vivo. Int J Pept Protein Res 10(3):190–196.914421
Biego GH, Joyeux M, Hartemann P, 1998. Determination of mineral contents in different kinds of milk and estimation of dietary intake in infants. Food Addit Contam 15(7):775–781.10211184
Boman A, Wahlberg JE, Hagelthorn G. 1979. Sensitizing potential of beryllium, copper and molybdenum compounds studied by the guinea pig maximization method. Contact Dermatitis 5(5):332–333. 10.1111/j.1600-0536.1979.tb04891.x.509937
+Bompart G, Pecher C, Prevot D, 1990. Mild renal failure induced by subchronic exposure to molybdenum: Urinary kallikrein excretion as a marker of distal tubular effect. Toxicol Lett 52(3):293–300.1975134
Bougle D, Bureau F, Foucault P, 1988. Molybdenum content of term and preterm human milk during the first 2 months of lactation. Am J Clin Nutr 48(3):652–654.3414580
Bougle D, Voirin J, Bureau F, 1989. Molybdenum. Normal plasma values at delivery in mothers and newborns. Acta Paediatr Scand 78(2):319–320.2929358
Brewer GJ, Dick RD, Grover DK, 2000. Treatment of metastatic cancer with tetrathiomolybdate, an anticopper, antiangiogenic agent: Phase I study. Clin Cancer Res 6(1):1–10.10656425
+Brinkman GL, Miller RF. 1961. Influence of cage type and dietary zinc oxide upon molybdenum toxicity. Science 134(3489):1531–1532.
Burzlaff A, Beevers C, Pearce H, 2017. New studies on the in vitro genotoxicity of sodium molybdate and their impact on the overall assessment of the genotoxicity of molybdenum substances. Regul Toxicol Pharmacol 86:279–291. 10.1016/j.yrtph.2017.03.018.28342846
Campillo N, López-García I, Viñas P, 2002. Determination of vanadium, molybdenum and chromium in soils, sediments and sludges by electrothermal atomic absorption spectrometry with slurry sample introduction. J Anal Atom Spectrom 17(10):1429–1433. 10.1039/b205699b.
Cannon P. 1959. Melting point and sublimation of molybdenum disulphide. Nature 183:1612–1613.
Cantone MC, de Bartolo D, Molho N, 1993. Response to a single oral test of molybdenum stable isotopes for absorption studies in humans. Physiol Meas 14(2):217–225.8334416
Cantone MC, de Bartolo D, Giussani A, 1997. A methodology for biokinetic studies using stable isotopes: results of repeated molybdenum investigations on a healthy volunteer. Appl Radiat Isot 48(3):333–338.9116652
Cardin CJ, Mason J. 1975. Sulphate transport by rat ileum. Effect of molybdate and other anions. Biochim Biophys Acta 394(1):46–54.166688
Cardin CJ, Mason J. 1976. Molybdate and tungstate transfer by rat ileum. Competitive inhibition by sulphate. Biochim Biophys Acta 455(3):937–946.999946
Casey CE, Neville MC. 1987. Studies in human lactation 3: Molybdenum and nickel in human milk during the first month of lactation. Am J Clin Nutr 45:921–926.3578094
CCME. 1999. Canadian water quality guidelines for the protection of aquatic life: Molybdenum. Canadian environmental quality guidelines. Winnipeg, Canada: Canadian Council of Ministers of the Environment. 1–4.
CDC. 2015. Fourth national report on human exposure to environmental chemicals, updated tables (February 2015). Atlanta, GA: Centers for Disease Control and Prevention. http://www.cdc.gov/exposurereport/. September 24, 2015.
CDC. 2019. Fourth national report on human exposure to environmental chemicals, updated tables, (January 2019). Atlanta, GA: Centers for Disease Control and Prevention. Vol. 1, 332–337, 844. https://www.cdc.gov/exposurereport/. April 29, 2019.
Chan KM, Riley JP. 1966. The determination of molybdenum in natural waters, silicates and biological materials. Anal Chim Acta 36:220–229.4288912
Cho K, Wu C. 2004. Control of molybdenum emission by sorbents: Equilibrium analysis. J Environ Eng (New York) 130(2):201–204. 10.1061/(ASCE)0733-9372(2004)130:2(201).
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
+Cook GA, Lesperance AL, Bohman VR, 1966. Interrelationship of molybdenum and certain factors to the development of the molybdenum toxicity syndrome. J Anim Sci 25(1):96–101.5905519
Coughtrey PJ, Thorne MC. 1983. Molybdenum. In: Radionuclide distribution and terrestrial and aquatic ecosystems. A critical review of data. Rotterdam: A.A. Balkema, 351–375.
+Cox DH, Davis GK, Shirley RL, 1960. Influence of excess dietary molybdenum on rat and calf liver and heart enzymes. J Nutr 70:63–68.13812509
Cruywagen JJ. 2000. Protonation, oligomerization, and condensation reactions of vanadate(V), molybdate(VI), and tungstate(VI). Adv Inorg Chem 49:127–182.
Cruywagen JJ, Draaijer AG, Heyns JBB, 2002. Molybdenum(VI) equilibria in different ionic media. Formation constants and thermodynamic quantities. Inorg Chim Acta 331(1):322–329. 10.1016/S0020-1693(02)00700-4.
Dang HS, Jaiswal DD, Somasundaram S, 1984. Concentrations of four essential trace elements in breast milk of mothers from two socio-economic groups: Preliminary observations. Sci Total Environ 35:85–89.6729439
Deltombe E, de Zoubov N, Pourbaix M. 1974. Molybdenum. In: Pourbaix M, Franklin JA, eds. Atlas of electrochemical equilibria in aqueous solutions. Houston, TX: National Association of Corrosion Engineers, 272–279.
+Deosthale YG, Gopalan C. 1974. The effect of molybdenum levels in sorghum (Sorghum vulgare Pers.) on uric acid and copper excretion in man. Br J Nutr 31(3):351–355.4835788
DiPietro ES, Phillips DL, Paschal DC, 1989. Determination of trace elements in human hair: Reference intervals for 28 elements in nonoccupationally exposed adults in the US and effects of hair treatments. Biol Trace Elem Res 22(1):83–100.2484231
DOE. 2018a. Protective Action Criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29A, June 2018. Oak Ridge, TN: U.S. Department of Energy. https://sp.eota.energy.gov/pac/. July 26, 2018.
DOE. 2018b. Table 3: Protective Action Criteria (PAC) Rev. 29a based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. June 2018. Oak Ridge, TN: U.S. Department of Energy. https://sp.eota.energy.gov/pac/docs/Revision_29A_Table3.pdf. July 26, 2018.
DOI. 1967. Trace metals in water of the United States. A five year summary of trace metals in rivers and lakes of the United States (October 1, 1967 - September 30, 1967). Cincinnati, OH: U.S. Department of the Interior. 1–12. PB215680.
Doll CG, Sorensen CM, Bowyer TW, 2014. Abatement of xenon and iodine emissions from medical isotope production facilities. J Environ Radioact 130:33–43.24418952
Domingo-Relloso A, Grau-Perez M, Galan-Chilet I, 2019. Urinary metals and metal mixtures and oxidative stress biomarkers in an adult population from Spain: The Hortega Study. Environ Int 123:171–180. 10.1016/j.envint.2018.11.055.30529889
+Droste JH, Weyler JJ, Van Meerbeeck JP, 1999. Occupational risk factors of lung cancer: A hospital based case-control study. Occup Environ Med 56(5):322–327.10472306
ECHA. 2019a. Molybdenum. Physical and chemical properties. Helsinki, Finland: European Chemicals Agency. https://echa.europa.eu/registration-dossier/-/registered-dossier/15524/4/9. July 8, 2019.
ECHA. 2019b. Ammonium molybdate(VI). Registration dossier. Helsinki, Finland: European Chemical Agency. https://echa.europa.eu/registration-dossier/-/registered-dossier/22245/4/3. June 14, 2019.
ECHA. 2019c. Diammonium dimolybdate. Physical and chemical properties. Helsinki, Finland: European Chemicals Agency. https://echa.europa.eu/substance-information/-/substanceinfo/100.044.092. June 6, 2019.
EFSA. 2013. Scientific opinion on dietary reference values for molybdenum. EFSA panel on dietetic products, nutrition, and allergies (NDA). EFSA J 11(8):3333. http://www.efsa.europa.eu/sites/default/files/scientific_output/files/main_documents/3333.pdf. November 11, 2015.
Engel RW, Price NO, Miller RF. 1967. Copper, manganese, cobalt, and molybdenum balance in preadolescent girls. J Nutr 92(2):197–204.6029070
EPA. 1979. Human health effects of molybdenum in drinking water. U.S. Environmental Protection Agency. EPA600179006. PB292755. http://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=2000Z0FV.txt. October 2, 2015.
EPA. 1994. Method 200.8. Determination of trace elements in waters and wastes by inductively coupled plasma - mass spectrometry. Cincinnati, OH: U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2015-06/documents/epa-200.8.pdf. June 6, 2019.
EPA. 1999. Compendium method IO-3.3. Determination of metals in ambient particulate matter using x-ray fluorescence (XRF) spectroscopy. Compendium of methods for the determination of inorganic compounds in ambient air. Cincinnati, OH: U.S. Environmental Protection Agency. EPA625R96010a. https://www3.epa.gov/ttnamti1/files/ambient/inorganic/mthd-3-3.pdf. June 10, 2019.
EPA. 2005. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. U.S. Environmental Protection Agency. EPA260B05001.
EPA. 2009a. Characterization of coal combustion residues from electric utilities - Leaching and characterization data. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA600R09151. https://nepis.epa.gov/EPA/html/DLwait.htm?url=/Exe/ZyPDF.cgi/P1007JBD.PDF?Dockey=P1007JBD.PDF. June 10, 2019.
EPA. 2009b. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency. EPA816F090004. http://water.epa.gov/drink/contaminants/upload/mcl-2.pdf. March 4, 2015.
EPA. 2016. Acute Exposure Guideline Levels (AEGLs) values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2016-03/documents/compiled_aegl_update_.pdf. September 8, 2017.
EPA. 2017a. Framework for metals risk assessment. U.S. Environmental Protection Agency. EPA120R07001. https://www.epa.gov/sites/production/files/2013-09/documents/metals-risk-assessment-final.pdf. June 10, 2019.
EPA. 2017b. The third unregulated contaminant monitoring rule (UCMR 3): Data summary, January 2017. U.S. Environmental Protection Agency. EPA815S17001. https://www.epa.gov/sites/production/files/2017-02/documents/ucmr3-data-summary-january-2017.pdf. June 10, 2019.
EPA. 2018a. 2018 Edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency. EPA822S12001. https://www.epa.gov/sites/production/files/2018-03/documents/dwtable2018.pdf. July 25, 2018.
EPA. 2018b. Standards for the use or disposal of sewage sludge. Subpart B - Land application. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 503. https://www.govinfo.gov/content/pkg/CFR-2018-title40-vol32/xml/CFR-2018-title40-vol32-part503.xml. June 7, 2019.
EPA. 2018c. EPA Air Quality System database: Molybdenum. Washington, DC: U.S. Environmental Protection Agency. https://www.epa.gov/outdoor-air-quality-data. June 10, 2019.
EPA. 2019a. Ammonium molybdenum oxide. Substance Registry Services (SRS). U.S. Environmental Protection Agency. https://ofmpub.epa.gov/sor_internet/registry/substreg/searchandretrieve/substancesearch/search.do?details=displayDetails&selectedSubstanceId=56972. June 11, 2019.
EPA. 2019b. Ammonium molybdate. Substance Registry Services (SRS). U.S. Environmental Protection Agency. https://ofmpub.epa.gov/sor_internet/registry/substreg/searchandretrieve/substancesearch/search.do?details=displayDetails&selectedSubstanceId=61506. June 11, 2019.
Fairhall LT, Dunn RC, Sharpless NE, 1945. The toxicity of molybdenum. Public Health Bulletin, No 293(36):52.
FDA. 2017. Total diet study. Elements results summary statistics: Market baskets 2006 through 2013. College Park, Maryland: U.S. Food and Drug Administration. https://www.fda.gov/media/77948/download. June 10, 2019.
FDA. 2018. Substances Added to Food. Washington, DC: U.S. Food and Drug Administration. https://www.accessdata.fda.gov/scripts/fdcc/?set=FoodSubstances. July 26, 2018.
+Feaster JP, Davis GK. 1959. Sulfate metabolism in rabbits on high molybdenum intake. J Nutr 67(2):319–323.13642125
+Fejery P, Toth P, Kobor A. 1983. The effect of fluorine and molybdenum on some of the mechanical characteristics of the hard tissues in rats kept on a low and on a normal protein diet. J Int Assoc Dent Child 14:9–14.6581233
+Fell BF, Dinsdale D, El-Gallad TT. 1979. Gut pathology of rats dosed with tetrathiomolybdate. J Comp Pathol 89(4):495–514.541455
Fitzgerald D, Nicholson R, Regoli L. 2008. Environmental management criteria for molybdenum and selenium: A review relevant to the mining industry. Vancouver, Canada: University of British Columbia. https://circle.ubc.ca/bitstream/handle/2429/9191/10Fitzgerald%20Nicholson%20Paper.pdf?sequence=1. Sept 24, 2015.
FOREGS. 2005. Statistical data of analytical results. In: Geochemical Atlas of Europe, Part 1: Background information, methodology and maps. Forum of European Geological Surveys, http://weppi.gtk.fi/publ/foregsatlas/article.php?id=15. May 24, 2016.
Fox V. 2005. Sublimed undensified molybdenum trioxide: in vitro micronucleus assay in human lymphocytes. London, England: International Molybdenum Association.
+Franke KW, Moxon AL. 1937. The toxicity of orally ingested arsenic, selenium, tellurium, vanadium, and molybdenum. J Pharmacol Exp Ther 61:89–102.
Frascoli F, Hudson-Edwards K. 2018. Geochemistry, mineralogy and microbiology of molybdenum in mining-affected environments. Minerals 8(2):42. 10.3390/min8020042.
Friel JK, Andrews WL, Jackson SE, 1999a. Elemental composition of human milk from mothers of premature and full-term infants during the first 3 months of lactation. Biol Trace Elem Res 67:225–247.10201330
Friel JK, MacDonald AC, Mercer CN, 1999b. Molybdenum requirements in low-birth-weight infants receiving parenteral and enteral nutrition. JPEN J Parenter Enteral Nutr 23(3):155–159. 10.1177/0148607199023003155.10338223
Fungwe TV, Buddingh F, Yang MT, 1989. Hepatic, placental, and fetal trace elements following molybdenum supplementation during gestation. Biol Trace Elem Res 22(2):189–199.2484239
+Fungwe TV, Buddingh F, Demick DS, 1990. The role of dietary molybdenum on estrous activity, fertility, reproduction and molybdenum and copper enzyme activities of female rats. Nutr Res 10(5):515–524.
Gibson DP, Brauninger R, Shaffi HS, 1997. Induction of micronuclei in Syrian hamster embryo cells: Comparison to results in the SHE cell transformation assay for National Toxicology Program test chemicals. Mutat Res 1(2):61–70.
Gimenez I, Garay R, Alda JO. 1993. Molybdenum uptake through the anion exchanger in human erythrocytes. Pflugers Arch 424(3–4):245–249.8414913
+Gipp WF, Pond WG, Smith SE. 1967. Effects of level of dietary copper, molybdenum, sulfate and zinc on bodyweight gain, hemoglobin and liver copper storage of growing pigs. J Anim Sci 26(4):727–730.6076863
Giussani A. 2008. A recycling systemic model for the biokinetics of molybdenum radionuclides. Sci Total Environ 404(1):44–55. 10.1016/j.scitotenv.2008.06.019.18640703
Giussani A, Cantone MC, de Bartolo D, 1998. A revised model of molybdenum biokinetics in humans for application in radiation protection. Health Phys 75(5):479–486.9790556
Giussani A, Cantone MC, de Bartolo D, 2000. Internal dose for ingestion of molybdenum radionuclides based on a revised biokinetic model. Health Phys 78(1):46–52.10608309
Giussani A, Arogunjo AM, Claire Cantone M, 2006. Rates of intestinal absorption of molybdenum in humans. Appl Radiat Isot 64(6):639–644. 10.1016/j.apradiso.2005.12.013.16439140
Giussani A, Cantone MC, Hollriegl V, 2007. Modelling urinary excretion of molybdenum after oral and intravenous administration of stable tracers. Radiat Prot Dosimetry 127(1–4):136–139. 10.1093/rpd/ncm263.17561520
Goldberg S, Lesch SM, Suarez DL. 2002. Predicting molybdenum absorption by soils using soil chemical parameters in the constant capacitance model. Soil Sci Soc Am J 66:1836–1842.
Gould L, Kendall NR. 2011. Role of the rumen in copper and thiomolybdate absorption. Nutr Res Rev 24(2):176–182. 10.1017/s0954422411000059.22296933
+Gray LF, Daniel LJ. 1954. Some effects of excess molybdenum on the nutrition of the rat. J Nutr 53(1):43–51.13163754
Greenwood NN, Earnshaw A. 1997. Chromium, molybdenum and tungsten. In: Chemistry of the elements. Burlington, MA: Elsevier Butterworth-Heinemann, 1002–1039.
Hadjimarkos DM. 1967. Effect of trace elements in drinking water on dental caries. J Pediatr 70(6):967–969.6026122
Hattori H, Ashida A, Ito C, 2004. Determination of molybdenum in foods and human milk, and an estimate of average molybdenum intake in the Japanese population. J Nutr Sci Vitaminol (Tokyo) 50(6):404–409.15895515
Haynes W, Lide DR, Bruno T. 2014. Physical constants of inorganic compounds. In: CRC Handbook of chemistry and physics. 95th ed. Boca Raton, FL: Taylor and Francis Group, LLC, 4–47 to 44–48.
Haywood S. 1985. Copper toxicosis and tolerance in the rat. I - Changes in copper content of the liver and kidney. J Pathol 145(2):149–158. 10.1002/path.1711450203.3973768
Helaly AM, Mokhtar N, Firgany AEL, 2018. Molybdenum bupropion combined neurotoxicity in rats. Regul Toxicol Pharmacol 98:224–230. 10.1016/j.yrtph.2018.08.001.30081056
+Howell JM, Shunxiang Y, Gawthorne JM. 1993. Effect of thiomolybdate and ammonium molybdate in pregnant guinea pigs and their offspring. Res Vet Sci 55(2):224–230 8235091
Huang X, Sillanpaa M, Gjessing ET, 2010. Environmental impact of mining activities on the surface water quality in Tibet: Gyama Valley. Sci Total Environ 408(19):4177–4184. 10.1016/j.scitotenv.2010.05.015.20542540
+Hunt CE, Navia JM. 1973. Effects of Sr, Mo, Li and B on developing teeth and other tissues of neonatal rats. Trace Subst Environ Health VI:159–168.
+Hunt CE, Navia JM. 1975. Pre-eruptive effects of Mo, B, Sr and F on dental caries in the rat. Arch Oral Biol 20(8):497–501.1057875
IARC. 2018. Molybdenum trioxide. IARC Monographs on the evaluation of carcinogenic risks to humans. Volume 118. Welding, molybdenum trioxide, and indium tin oxide. Lyon, France: International Agency for Research on Cancer. http://publications.iarc.fr/569. October 31, 2018.
ICRP. 1994. Molybdenum. International Commission on Radiological Protection. Ann ICRP 23(3–4):45–47.
ICRP. 2012. Annals of the ICRP: Compendium of dose coefficients based on ICRP publication 60. International Commission on Radiological Protection. ICRP Publication 119. http://www.icrp.org/publication.asp?id=ICRP%20Publication%20119. April 30, 2019.
IMOA. 2015. Molybdenum analysis. Health, safety & environment. Background chemistry of molybdenum. International Molybdenum Association. http://www.imoa.info/HSE/environmental_data/chemistry/molybdenum_analysis.php. September 23, 2015.
IRIS. 2003. Molybdenum (CASRN 7439–98-7). Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/iris/subst/0425.htm. July 23, 2015.
Iyengar GV, Kollmer WE, Bowen HJM. 1978. Molybdenum. In: The elemental composition of human tissues and body fluids. New York: Verlag Chemie, 1, 4, 10, 15, 19, 25, 29, 33, 36, 41–45, 47–48, 53, 56–57, 61, 64, 67, 73, 79, 84, 86, 89, 91, 94, 96, 101, 104, 108, 110, 113, 116, 119, 121, 122, 125, 129, 131.
+Jackson GC, Hardy CJ, Rupanagudi SR, 1991a. Ammonium dimolybdate. Acute inhalation toxicity study in rats. 4 hour exposure. London, England: International Molybdenum Association.
+Jackson GC, Hardy CJ, Suttie AW, 1991b. Pure molybdic. Oxide acute inhalation toxicity study in rats. 4-hour Exposure. London, England: International Molybdenum Association.
+Jackson GC, Hardy CJ, Suttie AW, 1991c. Sodium molybdate. Acute inhalation toxicity study in rats. 4-hour exposure. London, England: International Molybdenum Association.
+Jackson GC, Hardy CJ, Suttie AW, 1991d. Technical molybdenum oxide acute inhalation toxicity study in rats: 4-Hour exposure. London, England: International Molybdenum Association.
+Jeter MA, Davis GK. 1954. The effect of dietary molybdenum upon growth, hemoglobin, reproduction and lactation of rats. J Nutr 54(2):215–220.13212460
+Johnson HL, Miller RF. 1961. The interrelationships between dietary molybdenum, copper, sulfate, femur alkaline phosphatase activity and growth of the rat. J Nutr 75:459–464.14452044
+Johnson RH, Little JW, Bickley HC. 1969. Some effects of molybdenum on connective tissue. J Dent Res 48(6):1290–1295.5262062
Jones E. 2004. Sublimes undensified pure molybdenum trioxide: Bacterial mutation assay in S. typhimurium and E. coli. London, England: International Molybdenum Association.
Kanematsu N, Hara M, Kada T. 1980. Rec assay and mutagenicity studies on metal compounds. Mutat Res 77:109–116.6769036
Kawabuchi K, Kuroda R. 1969. A combined ion-exchange spectrophotometric method for the determination of molybdenum and tungsten in sea water. Anal Chim Acta 46:23–30.
Keyes WR, Turnlund JR. 2002. Determination of molybdenum and enriched Mo stable isotope concentrations in human blood plasma by isotope dilution ICP-MS. J Anal Atom Spectrom 17(9):1153–1156. 10.1039/b202250h.
Kiriyama T, Kuroda R. 1984. Application of anion-exchange techniques to the determination of traces of molybdenum in sea-water. Talanta 31(6):472–474.18963633
+Kline RD, Corzo MA, Hays VW, 1973. Related effects of copper, molybdenum and sulfide on performance, hematology and copper stores of growing pigs. J Anim Sci 37(4):936–941.4747186
Koster R, Vieluf D, Kiehn M, 2000. Nickel and molybdenum contact allergies in patients with coronary in-stent restenosis. Lancet 356(9245):1895–1897. 10.1016/s0140-6736(00)03262-1.11130387
+Koval’skiy VV, Yarovaya GA, Shmavonyan DM. 1961. Changes of purine metabolism in man and animals under conditions of molybdenum biogeochemical provinces. Zh Obshch Biol 22(3):179–191.13753620
Krachler M, Rossipal E, Micetic-Turk D. 1999. Concentrations of trace elements in arterial and venous umbilical cord sera. Trace Elem Electrolytes 16(1):46–52.
Krachler M, Li FS, Rossipal E, 1998. Changes in the concentrations of trace elements in human milk during lactation. J Trace Elem Med Biol 12:159–176.9857329
Krishnan K, Anderson ME, Clewell HJ, 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kucera J, Bencko V, Papoyova A, 2000. Monitoring of occupational exposure in manufacturing of stainless steel constructions. Part I: Chromium, iron, manganese, molybdenum, nickel and vanadium in the workplace air of stainless steel welders. Cent Eur J Public Health 9:171–175.
Kulathilake AI, Chat A. 1980. Determination of molybdenum in sea water and estuarine water with beta-naphthoin oxime and neutron activation. Anal Chem 52(6):828–833.
Lee A, Beck L, Markovich D. 2000. The human renal sodium sulfate cotransporter (SLC13A1; hNaSi-1) cDNA and gene: Organization, chromosomal localization, and functional characteristics. Genomics 70(3):354–363.11161786
Lener J, Bibr B. 1979. Biliary excretion and tissue distribution of pentavalent and hexavalent molybdenum in rats. Toxicol Appl Pharmacol 51(2):259–264.531891
Leuschner PJ. 2010. Acute inhalation toxicity study of molybdenum trioxide in rats - According to EC Method B.2 and OECD Guideline 403. London, England: International Molybdenum Association. 1–77.
Lewis RC, Meeker JD. 2015. Biomarkers of exposure to molybdenum and other metals in relation to testosterone among men from the United States National Health and Nutrition Examination Survey 2011–2012. Fertil Steril 103(1):172–178. 10.1016/j.fertnstert.2014.09.020.25439796
Lide DR. 2005. Vapor pressure. In: CRC Handbook of chemistry and physics. 86^th^ ed. Boca Raton, FL: Taylor and Francis Group, LLC, 6–58.
+Liggett MP, McRae LA. 1990a. Irritant effects on the rabbit eye of ammonium molybdate. London, England: International Molybdenum Association.
+Liggett MP, McRae LA. 1990b. Irritant effects on the rabbit eye of pure molybdic oxide. London, England: International Molybdenum Association.
+Liggett MP, McRae LA. 1990c. Irritant effects on the rabbit eye of sodium molybdate. London, England: International Molybdenum Association.
+Liggett MP, McRae LA. 1990d. Irritant effects on the rabbit eye of technical molybdic oxide. London, England: International Molybdenum Association.
+Liggett MP, McRae LA. 1990e. Irritant effects on rabbit skin of ammonium molybdate. London, England: International Molybdenum Association.
+Liggett MP, McRae LA. 1990f. Irritant effects on rabbit skin of pure molybdic oxide. London, England: International Molybdenum Association.
+Liggett MP, McRae LA. 1990g. Irritant effects on rabbit skin of sodium molybdate. London, England: International Molybdenum Association.
Lloyds M. 2009. Mutation at the thymidine kinase (tk) locus of mouse lymphoma L5178Y cells (MLA) using the Microtitre fluctuation technique. London, England: International Molybdenum Association.
Lyubimov AV, Merceica MD, Tomaszewski JE, 2002. The developmental toxicity of tetrathiomolybdate (TTM, NSC-714598) and protective effects of copper in rats. Teratology 65(6):309.
Lyubimov AV, Mercieca MD, Smith AC, 2003. Oral developmental toxicity study of ammonium tetrathiomolybdate (NSC-714598) in rabbits. Birth Defects Res Part A Clin Mol Teratol 67(5):328.
+Lyubimov AV, Smith JA, Rousselle SD, 2004. The effects of tetrathiomolybdate (TTM, NSC-714598) and copper supplementation on fertility and early embryonic development in rats. Reprod Toxicol 19(2):223–233. 10.1016/j.reprotox.2004.07.006.15501388
Markovich D, Aronson PS. 2007. Specificity and regulation of renal sulfate transporters. Annu Rev Physiol 69:361–375.17002596
+Meeker JD, Rossano MG, Protas B, 2008. Cadmium, lead, and other metals in relation to semen quality: Human evidence for molybdenum as a male reproductive toxicant. Environ Health Perspect 116(11):1473–1479. 10.1289/ehp.11490.19057699
Meeker JD, Rossano MG, Protas B, 2009. Multiple metals predict prolactin and thyrotropin (TSH) levels in men. Environ Res 109:869–873.19595304
+Meeker JD, Rossano MG, Protas B, 2010. Environmental exposure to metals and male reproductive hormones: Circulating testosterone is inversely associated with blood molybdenum. Fertil Steril 93(1):130–140. 10.1016/j.fertnstert.2008.09.044.18990371
Mendel RR, Kruse T. 2012. Cell biology of molybdenum in plants and humans. Biochim Biophys Acta 1823(9):1568–1579. 10.1016/j.bbamcr.2012.02.007.22370186
+Mendy A, Gasana J, Vieira ER. 2012. Urinary heavy metals and associated medical conditions in the US adult population. Int J Environ Health Res 22(2):105–118. 10.1080/09603123.2011.605877.21854105
Menezes LM, Campos LC, Quintao CC, 2004. Hypersensitivity to metals in orthodontics. Am J Orthod Dentofacial 126(1):58–64. 10.1016/s0889540604000836.
Menke A, Guallar E, Cowie CC. 2016. Metals in urine and diabetes in U.S. adults. Diabetes 65(1):164–171. 10.2337/db15-0316.26542316
Miekeley N, Carneiro MTW, Silveira CL P. 1998. How reliable are human hair reference intervals for trace elements? Sci Total Environ 218(1):9–17.9718741
Miller RF, Price NO, Engel RW. 1956. Added dietary inorganic sulfate and its effect upon rats fed molybdenum. J Nutr 60(4):539–547.13385719
Mills CF, El-Gallad TT, Bremner I. 1981a. Effects of molybdate, sulfide, and tetrathiomolybdate on copper metabolism in rats. J Inorg Biochem 14(3):189–207.7264629
+Mills CF, Monty KJ, Ichihara A, 1958. Metabolic effects of molybdenum toxicity in the rat. J Nutr 65(1):129–142.13550007
Mills CF, El-Gallad TT, Bremner I, 1981b. Copper and molybdenum absorption by rats given ammonium tetrathiomolybdate. J Inorg Biochem 14(2):163–175.7252494
Momcilovic B. 1999. A case report of acute human molybdenum toxicity from a dietary molybdenum supplement - A new member of the "Lucor metallicum" family. Arh Hig Rada Toksikol 50(3):289–297.10649845
+Montenegro MA, Sanchez M Negrette, Gimeno EJ, 2002. Effects of high molybdenum intake on 1,2-dimethylhydrazine-induced intestinal tumors in rats. Biocell 26(3):339–345.12619566
Murer HI, Markovich D, Biber J. 1994. Renal and small intestinal sodium-dependent symporters of phosphate and sulphate. J Exp Biol 196:167–181.7823020
+Murray FJ, Sullivan FM, Tiwary AK, 2014a. 90-Day subchronic toxicity study of sodium molybdate dihydrate in rats. Regul Toxicol Pharmacol 70(3):579–588. 10.1016/j.yrtph.2013.09.003.24041747
+Murray JF, Tyl RW, Sullivan FM, 2014b. Developmental toxicity study of sodium molybdate dihydrate administered in the diet to Sprague Dawley rats. Reprod Toxicol 49:202–208. 10.1016/j.reprotox.2014.09.001.25236591
+Murray FJ, Sullivan FM, Hubbard SA, 2019. A two-generation reproductive toxicity study of sodium molybdate dihydrate administered in drinking water or diet to Sprague-Dawley rats. Reprod Toxicol 84:75–92. 10.1016/j.reprotox.2018.11.004.30503857
Nagra MS, Pallah BS, Sahota GPS, 1992. A study of trace elements in scalp hair and fingernails of industrial workers of Ontario, Canada. J Radioanal Nucl Chem 162(2):283–288.
+Nakadaira H, Endoh K, Yamamoto M, 1995. Distribution of selenium and molybdenum and cancer mortality in Niigata, Japan. Arch Environ Health 50(5):374–380. 10.1080/00039896.1995.9935970.7574892
Nakanishi Y, Iida S, Ueoka-Nakanishi H, 2013. Exploring dynamics of molybdate in living animal cells by a genetically encoded FRET nanosensor. PLoS ONE 8(3):e58175. 10.1371/journal.pone.0058175.23472155
Nakata R, Okazaki S, Hori T, 1983. Collection of trace metals from sea water by column electrolysis for neutron activation γ-spectrometry. Anal Chim Acta 149:67–75.
NAS. 1977. Table 1. Nutrient requirements of rabbits fed ad libitum (percentage or amount per kg of diet). In: Nutrient requirements of rabbits. National Academy of Sciences. National Research Council, 14. http://www.nap.edu/catalog/35/nutrient-requirements-of-rabbits-second-revised-edition-1977. September 24, 2015.
NAS. 1995. Nutrient requirements of laboratory animals, fourth revised edition, 1995. National Academy of Sciences. National Research Council. 11–102. http://www.nap.edu/catalog/4758/nutrient-requirements-of-laboratory-animals-fourth-revised-edition-1995. September 24, 2015.
NAS. 2001. Molybdenum. In: Dietary reference intakes for vitamin A, vitamin K, arsenic, boron, chromium, copper, iodine, iron, manganese, molybdenum, nickel, silicon, vanadium, and zinc. Washington, DC: National Academies Press, 420–439.
NAS. 2018. Prospects for molybdenum-99 future supply. In: Opportunities and Approaches for Supplying Molybdenum-99 and Associated Medical Isotopes to Global Markets: Proceedings of a Symposium. Washington, DC: The National Academies Press, 29–41. 10.17226/24909.
NAS/NRC. 1989. Report of the oversight committee. Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press. 15–35.
Nederbragt H. 1980. The influence of molybdenum on the copper metabolism of the rat at different Cu levels of the diet. Br J Nutr 43(2):329–338.7378340
Nederbragt H. 1982. Changes in the distribution of copper and molybdenum after Mo administration and subsequent additional oral or intraperitoneal Cu administration to rats. Br J Nutr 48(2):353–364.7115661
NIH. 2019. Molybdenum. Fact sheet for health professionals. National Institutes of Health. https://ods.od.nih.gov/factsheets/Molybdenum-HealthProfessional/#en25.
NIOSH. 1994a. Molybdenum (insoluble compounds, as Mo). Immediately Dangerous to Life or Health Concentrations (IDLH). Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. https://www.cdc.gov/niosh/idlh/7439987.html. November 5, 2018.
NIOSH. 1994b. Molybdenum (soluble compounds, as Mo). Immediately Dangerous to Life or Health Concentrations (IDLH). Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. https://www.cdc.gov/niosh/idlh/moly-mo.html. December 18, 2018.
NIOSH. 2016a. Molybdenum (insoluble compounds, as Mo). NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. https://www.cdc.gov/niosh/npg/npgd0433.html. November 5, 2018.
NIOSH. 2016b. Molybdenum (soluble compounds, as Mo). NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. https://www.cdc.gov/niosh/npg/npgd0434.html. December 18, 2018.
NIOSH. 2018. Appendix D - Substances with no established RELs. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. https://www.cdc.gov/niosh/npg/nengapdxd.html. April 15, 2019.
Nishioka H. 1975. Mutagenic activities of metal compounds in bacteria. Mutat Res 31(3):185–190.805366
NJDOH. 2009. Hazardous substance fact sheet. Ammonium molybdate. New Jersey Department of Health. http://nj.gov/health/eoh/rtkweb/documents/fs/0105.pdf. November 13, 2015.
NLM. 2019. ChemIDplus: Tiomolibdate diammonium, 15060–55-6. U.S. National Library of Medicine. https://chem.nlm.nih.gov/chemidplus/rn/15060-55-6. June 10, 2019.
NLM. 2020a. PubChem: Molybdenum. U.S. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/23932. April 1, 2020.
NLM. 2020b. PubChem: Molybdenum disulfide. U.S. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/14823. April 1, 2020.
NLM. 2020c. PubChem: Molybdenum trioxide. U.S. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/14802. April 1, 2020.
NLM. 2020d. PubChem: Sodium molybdate. U.S. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/61424. April 1, 2020.
NLM. 2020e. ChemIDplus: Ammonium molybdate, 12054–85-2. U.S. National Library of Medicine. https://chem.nlm.nih.gov/chemidplus/rn/12054-85-2. April 1, 2020.
NOAA. 2015. CAMEO Chemicals version 2.4.2. Molybdenum trioxide. CAS Number: 1313–27-5. National Oceanic and Atmospheric Administration. http://cameochemicals.noaa.gov/chemical/8862. November 12, 2015.
Novotny JA, Turnlund JR. 2006. Molybdenum kinetics in men differ during molybdenum depletion and repletion. J Nutr 136(4):953–957.16549456
Novotny JA, Turnlund JR. 2007. Molybdenum intake influences molybdenum kinetics in men. J Nutr 137(1):37–42.17182798
NRC. 2018. Standards for protection against radiation. Appendix B to part 20 - Annual limits on intake (ALIS) and derived air concentrations (DACS) of radionuclides for occupational exposure; effluent concentrations; concentrations for release to sewerage. Code of Federal Regulations 10 CFR 20 App B. U.S. Nuclear Regulatory Commission. https://www.govinfo.gov/content/pkg/CFR-2018-title10-vol1/pdf/CFR-2018-title10-vol1-part20-appB.pdf. December 20, 2018.
+NTP. 1997. Toxicology and carcinogenesis studies of molybdenum trioxide in F344/N rats and B6C3F1 mice (inhalation studies). Research Triangle Park, NC: National Toxicology Program. TR-263. https://ntp.niehs.nih.gov/ntp/htdocs/lt_rpts/tr462.pdf. April 26, 2019.
NTP. 2013. Draft OHAT approach for systematic review and evidence integration for literature-based health assessments- February 2013. National Toxicology Program.
NTP. 2015. Handbook for conducting a literature-based health assessment using OHAT approach for systematic review and evidence integration. National Toxicology Program. http://ntp.niehs.nih.gov/ntp/ohat/pubs/handbookjan2015_508.pdf. October 2, 2015.
NTP. 2016. Report on carcinogens, Fourteenth edition. CASRN Index in MS Excel. Research Triangle Park, NC: National Toxicology Program. https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html#P. March 1, 2017.
Nusbaum RE, Butt EM, Gilmour TC, 1965. Relation of air pollutants to trace metals in bone. Arch Environ Health 10:227–232.14232906
OECD. 2013. SIDS initial assessment profile. Highly soluble molybdenum salts. Business and Industry Advisory Committee to the OECD. http://webnet.oecd.org/HPV/UI/handler.axd?id=7feeff59-de60-4000-8d08-f3c9c7770149. November 13, 2015.
Ogawa HI, Shibahara T, Iwata H, 1994. Genotoxic activities in vivo of cobaltous chloride and other metal chlorides as assayed in the Drosophila wing spot test. Mutat Res 320(1–2):133–140.7506380
Olivier P, Marzin D. 1987. Study of the genotoxic potential of 48 inorganic derivatives with the SOS chromotest. Mutat Res 189(3):263–270.3118206
OSHA. 2018a. 29CFR1910.1000: Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z-1: Limits for air contaminants Code of Federal Regulations 29 CFR 1910.1000. Occupational Safety and Health Administration. https://www.osha.gov/laws-regs/regulations/standardnumber/1910/1910.1000TABLEZ1. November 1, 2018.
OSHA. 2018b. 29CFR1915.1000: Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Air contaminants. Code of Federal Regulations 29 CFR 1915.1000. Occupational Safety and Health Administration. https://www.osha.gov/laws-regs/regulations/standardnumber/1915/1915.1000. November 1, 2018.
OSHA. 2018c. 29CFR1926.55: Safety and health regulations for construction. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Code of Federal Regulations 29 CFR 1926.55 Appendix A. Occupational Safety and Health Administration. https://www.osha.gov/laws-regs/regulations/standardnumber/1926/1926.55AppA. November 1, 2018.
+Ostrom CA, Van Reen R, Miller CW. 1961. Changes in the connective tissue of rats fed toxic diets containing molybdenum. J Dent Res 40:520–528. 10.1177/00220345610400032001.
+Ott HC, Prior C, Herold M, 2004. Respiratory symptoms and bronchoalveolar lavage abnormalities in molybdenum exposed workers. Wien Klin Wochenschr 116(Suppl 1):25–30.15518088
+Pandey R, Singh SP. 2002. Effects of molybdenum on fertility of male rats. Biometals 15(1):65–72.11860024
Pandey R, Kumar R, Singh SP, 2002. Molybdenum in rat tissue. Hum Exp Toxicol 21(1):33–35. 10.1191/0960327102ht203oa.12046721
Parma E. 2009. The supply of the medical radioisotope Tc-99m/Mo-99. Recent shortages call for action in developing a domestic production capability. Albuquerque, NM: Sandia National Laboratories. SAND2009–6898P. http://local.ans.org/trinity/files/parma091106.pdf. November 13, 2015.
+Parry NM, Phillippo M, Reid MD, 1993. Molybdenum-induced changes in the epiphyseal growth plate. Calcif Tissue Int 53(3):180–186.8242470
Paschal DC, Dipietro ES, Phillips DL, 1989. Age dependence of metals in hair in a selected USA population. Environ Res 48(1):17–28.2914563
Paschal DC, Ting BG, Morrow JC, 1998. Trace metals in urine of United States residents: Reference range concentrations. Environ Res 76(1):53–59.9466897
Pennington JA, Jones JW. 1987. Molybdenum, nickel, cobalt, vanadium, and strontium in total diets. J Am Diet Assoc 87(12):1644–1650.3680822
+Peredo HA, Andrade V, Donoso AS, 2013. Sodium molybdate prevents hypertension and vascular prostanoid imbalance in fructose-overloaded rats. Auton Autacoid Pharmacol 33(3–4):43–48. 10.1111/aap.12010.23906370
+Prakash R. 1989. Glycogen in the muscles of rats poisoned by metal ions. Arh Hig Rada Toksikol 40(4):363–366.2637659
+Rana SV, Chauhan A. 0~2000. Influence of methionine and zinc on liver collagen in molybdenotic rats: relationship with lipid peroxidation. Biol Trace Elem Res 73(1):85–91. 10.1385/bter:73:1:85.10949972
+Rana SV, Kumar A. 1979. Enzyme modification in rat kidney after individual and combined treatments with molybdenum and copper. Ind Health 17(1):11–19.
+Rana SV, Kumar A. 1980a. Enzymological studies on the liver of rats fed with molybdenum and copper. Toxicol Lett 6(3):163–166.7404595
+Rana SV, Kumar A. 1980b. On the lipid accumulation in molybdenotic rats. Indian J Exp Biol 18(7):726–728.7429588
+Rana SV, Kumar A. 1980c. Proteins, lipids and carbohydrates in the liver and kidney of rats after molybdenum and copper treatment. Bull Environ Contam Toxicol 25(1):146–152.7459479
+Rana SV, Kumar A. 1981. Effect of molybdenum and copper on key enzymes of rat kidney with special reference to physiological antagonism. Toxicol Lett 7(6):393–397.7245224
+Rana SV, Kumar A. 1983. Liver and kidney function in molybdenum and copper poisoning. Arh Hig Rada Toksikol 34(1):9–13.6639375
+Rana SV, Kumar A, Bhardwaj NG. 1980. Lipids in the liver and kidney of rats, fed various heavy metals. Acta Anat (Basel) 108(3):402–412.7415805
+Rana SVS, Prakash R, Kumar A, 1985. A study of glycogen in the liver of metal-fed rats. Toxicol Lett 29(1):1–4.4082201
Regoli L, Van Tilborg W, Heijerick D, 2012. The bioconcentration and bioaccumulation factors for molybdenum in the aquatic environment from natural environmental concentrations up to the toxicity boundary. Sci Total Environ 435–436:96–106. 10.1016/j.scitotenv.2012.06.020.
RePORTER. 2019. Molybdenum. National Institutes of Health, Research Portfolio Online Reporting Tools. http://projectreporter.nih.gov/reporter.cfm. April 22, 2019.
Richards P. 1989. Technetium-99m: The early days. In: DOE’s International symposium on technetium in chemistry and nuclear medicine, Padova, Italy, 5–8 Sep 1989. Upton, NY: Brookhaven National Laboratory, Medical Department, 1–12.
Riley JP, Taylor D. 1968. The use of chelating ion exchange in the determination of molybdenum and vanadium in sea water. Anal Chim Acta 41:173–175.
+Robinson GA, Valli VE, McSherry BJ, 1969. The survival of DF32 P-labelled erythrocytes in molybdate-fed rabbits. Can J Physiol Pharmacol 47(4):343–347.5772629
Robinson MF, McKenzie JM, Tomson CD, 1973. Metabolic balance of zinc, copper, cadmium, iron, molybdenum and selenium in young New Zealand women. Br J Nutr 30(2):195–205.4746683
+Rodriguez CR Flores, Puga MP, Wrobel K, 2011. Trace elements status in diabetes mellitus type 2: Possible role of the interaction between molybdenum and copper in the progress of typical complications. Diabetes Res Clin Pract 91(3):333–341. 10.1016/j.diabres.2010.12.014.21211861
Rooney AA, Boyles AL, Wolfe MS, 2014. Systematic review and evidence integration for literature-based environmental health science assessments. Environ Health Perspect 122(7):711–718.24755067
Roper C. 2008. The in-vitro percutaneous absorption of molybdenum through human skin. London, England: International Molybdenum Association.
Rosoff B, Spencer H. 1964. Fate of molybdenum-99 in man. Nature 202:410–411.14152844
Rossipal E, Krachler M. 1998. Pattern of trace elements in human milk during the course of lactation. Nutr Res 18(1):11–24.
Rossman TG, Molina M, Meyer LW. 1984. The genetic toxicology of metal compounds: I. Induction of lambda prophage in E. coli WP2S. Environ Mutagen 6(1):59–69.6229401
Rumble J, Lide D, Bruno T. 2018. Atomic masses and abundances. In: CRC Handbook of chemistry and physics. 99^th^ ed. Boca Raton, FL: Taylor & Francis Group, LLC, 1–13.
Ryan J, McKillen M, Mason J. 1987. Sulphate/molybdate interactions: in vivo and in vitro studies on the group VI oxyanion transport system in ovine renal tubule epithelial cells. Ann Rech Vet 18(1):47–55 3579182
Sardesai VM. 1993. Molybdenum: an essential trace element. Nutr Clin Pract 8(6):277–281. 10.1177/0115426593008006277.8302261
+Sasmal N, Kar NC, Mukherjee D, 1968. The effect of molybdenum on ascorbic acid metabolism in rats. Biochem J 106(3):633–637.5639920
+Schroeder HA, Kraemer LA. 0∼1974. Cardiovascular mortality, municipal water, and corrosion. Arch Environ Health 28:303–311.4829083
+Schroeder HA, Mitchener M. 1971. Toxic effects of trace elements on the reproduction of mice and rats. Arch Environ Health 23(2):102–106.5558140
Schroeder HA, Balassa JJ, Tipton IH. 1970. Essential trace metals in man: Molybdenum. J Chronic Dis 23:481–499.26309918
Schwarz G, Mendel RR, Ribbe MW. 2009. Molybdenum cofactors, enzymes and pathways. Nature 460:839–847 19675644
Sebenik RF, Burkin AR, Dorfler RR, 2012. Molybdenum and molybdenum compounds. In: Ullmann’s encyclopedia of industrial chemistry. John Wiley & Sons, Inc, 522–566. 10.1002/14356007.a16_655/abstract.
+Shirai S, Suzuki Y, Yoshinaga J, 2010. Maternal exposure to low-level heavy metals during pregnancy and birth size. J Environ Sci Health A Tox Hazard Subst Environ Eng 45(11):1468–1474. 10.1080/10934529.2010.500942.20694885
+Shiue I, Hristova K. 2014. Higher urinary heavy metal, phthalate and arsenic concentrations accounted for 3–19% of the population attributable risk for high blood pressure: US NHANES, 2009–2012. Hypertens Res 37(12):1075–1081. 10.1038/hr.2014.121.25077919
Sievers E, Dorner K, Garbe-Schonberg D, 2001a. Molybdenum metabolism: Stable isotope studies in infancy. J Trace Elem Med Biol 15(2–3):185–191. 10.1016/s0946-672x(01)80065-1.11787987
Sievers E, Oldigs HD, Dorner K, 2001b. Molybdenum balance studies in premature male infants. Eur J Pediatr 160(2):109–113.11271381
Sigma-Aldrich. 2015. Ammonium tetrathiomolybdate. Safety data sheet. Version 4.8. Sigma-Aldrich. http://www.sigmaaldrich.com/MSDS/MSDS/DisplayMSDSPage.do?country=US&language=en&productNumber=323446&brand=ALDRICH&PageToGoToURL=http%3A%2F%2Fwww.sigmaaldrich.com%2Fcatalog%2Fproduct%2Faldrich%2F323446%3Flang%3Den. November 13, 2015.
Singh I. 1983. Induction of reverse mutation and mitotic gene conversion by some metal compounds in saccharomyces cerevisiae. Mutat Res 117:149–152.6339905
Skierszkan EK, Mayer KU, Weis D, 2016. Molybdenum and zinc stable isotope variation in mining waste rock drainage and waste rock at the Antamina mine, Peru. Sci Total Environ 550:103–113. 10.1016/j.scitotenv.2016.01.053.26808401
Smedley PL, Kinniburgh DG. 2017. Molybdenum in natural waters: A review of occurrence, distributions and controls. Appl Geochem 84:387–432. 10.1016/j.apgeochem.2017.05.008.
Smedley PL, Cooper DM, Lapworth DJ. 2014. Molybdenum distributions and variability in drinking water from England and Wales. Environ Monit Assess 186:6403–6416. 10.107/s10661-014-3863-x.25012143
Solongo T, Fukushi K, Altansukh O, 2018. Distribution and chemical speciation of molybdenum in river and pond sediments affected by mining activity in Erdenet City, Mongolia. Minerals 8(7):288. 10.3390/min8070288.
Sorensen LB, Archambault M. 1963. Visualization of the liver by scanning with Mo-99 (molybdate) as tracer. J Lab Clin Med 62:330–340.14057883
+Spence JA, Suttle NF, Wenham G, 1980. A sequential study of the skeletal abnormalities which develop in rats given a small dietary supplement of ammonium tetrathiomolybdate. J Comp Pathol 90(1):139–153.7391276
Stiefel EI. 2011. Molybdenum compounds. In: Kirk-Othmer encyclopedia of chemical technology. John Wiley & Sons., 10.1002/0471238961.1315122519200905.a01.pub3.
Sumino K, Hayakawa K, Shibata T, 1975. Heavy metals in normal Japanese tissues: Amounts of 15 heavy metals in 30 subjects. Arch Environ Health 30(10):487–494.1180571
Taylor H. 2009. Induction of micronuclei in cultured human peripheral blood lymphocytes. London, England: International Molybdenum Association.
Tejada-Jimenez M, Galvan A, Fernandez E. 2011. Algae and humans share a molybdate transporter. Proc Natl Acad Sci USA 108(16):6420–6425. 10.1073/pnas.1100700108.21464289
Tejada-Jimenez M, Llamas A, Sanz-Luque E, 2007. A high-affinity molybdate transporter in eukaryotes. Proc Natl Acad Sci USA 104(50):20126–20130. 10.1073/pnas.0704646104.18077439
Telfer SB, Kendall NR, Illingworth DV, 2004. Molybdenum toxicity in cattle: An underestimated problem. Cattle Prac 12:259–263.
Terpilowska S, Siwicki AK. 2019. Pro- and antioxidant activity of chromium(III), iron(III), molybdenum(III) or nickel(II) and their mixtures. Chem Biol Interact 298:43–51. 10.1016/j.cbi.2018.10.028.30389395
The White House. 2012. Fact Sheet: Encouraging reliable supplies of molybdenum-99 produced without highly enriched uranium. Washington, DC: The White House. https://www.whitehouse.gov/the-press-office/2012/06/07/fact-sheet. May 24, 2016.
Thompson KH, Scott KC, Turnlund JR. 1996. Molybdenum metabolism in men with increasing molybdenum intakes: changes in kinetic parameters. J Appl Physiol 81(3):1404–1409.8889780
Tipton IH, Cook MJ. 1963. Trace elements in human tissue Part II. Adult subjects from the United States. Health Phys 9:103–145.13985137
Tipton I, Stewart PL, Martin PG. 1966. Trace elements in diets and excreta. Health Phys 12(12):1683–1689.
Tipton IH, Schroeder HA, Perry HM, 1965. Trace elements in human tissue. Part III. Subjects from Africa, the Near and Far East and Europe. Health Phys 11:403–451.14313682
Titenko-Holland N, Shao J, Zhang L, 1998. Studies on the genotoxicity of molybdenum salts in human cells in vitro and mice in vivo. Environ Mol Mutagen 32(3):251–259.9814440
TRI17. 2018. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: U.S. Environmental Protection Agency. https://www.epa.gov/toxics-release-inventory-triprogram/tri-data-and-tools. November 14, 2018.
Turnlund JR, Keyes WR. 2000. Dietary molybdenum. Effect on copper absorption, excretion, and status in young men. In: Trace elements in man and animals. New York, NY: Plenum Publishers, 951–953.
Turnlund JR, Keyes WR. 2004. Plasma molybdenum reflects dietary molybdenum intake. J Nutr Biochem 15(2):90–95. 10.1016/j.jnutbio.2003.10.003.14972348
Turnlund JR, Keyes WR, Peiffer GL. 1995a. Molybdenum absorption, excretion, and retention studied with stable isotopes in young men at five intakes of dietary molybdenum. Am J Clin Nutr 62(4):790–796.7572711
Turnlund JR, Keyes WR, Peiffer GL, 1995b. Molybdenum absorption, excretion, and retention studied with stable isotopes in young men during depletion and repletion. Am J Clin Nutr 61(5):1102–1109.7733035
Ulitzur S, Barak M. 1988. Detection of genotoxicity of metallic compounds by the bacterial bioluminescence test. J Biolumin Chemilumin 2:95–99.3213595
USGS. 1964. Public water supplies of the 100 largest cities in the United States, 1962. Geological survey water-supply paper 1812. Washington, DC: U.S. Geological Survey. http://pubs.usgs.gov/wsp/1812/report.pdf. October 2, 2015.
USGS. 2006. Review of trace element blank and replicate data collected in ground and surface water for the National Water-Quality Assessment Program, 1991–2002. Scientific Investigations Report 2006–5093. U.S. Geological survey. https://pubs.er.usgs.gov/publication/sir20065093. June 12, 2019.
USGS. 2011. Trace elements and radon in groundwater across the United States, 1992–2003. Scientific investigations report 2011–5059. U.S. Geological Survey. http://pubs.usgs.gov/sir/2011/5059/pdf/sir2011-5059_report-covers_508.pdf. November 13, 2015.
USGS. 2014. Geochemical and mineralogical maps for soils of the conterminous United States. Reston, VA: U.S. Geological Survey. 10.3133/ofr20141082
USGS. 2015a. Molybdenum [advance release]. 2013 Minerals yearbook U.S. Geological Survey. 50.51–50.12. http://minerals.usgs.gov/minerals/pubs/commodity/molybdenum/myb1-2013-molyb.pdf. October 2, 2015.
USGS. 2015b. Molybdenum. Mineral commodity summaries, January 2015. U.S. Geological Survey. http://minerals.usgs.gov/minerals/pubs/commodity/molybdenum/index.html#mcs. November 24, 2015.
USGS. 2019. Molybdenum in March 2019. Mineral industry surveys. Reston, VA: U.S. Geological Survey. https://prd-wret.s3-us-west-2.amazonaws.com/assets/palladium/production/atoms/files/mis-201903-molyb.pdf. June 7, 2019.
USNRC. 2015. Molybdenum-99 production and its impact on the medical community. U.S. Nuclear Regulatory Commission. http://www.nrc.gov/reading-rm/doc-collections/commission/slides/2015/20150414/palestro-20150414.pdf. January 14, 2015.
USNRC. 2016a. Part 20- Standards for protection against radiation. Subpart A to Subpart O. Code of Federal Regulations. 10 CFR 20. U.S. Nuclear Regulatory Commission. http://www.nrc.gov/reading-rm/doc-collections/cfr/part020/full-text.html. May 24, 2016.
USNRC. 2016b. Part 35- Medical use of byproduct material. Code of Federal Regulations. 10 CFR 35. U.S. Nuclear Regulatory Commission. http://www.nrc.gov/reading-rm/doc-collections/cfr/part035/full-text.html. May 24, 2016.
+Valli VE, McCarter A, McSherry BJ, 1969. Hematopoiesis and epiphyseal growth zones in rabbits with molybdenosis. Am J Vet Res 30(3):435–445.5766739
Van Noorden R. 2013. The medical testing crisis. With a serious shortage of medical isotopes looming, innovative companies are exploring ways to make them without nuclear reactors. Nature (London) New Biol 504:202–204.24336269
+Van Reen R. 1959. The specificity of the molybdate-sulfate interrelationship in rats. J Nutr 68(2):243–250.13665411
+Van Reen R, Williams MA. 1956. Studies on the influence of sulfur compounds on molybdenum toxicity in rats. Arch Biochem Biophys 63(1):1–8.13341036
+Van Reen R, Ostrom CA, Berzinskas VJ. 1962. Studies of the possible cariostatic effect of sodium molybdate. Arch Oral Biol 7:351–356.13924619
+Vazquez-Salas RA, Lopez-Carrillo L, Menezes-Filho JA, 2014. Prenatal molybdenum exposure and infant neurodevelopment in Mexican children. Nutr Neurosci 17(2):72–80. 10.1179/1476830513y.0000000076.24479423
Vyskocil A, Viau C. 1999. Assessment of molybdenum toxicity in humans. J Appl Toxicol 19(3):185–192.10362269
Wahl B, Reichmann D, Niks D, 2010. Biochemical and spectroscopic characterization of the human mitochondrial amidoxime reducing components hmARC-1 and hmARC-2 suggests the existence of a new molybdenum enzyme family in eukaryotes. J Biol Chem 285(48):37847–37859. 10.1074/jbc.M110.169532.20861021
+Walravens PA, Moure-Eraso R, Solomons CC, 1979. Biochemical abnormalities in workers exposed to molybdenum dust. Arch Environ Health 34(5):302–308.496425
Wang S, Ge H, Sun S, 2015. A new molybdenum nitride catalyst with rhombohedral MoS2 structure for hydrogenation applications. J Am Chem Soc 137:4815–4822.25799018
+Wang HW, Zhou BH, Zhang S, 2016. Reproductive toxicity in male mice after exposure to high molybdenum and low copper concentrations. Toxicol Ind Health 32(9):1598–1606. 10.1177/0748233715569269.25691499
Wappelhorst O, Kuhn I, Heidenreich H, 2002. Transfer of selected elements from food into human milk. Nutrition 18:316–322.11934544
WDNR. 2013. Caledonia groundwater molybdenum investigation: Southeast Wisconsin. Wisconsin Department of Natural Resources. PUB-WA 1625. http://dnr.wi.gov/files/PDF/pubs/WA/WA1625.pdf. November 24, 2015.
Welsh JA, Bigles CI, Valderrabano A. 2015. Future U.S. supply of Mo-99 production through fission based LEU/LEU technology. J Radioanal Nucl Chem 305:9–12.26224990
Werner E, Giussani A, Heinrichs U, 1998. Biokinetic studies in humans with stable isotopes as tracers. Part 2: Uptake of molybdenum from aqueous solutions and labelled foodstuffs. Isotopes Environ Health Stud 34(3):297–301. 10.1080/10256019808234063.9919682
Werner E, Roth P, Heinrichs U, 2000. Internal biokinetic behaviour of molybdenum in humans studied with stable isotopes as tracers. Isotopes Environ Health Stud 36(2):123–132. 10.1080/10256010008032938.11077927
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. April 25, 2012.
WHO. 2017. Guidelines for drinking-water quality. Fourth edition incorporating the first addendum. Geneva, Switzerland: World Health Organization. https://apps.who.int/iris/bitstream/handle/10665/254637/9789241549950-eng.pdf?sequence=1. February 28, 2017.
+Widjajakusuma MC, Basrur PK, Robinson GA. 1973. Thyroid function in molybdenotic rabbits. J Endocrinol 57(3):419–424.4715721
+Williams MA, Van Reen R. 1956. Molybdenum toxicity in the rat. Proc Soc Exp Biol Med 91(4):638–641.13323031
+Yang MT, Yang SP. 1989. Effect of molybdenum supplementation on hepatic trace elements and enzymes of female rats. J Nutr 119(2):221–227.2918395
Yoo YC, Lee SK, Yang JY, 2002. Organ distribution of heavy metals in autopsy material from normal Korean. J Health Sci 48(2):186–194.
+Yorita Christensen KL. 2013. Metals in blood and urine, and thyroid function among adults in the United States 2007–2008. Int J Hyg Environ Health 216(6):624–632. 10.1016/j.ijheh.2012.08.005.23044211
Yoshida M, Hattori H, Ota S, 2006. Molybdenum balance in healthy young Japanese women. J Trace Elem Med Biol 20(4):245–252. 10.1016/j.jtemb.2006.07.004.17098584
Zeiger E, Anderson B, Haworth S, 1992. Salmonella mutagenicity tests: V. Results from the testing of 311 chemicals. Environ Mol Mutagen 21:2–141.
Zeisler R, Greenberg RR, Stone SF. 1988. Radiochemical and instrumental neutron activation analysis procedures for the determination of low level trace elements in human livers. J Radioanal Nucl Chem 124(1):47–63.
Zeng Y, Feng W, Li J, 2014. A prospective study concerning the relationship between metal allergy and post-operative pain following total hip and knee arthroplasty. Int Orthop 38(11):2231–2236. 10.1007/s00264-014-2367-1.24910214
+Zhai XW, Zhang YL, Qi Q, 2013. Effects of molybdenum on sperm quality and testis oxidative stress. Syst Biol Reprod Med 59(5):251–255. 10.3109/19396368.2013.791347.23651332
+Zhang Y-L, Liu F-J, Chen X-L, 2013. Dual effects of molybdenum on mouse oocyte quality and ovarian oxidative stress. Syst Biol Reprod Med 59(6):312–318. 10.3109/19396368.2013.826296.23947923
Zhuang Y, Liu P, Wang L, 2016. Mitochondrial oxidative stress-induced hepatocyte apoptosis reflects increased molybdenum intake in caprine. Biol Trace Elem Res 170(1):106–114. 10.1007/s12011-015-0450-0.26208811