# CONTRIBUTORS & REVIEWERS

## CHEMICAL MANAGER TEAM

- G. Daniel Todd, Ph.D. (Lead)
  Sam Keith, M.S., C.H.P.
  Obaid Faroon, D.V.M., Ph.D.
  Melanie Buser, M.P.H.
- ATSDR, Division of Toxicology and Human Health Sciences, Atlanta, GA
- Lisa Ingerman, Ph.D., D.A.B.T.
  Mario Citra, Ph.D.
  Gary L. Diamond, Ph.D.
  Courtney Hard, B.A.
  Julie M. Klotzbach, Ph.D.
  Amy Nguyen, Ph.D.
- SRC, Inc., North Syracuse, NY

## REVIEWERS

Interagency Minimal Risk Level Workgroup:

Includes ATSDR; National Center for Environmental Health (NCEH); National Institute for Occupational Health and Safety (NIOSH); U.S. Environmental Protection Agency (EPA); National Toxicology Program (NTP).

Additional reviews for science and/or policy:

ATSDR, Division of Community Health Investigations; ATSDR, Office of Science; NCEH, Division of Laboratory Science; NCEH, Division of Environmental Health Science and Practice; EPA, Office of Water.

## PEER REVIEWERS

1. David C. Dorman, DVM, Ph.D., DABT, DABVT, Professor, Toxicology, North Carolina State University, Raleigh, North Carolina
2. Jonathan H Freedman, Ph.D., Professor, Department of Pharmacology and Toxicology, University of Louisville School of Medicine, Louisville, Kentucky
3. Michael Aschner, Ph.D., Department of Molecular Pharmacology, Albert Einstein College of Medicine, Bronx, New York
4. John Meeker, Sc.D., C.I.H., Professor, Environmental Health Sciences, Associate Dean for Research, School of Public Health, University of Michigan, Ann Arbor, Michigan
5. Alexander V. Lyubimov, M.D., Ph.D., D.A.B.T., Toxicology Research Laboratory, Chicago, Illinois
6. Dagobert Heijerick, ARCHE consulting, Gent, Belgium

These experts collectively have knowledge of toxicology, chemistry, and/or health effects. All reviewers were selected in conformity with Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

ATSDR scientists review peer reviewers’ comments and determine whether changes will be made to the profile based on comments. The peer reviewers’ comments and responses to these comments are part of the administrative record for this compound.

The listing of peer reviewers should not be understood to imply their approval of the profile’s final content. The responsibility for the content of this profile lies with ATSDR.