# VERSION HISTORY

Date | Description
May 2020 | Final toxicological profile released
April 2017 | Draft for public comment toxicological profile released