# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding molybdenum in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for molybdenum.

Table 7-1 Regulations and Guidelines Applicable to Molybdenum

Agency | Description | Information | Reference
Air
EPA | RfC | No data | IRIS 2003
WHO | Air quality guidelines | Not listed | WHO 2010
Water & Food
EPA | Drinking water standards and health advisories for molybdenum | | EPA 2018a
EPA | | | EPA 2018a
EPA | 1-Day health advisory (10-kg child) | 0.08 mg/L | EPA 2018a
EPA | | | EPA 2018a
EPA | 10-Day health advisory (10-kg child) | 0.08 mg/L | EPA 2018a
EPA | | | EPA 2018a
EPA | DWEL | 0.2 mg/L | EPA 2018a
EPA | | | EPA 2018a
EPA | Lifetime health advisory | 0.04 mg/L | EPA 2018a
EPA
EPA | National primary drinking water regulations | Not listed | EPA 2009b
EPA
EPA | RfD (molybdenum) | 5×10^−3^ mg/kg/day^a^ | IRIS 2003
WHO | Drinking water quality guidelines | Not established^b^ | WHO 2017
FDA | Substances added to food | Not listed^c^ | FDA 2018
USNRC | Annual limit on intake, oral ingestion | | NRC 2018
USNRC | | | NRC 2018
USNRC | ^99^Molybdenum compounds except oxides, hydroxides, and molybdenum disulfide | 2×10^3^ μCi | NRC 2018
Cancer
HHS | Carcinogenicity classification | No data | NTP 2016
EPA | Carcinogenicity classification | No data | IRIS 2003
IARC | Carcinogenicity classification; Molybdenum trioxide | Group 2B^d^ | IARC 2018
Occupational
OSHA | PEL (8-hour TWA) for general industry, shipyards and construction (molybdenum, as molybdenum) | | OSHA 2018a, 2018c
OSHA | Soluble compounds | 5 mg/m^3^ | OSHA 2018a, 2018c
OSHA | Insoluble compounds, total dust | 15 mg/m^3^ | OSHA 2018a, 2018c
NIOSH | REL (up to 10-hour TWA) | Not established^e^ | NIOSH 2016a, 2016b
NIOSH
NIOSH | IDLH (molybdenum, as molybdenum)
NIOSH | Soluble compounds | 1,000 mg Mo/m^3^ | NIOSH 1994a
NIOSH | Insoluble compounds | 5,000 mg Mo/m^3^ | NIOSH 1994b
USNRC | Annual limit on intake, inhalation | | NRC 2018
USNRC | ^99^Molybdenum compounds except oxides, hydroxides, and molybdenum disulfide | 3×10^3^ μCi | NRC 2018
USNRC | | | NRC 2018
USNRC | Derived air concentration | | NRC 2018
USNRC | ^99^Molybdenum compounds except oxides, hydroxides, and molybdenum disulfide | 1×10^−6^ μCi/mL | NRC 2018
Emergency Criteria
EPA | AEGLs-air | No data | EPA 2016
DOE | PACs-air | | DOE 2018b
DOE | | | DOE 2018b
DOE | PAC-1^f^ | | DOE 2018b
DOE | Molybdenum | 30 mg/m^3^ | DOE 2018b
DOE | Ammonium heptamolybdate | 2.6 mg/m^3^ | DOE 2018b
DOE | Ammonium molibdate | 3.5 mg/m^3^ | DOE 2018b
DOE | Ammonium molybdate(VI) tetrahydrate | 2.8 mg/m^3^ | DOE 2018b
DOE | Diammonium dimolybdate | 2.6 mg/m^3^ | DOE 2018b
DOE | Diammonium molybdate | 3.1 mg/m^3^ | DOE 2018b
DOE | Disodium molybdate | 3.2 mg/m^3^ | DOE 2018b
DOE | Molybdenum carbide | 34 mg/m^3^ | DOE 2018b
DOE | Molybdenum dioxide | 40 mg/m^3^ | DOE 2018b
DOE | Molybdenum hexacarbonyl | 83 mg/m^3^ | DOE 2018b
DOE | Molybdenum pentachloride | 4.3 mg/m^3^ | DOE 2018b
DOE | Molybdenum trioxide | 2.3 mg/m^3^ | DOE 2018b
DOE | Molybdenum(IV) sulfide | 50 mg/m^3^ | DOE 2018b
DOE | Sodium molybdate dihydrate | 3.8 mg/m^3^ | DOE 2018b
DOE | | | DOE 2018b
DOE | PAC-2^f^ | | DOE 2018b
DOE | Molybdenum | 330 mg/m^3^ | DOE 2018b
DOE | Ammonium heptamolybdate | 230 mg/m^3^ | DOE 2018b
DOE | Ammonium molibdate | 290 mg/m^3^ | DOE 2018b
DOE | Ammonium molybdate(VI) tetrahydrate | 30 mg/m^3^ | DOE 2018b
DOE | Diammonium dimolybdate | 29 mg/m^3^ | DOE 2018b
DOE | Diammonium molybdate | 22 mg/m^3^ | DOE 2018b
DOE | Disodium molybdate | 17 mg/m^3^ | DOE 2018b
DOE | Molybdenum carbide | 360 mg/m^3^ | DOE 2018b
DOE | Molybdenum dioxide | 430 mg/m^3^ | DOE 2018b
DOE | Molybdenum hexacarbonyl | 920 mg/m^3^ | DOE 2018b
DOE | Molybdenum pentachloride | 410 mg/m^3^ | DOE 2018b
DOE | Molybdenum trioxide | 43 mg/m^3^ | DOE 2018b
DOE | Molybdenum(IV) sulfide | 260 mg/m^3^ | DOE 2018b
DOE | Sodium molybdate dihydrate | 34 mg/m^3^ | DOE 2018b
DOE | | | DOE 2018b
DOE | PAC-3^f^ | | DOE 2018b
DOE | Molybdenum | 2,000 mg/m^3^ | DOE 2018b
DOE | Ammonium heptamolybdate | 1,400 mg/m^3^ | DOE 2018b
DOE | Ammonium molibdate | 1,700 mg/m^3^ | DOE 2018b
DOE | Ammonium molybdate(VI) tetrahydrate | 180 mg/m^3^ | DOE 2018b
DOE | Diammonium dimolybdate | 170 mg/m^3^ | DOE 2018b
DOE | Diammonium molybdate | 130 mg/m^3^ | DOE 2018b
DOE | Disodium molybdate | 100 mg/m^3^ | DOE 2018b
DOE | Molybdenum carbide | 2,200 mg/m^3^ | DOE 2018b
DOE | Molybdenum dioxide | 2,600 mg/m^3^ | DOE 2018b
DOE | Molybdenum hexacarbonyl | 5,500 mg/m^3^ | DOE 2018b
DOE | Molybdenum pentachloride | 2,400 mg/m^3^ | DOE 2018b
DOE | Molybdenum trioxide | 260 mg/m^3^ | DOE 2018b
DOE | Molybdenum(IV) sulfide | 1,600 mg/m^3^ | DOE 2018b
DOE | Sodium molybdate dihydrate | 210 mg/m^3^ | DOE 2018b

a The RfD is based on a LOAEL of 0.14 mg/kg/day for increased uric acid levels in humans (Koval’skiy et al. 1961).

b Reason for not establishing guideline value: occurs in drinking water at concentrations well below those of health concern.

c The Substances Added to Food inventory replaces EAFUS and contains the following types of ingredients: food and color additives listed in FDA regulations, flavoring substances evaluated by FEMA or JECFA, GRAS substances listed in FDA regulations, substances approved for specific uses in food prior to September 6, 1958, substances that are listed in FDA regulations as prohibited in food, delisted color additives, and some substances “no longer FEMA GRAS.”

d Group 2B: possibly carcinogenic to humans.

e In 1988, NIOSH provided comments to OSHA in which NIOSH questioned whether proposed PELs for particular substances, including the TWA 5 mg/m^3^ PEL for molybdenum (soluble compounds as molybdenum), were adequate to protect workers from recognized health hazards. At that time, NIOSH also concluded that the documentation cited by OSHA was inadequate to support a proposed PEL of 10 mg/m^3^ for particular substances including molybdenum (insoluble compounds as molybdenum) (NIOSH 2018).

f Definitions of PAC terminology are available from U.S. Department of Energy (DOE 2018a).

AEGL = acute exposure guideline level; DOE = Department of Energy; DWEL = drinking water equivalent level; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; FEMA = Flavor and Extract Manufacturers Association; GRAS = generally recognized as safe; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; JECFA = Joint FAO/WHO Expert Committee on Food Additives; LOAEL = lowest-observed-adverse-effect level; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PEL = permissible exposure limit; REL = recommended exposure limit; RfD = oral reference dose; TWA = time-weighted average; USNRC = U.S. Nuclear Regulatory Commission; WHO = World Health Organization