# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Molybdenum (Mo) is a naturally occurring metallic trace element found in natural minerals, but not as the free metal. Biologically, it is an important micronutrient in plants and animals, including humans. It is used widely in industry for metallurgical applications (EPA 1979).

Molybdenum metal is a dark-gray or black powder with a metallic luster (NLM 2020a). It is a transition element in Group 6 of the Periodic Table. It has oxidation states from −2 to +6. Commonly encountered compounds are those of molybdenum in oxidation state +6 (Mo(VI), MoO_3_, molybdates) and +4 (Mo(IV), MoS_2_). It does not occur naturally in the pure metallic form; it more commonly occurs in the mineral, molybdenite (Sebenik et al. 2012). Other naturally occurring molybdenum-containing minerals are powellite, wulfenite, ferrimolybdite, and ilsemannite; however, molybdenite is the primary commercial source of molybdenum. Molybdenum (VI) anions include molybdate (MoO_4_^−2^) with molybdenum at the center of a tetrahedron of four oxygen atoms, and polyberic anions (‘isopolymolybdates’) of which the most common are heptamolybdate (Mo_7_O_24_^6−^) and octamolybdate (Mo_8_O_26_^4−^) (EPA 1979). These anions occur in sodium and ammonium salts, often hydrated, which are the common sources of molybdenum in commerce and industrial applications.

There are 33 known isotopes of molybdenum. Seven isotopes occur naturally: mass numbers 92, 94, 95, 96, 97, 98, and 100. ^98^Mo is the most abundant isomer, comprising approximately 24.3% (Rumble et al. 2018). Radioisotopes of masses 83–91, 93, 99, and 101–115 have been reported. The only one of major worldwide importance is Mo-99 (^99^Mo), a 100% beta-emitting isotope with a 65.976-hour radioactive half-life that is used to produce technetium-99m (Tc-99^m^ or ^99m^Tc) for medical scans (Doll et al. 2014; Parma 2009; Richards 1989).

Under physiological conditions (pH >6.5), the molybdate anion, [MoO_4_]^2−^, is the sole molybdenum species in aqueous media (Cruywagen 2000; Cruywagen et al. 2002). Molybdenum compounds (e.g., molybdenum trioxide and polymolybdates) transform rapidly to the [MoO_4_]^2−^ ion under environmentally relevant test conditions (Deltombe et al. 1974; Greenwood and Earnshaw 1997). Protonated forms, such as [HMoO_4_]^−^ and H_2_MoO_4_, are found at pH <5 (Smedley and Kinniburgh 2017). Molybdenum tends to be more mobile under alkaline conditions, but adsorption increases with decreasing pH (Goldberg et al. 2002).

Information regarding the chemical identity of molybdenum and molybdenum compounds is provided in Table 4-1.

Table 4-1 Chemical Identity of Molybdenum and Compounds

Characteristic | | Information
Chemical name | Molybdenum^a^ | Molybdenum disulfide^b^ | Molybdenum trioxide^c^
Synonym(s) and registered trade names^d^ | MChVL; TsM1; Amperit 105.054; Amperit 106.2; Metco 63 | Molybdenite (natural mineral); molybdenum(IV) sulfide; DAG 325; Molykote | Molybdenum(VI) oxide; molybdic acid anhydride; molybdic anhydride; molybdic oxide
Chemical formula | Mo | MoS_2_ | MoO_3_
CAS Registry Number | 7439-98-7 | 1309-56-4/1317-33-5 (natural mineral form)^e^; 12612-50-9 (synthetic form) | 1313-27-5
Chemical name | Sodium molybdate^f^ | Ammonium dimolybdate | Ammonium heptamolybdate tetrahydrate^g^
Synonym(s) and registered trade names^d^ | Disodium molybdate; molybdic acid, disodium salt^e^ | Ammonium molybdenum oxide^e^ | Ammonium paramolybdate tetrahydrate; hexammonium molybdate
Chemical formula | Na_2_MoO_4_ | (NH_4_)_2_Mo_2_O_7_ | (NH_4_)_6_Mo_7_O_24_ 4H_2_O
CAS Registry Number | 7631-95-0 | 27546-07-2 | 12054-85-2/12027-67-7 (anhydrous)^h^
Chemical name | Diammonium molybdate | Ammonium tetrathiomolybdate
Synonym(s) and registered trade names^d^ | Ammonium molybdate; molybdic acid, diammonium salt^i^ | Tiomolibdate diammonium; ammonium molybdenum sulfide; ammonium tetrathiomolybdate; thiomolybdic acid, diammonium salt; Coprexa; TM; ATTM^j^
Chemical formula | (NH_4_)_2_MoO_4_ | (NH_4_)_2_MoS_4_
CAS Registry Number | 13106-76-8 | 15060-55-6

a All information in this column obtained from NLM (2020a), unless otherwise noted.

b All information in this column obtained from NLM (2020b), unless otherwise noted.

c All information in this column obtained from NLM (2020c), unless otherwise noted.

d Additional synonyms and trade names may be queried using the Common Chemistry service from Chemical Abstracts Service (http://www.commonchemistry.org/).)

e EPA 2019a.

f All information in this column obtained from NLM (2020d), unless otherwise noted.

g All information in this column obtained from NLM (2020e), unless otherwise noted.

h OECD 2013.

i EPA 2019b.

j NLM 2019.

CAS = Chemical Abstracts Service

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Metallic molybdenum, in the form of fine molybdenum powder, is considered nonflammable.

Information regarding the physical and chemical properties of molybdenum and molybdenum compounds is provided in Table 4-2. Much of the information presented was obtained from the chapter, Molybdenum and Molybdenum Compounds, in the Ullmann’s Encyclopedia of Industrial Chemistry (Sebenik et al. 2012), or handbooks such as the CRC Handbook of Chemistry and Physics or the European Chemicals Agency (ECHA) registration dossiers.

Table 4-2 Physical and Chemical Properties of Molybdenum and Compounds^a^

Property | | Information
Chemical name | Molybdenum | Molybdenite (natural mineral)/molybdenum disulfide | Molybdenum trioxide
Molecular weight | 95.94 | 160.07 | 143.95
Color | Dull gray | Black | White, turns slightly blue in light
Physical state | Powder | Crystalline solid | Crystalline solid
Melting point | 2,617°C | >1,600°C (rhombohedral crystal); did not melt at 1,800°C^b^ | 801°C
Boiling point | 4,612°C | No data | 1,155°C
Density/specific gravity | 10.22 g/cm^3^ | 5.05 g/cm^3^ | 4.692 g/cm^3^ (21°C)
Odor | No data | Odorless | Odorless^c^
Odor threshold:
Water | No data | No data | No data
Air | No data | No data | No data
Solubility:
Water at 25°C | Insoluble; 5.5–12 mg/L at 20°C and pH 3.5– 4.3^d^ | Insoluble | 490 mg/L (28°C)
Organic solvents | No data | Insoluble | Insoluble
Inorganic solvents | Dissolved by a mixture of concentrated nitric and concentrated hydrofluoric acids | Dissolves only in strongly oxidizing acids (e.g., aqua regia) | Soluble in aqueous alkali and ammonia; 14,000 mg/L in nitric acid (4 mol/L, 20°C)
Partition coefficients:
Log K_ow_ | NA | NA | NA
Log K_oc_ | NA | NA | NA
Vapor pressure^e^:
at 20°C | No data | No data | No data
at 2,469°C | 7.5×10^−3^ mm Hg
at 2,721°C | 7.5×10^−3^ mm Hg
at 3,039°C | 0.75 mm Hg
at 3,434°C | 7.5 mm Hg
at 3,939°C | 75 mm Hg
at 4,606°C | 750 mm Hg
Henry’s law constant at 25°C | NA | NA | NA
Autoignition temperature | NA | NA | NA
Flashpoint | NA | NA | NA
Flammability limits | Not flammable | Not flammable | Not flammable^c^
Explosive limits | NA | NA | NA
Conversion factors | NA | NA | NA
Chemical name | Sodium molybdate | Ammonium dimolybdate | Ammonium heptamolybdate tetrahydrate
Molecular weight | 205.92 | 339.95 | 1,235.8
Color | White | | White
Physical state | Crystalline powder^f^ | Solid, powder^g^ | Crystalline solid^f^
Melting point | 687°C^f^ | Decomposes from ca. 150°C^g^ | Decomposition at 90°C^h^
Boiling point | Not applicable | Decomposes from ca. 150°C^f^ | Decomposition at 90°C^h^
Density/specific gravity | 3.5 g/cm^h^ | 2.97 at 20°C^g^ | 2.86 (20°C)^f^
Odor | Odorless^f^ | Odorless^f^ | Odorless^f^
Odor threshold:
Water | No data | No data | No data
Air | No data | No data | No data
Solubility:
Water | 40 wt% (anhydrous salt in 100 g saturated solution, 25°C) | 228.4 g/L (20°C, pH 6.8)^g^ | 206.5 g/L (20°C, tetrahydrate)^f^
Organic solvents | No data | No data | No data
Inorganic solvents | No data | No data | No data
Partition coefficients:
Log K_ow_ | NA | NA | NA
Log K_oc_ | NA | NA | NA
Vapor pressure at 20°C | No data | No data | No data
Henry’s law constant at 25°C | NA | NA | NA
Autoignition temperature | NA | No data | NA
Flashpoint | No data | No data | No data
Flammability limits | No data | Non flammable^g^ | No data
Explosive limits | NA | NA | NA
Conversion factors | NA | NA | NA
Chemical name | Diammonium molybdate | Ammonium tetrathiomolybdate
Molecular weight | 196.01 | 260.28
Color | Colorless, white, or slightly greenish-yellowish^i^ | Deep red^h^
Physical state | Crystalline solid^h^ | Crystalline solid^h^
Melting point | No data | >300°C^j^
Boiling point | No data | No data
Density | 1.4^i^ | No data
Odor | Odorless^i^ | No data
Odor threshold:
Water | No data | No data
Air | No data | No data
Solubility:
Water | >10,000 mg/L^k^; 39 wt% (in 100 g saturated solution, 25°C) | Insoluble (hygroscopic)^l^
Organic solvents | No data | No data
Inorganic solvents | No data | No data
Partition coefficients:
Log K_ow_ | NA | No data
Log K_oc_ | No data | No data
Vapor pressure at 25°C | No data | NA
Henry's law constant at 25°C | NA | No data
Autoignition temperature | NA | NA
Flashpoint | NA | NA
Flammability limits | Not flammable^i^ | No data
Explosive limits | NA | NA
Conversion factors | NA | NA

a All information was obtained from Sebenik et al. (2012) unless otherwise noted.

b Cannon 1959.

c NOAA 2015.

d ECHA 2019a.

e Lide 2005.

f OECD 2013.

g ECHA 2019b.

h Haynes et al. 2014.

i NJDOH 2009.

j Sigma-Aldrich 2015.

k ECHA 2019c.

l Alfa Aesar 2015.

NA = not applicable