# APPENDIX C FRAMEWORK FOR ATSDR’S SYSTEMATIC REVIEW OF HEALTH EFFECTS DATA FOR MOLYBDENUM

To increase the transparency of ATSDR’s process of identifying, evaluating, synthesizing, and interpreting the scientific evidence on the health effects associated with exposure to molybdenum, ATSDR utilized a slight modification of NTP’s Office of Health Assessment and Translation (OHAT) systematic review methodology (NTP 2013, 2015; Rooney et al. 2014). ATSDR’s framework is an eight-step process for systematic review with the goal of identifying the potential health hazards of exposure to molybdenum:

- Step 1. Problem Formulation
- Step 2. Literature Search and Screen for Health Effects Studies
- Step 3. Extract Data from Health Effects Studies
- Step 4. Identify Potential Health Effect Outcomes of Concern
- Step 5. Assess the Risk of Bias for Individual Studies
- Step 6. Rate the Confidence in the Body of Evidence for Each Relevant Outcome
- Step 7. Translate Confidence Rating into Level of Evidence of Health Effects
- Step 8. Integrate Evidence to Develop Hazard Identification Conclusions

## C.1 PROBLEM FORMULATION

The objective of the toxicological profile and this systematic review was to identify the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to molybdenum. The inclusion criteria used to identify relevant studies examining the health effects of molybdenum are presented in Table C-1.

Table C-1 Inclusion Criteria for Identifying Health Effects Studies

Species
Human
Laboratory mammals
Route of exposure
Inhalation
Oral
Dermal (or ocular)
Parenteral (these studies will be considered supporting data)
Health outcome
Death
Systemic effects
Body weight effects
Respiratory effects
Cardiovascular effects
Gastrointestinal effects
Hematological effects
Musculoskeletal effects
Hepatic effects
Renal effects
Dermal effects
Ocular effects
Endocrine effects
Immunological effects
Neurological effects
Reproductive effects
Developmental effects
Other noncancer effects
Cancer

Data from human and laboratory animal studies were considered relevant for addressing this objective. Human studies were divided into two broad categories: observational epidemiology studies and controlled exposure studies. The observational epidemiology studies were further divided: cohort studies (retrospective and prospective studies), population studies (with individual data or aggregate data), and case-control studies.

## C.2 LITERATURE SEARCH AND SCREEN FOR HEALTH EFFECTS STUDIES

A literature search and screen was conducted to identify studies examining the health effects of molybdenum. The literature search framework for the toxicological profile is discussed in detail in Appendix B.

### C.2.1 Literature Search

As noted in Appendix B, the current literature search was intended to update the draft toxicological profile for molybdenum released for public comment in 2017. See Appendix B for the databases searched and the search strategy.

A total of 2,508 records relevant to all sections of the toxicological profile were identified (after duplicate removal).

### C.2.2 Literature Screening

As described in Appendix B, a two-step process was used to screen the literature search to identify relevant studies examining the health effects of molybdenum.

Title and Abstract Screen. In the Title and Abstract Screen step, 2,508 records were reviewed; 71 documents were considered to meet the health effects inclusion criteria in Table C-1 and were moved to the next step in the process.

Full Text Screen. In the second step in the literature screening process for the systematic review, a full text review of 92 health effects documents (documents identified in the update literature search and documents cited in older versions of the profile) was performed. From those 92 documents, 115 studies were included in the qualitative review.

## C.3 EXTRACT DATA FROM HEALTH EFFECTS STUDIES

Relevant data extracted from the individual studies selected for inclusion in the systematic review were collected in customized data forms. A summary of the type of data extracted from each study is presented in Table C-2. For references that included more than one experiment or species, data extraction records were created for each experiment or species.

Table C-2 Data Extracted From Individual Studies

Citation
Chemical form
Route of exposure (e.g., inhalation, oral, dermal)
Specific route (e.g., gavage in oil, drinking water)
Species
Strain
Exposure duration category (e.g., acute, intermediate, chronic)
Exposure duration
Frequency of exposure (e.g., 6 hours/day, 5 days/week)
Exposure length
Number of animals or subjects per sex per group
Dose/exposure levels
Parameters monitored
Description of the study design and method
Summary of calculations used to estimate doses (if applicable)
Summary of the study results
Reviewer’s comments on the study
Outcome summary (one entry for each examined outcome)
No-observed-adverse-effect level (NOAEL) value
Lowest-observed-adverse-effect level (LOAEL) value
Effect observed at the LOAEL value

A summary of the extracted data for each study is presented in the Supplemental Document for Molybdenum and overviews of the results of the studies are presented in Sections 2.2–2.18 of the profile and in the Levels of Significant Exposures tables in Section 2.1 of the profile (Tables 2-1–2-3).

## C.4 IDENTIFY POTENTIAL HEALTH EFFECT OUTCOMES OF CONCERN

Overviews of the potential health effect outcomes for molybdenum identified in human and animal studies are presented in Tables C-3 and C-4, respectively. The available human studies examined a limited number of endpoints and reported respiratory, hepatic, endocrine, other systemic (alterations in uric acid levels), reproductive, and developmental effects. Animal studies examined a number of endpoints following inhalation and oral exposure; no dermal exposure studies were identified. These studies examined most systemic endpoints and reported respiratory, gastrointestinal, hematological, musculoskeletal, hepatic, renal, endocrine, dermal, and body weight effects. Additionally, animal studies have reported neurological, reproductive, and developmental effects. Although animal studies have identified a number of affected tissues and systems, interpretation of much of the data is limited by an inadequate amount of copper in the diet. Studies in which the diet did not contain adequate levels of copper or administered ammonium tetrathiomolybdate were carried through Step 3 of the systematic review, but were not considered in the identification of potential health effect outcomes of concern. Additionally, body weight effects were not considered a primary effect especially since most studies did not provide data on food intake; thus, this endpoint was not considered in the assessment of potential human hazards. Studies examining the respiratory, hepatic, renal, uric acid, reproductive, and developmental outcomes were carried through to Steps 4–8 of the systematic review. There were 115 studies (published in 92 documents) examining these potential outcomes were carried through to Steps 4–8 of the systematic review.

Table C-3 Overview of the Health Outcomes for Molybdenum Evaluated In Human Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological | Neurological | Reproductive | Developmental | Other Noncancer | Caner
Inhalation studies
Cohort | | 2 | | | | | | | | | | | | | | 1 | 1
Cohort | | 1 | | | | | | | | | | | | | | 1 | 1
Case control
Population
Case series
Oral studies
Cohort | | | | | | | | | | | | | | 2 | 2 | 1
Cohort | | | | | | | | | | | | | | 2 | 1 | 0
Case control
Population | 1 | 1 | 3 | | | 1 | 1 | | | 1 | 3 | | | | | | 2
Population | 0 | 0 | 2 | | | 0 | 1 | | | 1 | 2 | | | | | | 0
Case series | | | | | | | | | | | | | | | | 1
Case series | | | | | | | | | | | | | | | | 0
Dermal studies
Cohort
Case control
Population
Case series
Number of studies examining endpoint | | | | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10
Number of studies reporting outcome | | | | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10

Table C-4 Overview of the Health Outcomes for Molybdenum Evaluated in Experimental Animal Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological^a^ | Neurological^a^ | Reproductive^a^ | Developmental | Other Noncancer | Caner
Inhalation studies
Acute-duration | 5 | 5
Acute-duration | 5 | 0
Intermediate-duration | | 2 | 2 | 2 | 2 | 2 | 2 | 2 | | | 2 | | 2 | 2
Intermediate-duration | | 0 | 0 | 0 | 0 | 0 | 0 | 0 | | | 0 | | 0 | 0
Chronic-duration | 2 | 2 | 2 | 2 | | 2 | 2 | 2 | | | 2 | | 2 | 2 | | | 2
Chronic-duration | 0 | 2 | 0 | 0 | | 0 | 0 | 0 | | | 0 | | 0 | 0 | | | 2
Oral studies
Acute-duration | 6 | | | 1 | 1 | 5 | 2 | 2 | | | | | | 4
Acute-duration | 2 | | | 1 | 0 | 4 | 1 | 0 | | | | | | 3
Intermediate-duration | 41 | 3 | 2 | 3 | 19 | 13 | 8 | 9 | 3 | | 8 | | 1 | 12 | 12 | 2
Intermediate-duration | 28 | 0 | 0 | 1 | 6 | 10 | 6 | 6 | 3 | | 5 | | 0 | 8 | 5 | 0
Chronic-duration
Dermal studies
Acute-duration | | | | | | | | | 7 | 4 | | 4
Acute-duration | | | | | | | | | 0 | 4 | | 0
Intermediate-duration
Chronic-duration
Number of studies examining endpoint | | | | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10
Number of studies reporting outcome | | | | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10

a Number of studies examining endpoint includes study evaluating histopathology, but not evaluating function.

## C.5 ASSESS THE RISK OF BIAS FOR INDIVIDUAL STUDIES

### C.5.1 Risk of Bias Assessment

The risk of bias of individual studies was assessed using OHAT’s Risk of Bias Tool (NTP 2015). The risk of bias questions for observational epidemiology studies, human-controlled exposure studies, and animal experimental studies are presented in Tables C-5, C-6, and C-7, respectively. Each risk of bias question was answered on a four-point scale:

- Definitely low risk of bias (++)
- Probably low risk of bias (+)
- Probably high risk of bias (−)
- Definitely high risk of bias (−−)

Table C-5 Risk of Bias Questionnaire for Observational Epidemiology Studies

Selection bias
Were the comparison groups appropriate?
Confounding bias
Did the study design or analysis account for important confounding and modifying variables?
Attrition/exclusion bias
Were outcome data complete without attrition or exclusion from analysis?
Detection bias
Is there confidence in the exposure characterization?
Is there confidence in outcome assessment?
Selective reporting bias
Were all measured outcomes reported?

Table C-6 Risk of Bias Questionnaire for Human-Controlled Exposure Studies

Selection bias
Was administered dose or exposure level adequately randomized?
Was the allocation to study groups adequately concealed?
Performance bias
Were the research personnel and human subjects blinded to the study group during the study?
Attrition/exclusion bias
Were outcome data complete without attrition or exclusion from analysis?
Detection bias
Is there confidence in the exposure characterization?
Is there confidence in outcome assessment?
Selective reporting bias
Were all measured outcomes reported?

Table C-7 Risk of Bias Questionnaire for Experimental Animal Studies

Selection bias
Was administered dose or exposure level adequately randomized?
Was the allocation to study groups adequately concealed?
Performance bias
Were experimental conditions identical across study groups?
Were the research personnel blinded to the study group during the study?
Attrition/exclusion bias
Were outcome data complete without attrition or exclusion from analysis?
Detection bias
Is there confidence in the exposure characterization?
Is there confidence in outcome assessment?
Selective reporting bias
Were all measured outcomes reported?

In general, “definitely low risk of bias” or “definitely high risk of bias” were used if the question could be answered with information explicitly stated in the study report. If the response to the question could be inferred, then “probably low risk of bias” or “probably high risk of bias” responses were typically used.

After the risk of bias questionnaires were completed for the health effects studies, the studies were assigned to one of three risk of bias tiers based on the responses to the key questions listed below and the responses to the remaining questions.

- Is there confidence in the exposure characterization? (only relevant for observational studies)
- Is there confidence in the outcome assessment?
- Does the study design or analysis account for important confounding and modifying variables? (only relevant for observational studies)

First Tier. Studies placed in the first tier received ratings of “definitely low” or “probably low” risk of bias on the key questions AND received a rating of “definitely low” or “probably low” risk of bias on the responses to at least 50% of the other applicable questions.

Second Tier. A study was placed in the second tier if it did not meet the criteria for the first or third tiers.

Third Tier. Studies placed in the third tier received ratings of “definitely high” or “probably high” risk of bias for the key questions AND received a rating of “definitely high” or “probably high” risk of bias on the response to at least 50% of the other applicable questions.

The results of the risk of bias assessment for the different types of molybdenum health effects studies (observational epidemiology, human-controlled exposure studies, and animal experimental studies) are presented in Tables C-8, C-9, and C-10, respectively.

## C.6 RATE THE CONFIDENCE IN THE BODY OF EVIDENCE FOR EACH RELEVANT OUTCOME

Confidences in the bodies of human and animal evidence were evaluated independently for each potential outcome. ATSDR did not evaluate the confidence in the body of evidence for carcinogenicity; rather, the Agency defaulted to the cancer weight-of-evidence assessment of other agencies including DHHS, EPA, and IARC. The confidence in the body of evidence for an association or no association between exposure to molybdenum and a particular outcome was based on the strengths and weaknesses of individual studies. Four descriptors were used to describe the confidence in the body of evidence for effects or when no effect was found:

- High confidence: the true effect is highly likely to be reflected in the apparent relationship
- Moderate confidence: the true effect may be reflected in the apparent relationship
- Low confidence: the true effect may be different from the apparent relationship
- Very low confidence: the true effect is highly likely to be different from the apparent relationship

Confidence in the body of evidence for a particular outcome was rated for each type of study: case-control, case series, cohort, population, human-controlled exposure, and experimental animal. In the absence of data to the contrary, data for a particular outcome were collapsed across animal species, routes of exposure, and exposure durations. If species (or strain), route, or exposure duration differences were noted, then the data were treated as separate outcomes.

Table C-8 Summary of Risk of Bias Assessment for Molybdenum—Observational Epidemiological Studies

| Risk of bias criteria and ratings
| Selection bias | Confounding bias | Attrition / exclusion bias | Detection bias | | Selective reporting bias
Reference | Were the comparison groups appropriate? | Did the study design or analysis account for important confounding and modifying variables?^*^ | Were outcome data complete without attrition or exclusion from analysis? | Is there confidence in the exposure characterization?^*^ | Is there confidence in the outcome assessment?^*^ | Were all measured outcomes reported? | Risk of bias tier
Outcome: Respiratory effects
Cohort studies
Ott et al. 2004 | − | − | + | na | + | ++ | Second
Walravens et al. 1979 | − | − | + | + | − | + | Second
Outcome: Hepatic effects
Cross-sectional studies
Mendy et al. 2012 | + | + | + | + | − | + | Second
Outcome: Alterations in uric acid levels
Cross-sectional studies
Koval’sky et al. 1961 | − | − | + | − | + | + | Second
Cohort studies
Walravens et al. 1979 | − | − | + | + | − | + | Second
Outcome: Reproductive effects
Cross-sectional studies
Lewis and Meeker 2015 | na | − | + | + | + | + | First
Meeker et al. 2008 | + | + | + | ++ | ++ | ++ | First
Meeker et al. 2010 | + | + | ++ | + | ++ | ++ | First
Outcome: Developmental effects
Cross-sectional studies
Vazquez-Salas et al. 2014 | + | + | + | + | ++ | + | First
Shirai et al. 2010 | na | − | + | + | + | + | Second

++ = definitely low risk of bias; + = probably low risk of bias; − = probably high risk of bias; −− = definitely high risk of bias; na = not applicable

* Key question used to assign risk of bias tier.

Table C-9 Summary of Risk of Bias Assessment for Molybdenum—Human-Controlled Exposure Studies

| Risk of bias criteria and ratings
| Selection bias | | Performance bias | Attrition/exclusion bias | Detection bias | | Selective reporting bias
Reference | Was administered dose or exposure level adequately randomized? | Was the allocation to study groups adequately concealed? | Were the research personnel blinded to the study group during the study? | Were outcome data complete without attrition or exclusion from analysis? | Is there confidence in the exposure characterization? | Is there confidence in the outcome assessment?^*^ | Were all measured outcomes reported? | Risk of bias tier
Outcome: Alterations in uric acid levels
Oral acute exposure
Deosthale and Gopalan 1974 | na | + | + | + | + | + | ++ | First

++ = definitely low risk of bias; + = probably low risk of bias; − = probably high risk of bias; −− = definitely high risk of bias; na = not applicable

* Key question used to assign risk of bias tier.

Table C-10 Summary of Risk of Bias Assessment for Molybdenum—Experimental Animal Studies

| Risk of bias criteria and ratings
| Selection bias | | Performance bias | | Attrition/exclusion bias | Detection bias | | Selective reporting bias | Other bias
Reference | Was administered dose or exposure level adequately randomized? | Was the allocation to study groups adequately concealed? | Were experimental conditions identical across study groups? | Were the research personnel blinded to the study group during the study? | Were outcome data complete without attrition or exclusion from analysis? | Is there confidence in the exposure characterization? | Is there confidence in the outcome assessment?^*^ | Were all measured outcomes reported? | Did the study design or analysis account for important confounding and modifying variables? | Risk of bias tier
Outcome: Respiratory effects
Inhalation acute exposure
NTP 1997 (rat) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | + | First
NTP 1997 (mouse) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | + | First
Inhalation intermediate exposure
NTP 1997 (rat) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | + | First
NTP 1997 (mouse) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | + | First
Inhalation chronic exposure
NTP 1997 (rat) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | + | First
NTP 1997 (mouse) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | + | First
Outcome: Hepatic effects
Inhalation intermediate exposure
NTP 1997 (rat) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | + | First
NTP 1997 (mouse) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | + | First
Inhalation chronic exposure
NTP 1997 (rat) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | + | First
NTP 1997 (mouse) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | + | First
Oral acute exposure
Bersenyi et al. 2008 (rabbit) | − | + | + | − | ++ | − | + | + | + | First
Bersenyi et al. 2008 (rabbit) | − | + | + | − | ++ | − | + | + | + | First
Oral intermediate exposure
Murray et al. 2014a (rat) | ++ | + | ++ | − | ++ | ++ | ++ | ++ | ++ | First
Rana and Chauhan 2000 (rat) | − | + | + | − | ++ | + | − | ++ | − | Second
Rana and Kumar 1980b (rat) | − | + | + | − | ++ | − | − | + | − | Third
Rana and Kumar 1980c (rat) | + | + | − | − | ++ | − | + | ++ | − | First
Rana and Kumar 1983 (rat) | + | + | − | − | ++ | + | + | ++ | − | First
Rana and Prakash 1986 (rat) | − | + | + | − | ++ | − | + | + | + | First
Rana et al. 1980 (rat) | − | + | + | − | + | − | + | + | + | First
Rana et al. 1985 (rat) | + | + | + | − | ++ | + | + | + | + | First
Outcome: Renal effects
Inhalation intermediate exposure
NTP 1997 (rat) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | + | First
NTP 1997 (mouse) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | + | First
Inhalation chronic exposure
NTP 1997 (rat) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | + | First
NTP 1997 (mouse) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | + | First
Oral acute exposure
Bersenyi et al. 2008 (rabbit, males) | − | + | + | − | ++ | − | + | + | + | First
Bersenyi et al. 2008 (rabbit, females) | − | + | + | − | ++ | − | + | + | + | First
Oral intermediate exposure
Bandyopadhyay et al. 1981 (rat) | − | + | + | − | ++ | − | + | ++ | ++ | First
Bompart et al. 1990 (rat) | + | + | + | − | ++ | + | + | ++ | + | First
Murray et al. 2014a (rat) | ++ | + | ++ | − | ++ | ++ | ++ | ++ | ++ | First
Rana et al. 1980 (rat) | − | + | + | − | + | − | + | + | + | First
Rana and Kumar 1980c | + | + | − | − | ++ | − | + | ++ | − | First
Rana and Kumar 1983 (rat) | + | + | − | − | ++ | + | + | ++ | − | First
Outcome: Alterations in uric acid levels
Oral intermediate exposure
Murray et al. 2014a (rat) | ++ | + | ++ | − | ++ | ++ | ++ | ++ | ++ | First
Outcome: Reproductive effects
Inhalation intermediate exposure
NTP 1997 (rat) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | + | First
NTP 1997 (mouse) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | + | First
Oral acute exposure
Zhang et al. 2013 (mouse) | − | + | ++ | − | ++ | −− | + | ++ | − | First
Zhai et al. 2013 (mouse) | − | + | ++ | − | ++ | −− | + | ++ | + | First
Bersenyi et al. 2008 (rabbit, males) | − | + | + | − | ++ | − | + | + | + | First
Bersenyi et al. 2008 (rabbit, females) | − | + | + | − | ++ | − | + | + | + | First
Oral intermediate exposure
Fungwe et al. 1990 (rat) | + | + | + | − | ++ | − | + | + | −− | First
Jeter and Davis 1954 (rat, adults) | − | + | + | − | ++ | − | + | + | − | First
Jeter and Davis 1954 (rat, weanling) | − | + | + | − | ++ | − | + | + | −− | First
Murray et al. 2014a (rat) | ++ | + | ++ | − | ++ | ++ | ++ | ++ | ++ | First
Murray et al. 2019 (rat) | ++ | + | ++ | − | ++ | ++ | ++ | ++ | ++ | First
Pandey and Singh 2002 (rat) | − | + | ++ | − | ++ | + | + | ++ | − | First
Pandey and Singh 2002 (rat fertility study) | − | + | ++ | − | ++ | + | + | ++ | − | First
Outcome: Developmental effects
Oral intermediate exposure
Jeter and Davis 1954 (rat, weanling) | − | + | + | − | ++ | − | + | + | −− | First
Murray et al. 2014b (rat) | ++ | + | + | − | ++ | ++ | + | ++ | + | First
Pandey and Singh 2002 (rat) | − | + | ++ | − | ++ | + | + | ++ | − | First

++ = definitely low risk of bias; + = probably low risk of bias; − = probably high risk of bias; −− = definitely high risk of bias

* Key question used to assign risk of bias tier.

### C.6.1 Initial Confidence Rating

In ATSDR’s modification to the OHAT approach, the body of evidence for an association (or no association) between exposure to molybdenum and a particular outcome was given an initial confidence rating based on the key features of the individual studies examining that outcome. The presence of these key features of study design was determined for individual studies using four “yes or no” questions, which were customized for epidemiology, human controlled exposure, or experimental animal study designs. Separate questionnaires were completed for each outcome assessed in a study. The key features for observational epidemiology (cohort, population, and case-control) studies, human controlled exposure, and experimental animal studies are presented in Tables C-11, C-12, and C-13, respectively. The initial confidence in the study was determined based on the number of key features present in the study design:

- High Initial Confidence: Studies in which the responses to the four questions were “yes”.
- Moderate Initial Confidence: Studies in which the responses to only three of the questions were “yes”.
- Low Initial Confidence: Studies in which the responses to only two of the questions were “yes”.
- Very Low Initial Confidence: Studies in which the response to one or none of the questions was “yes”.

Table C-11 Key Features of Study Design for Observational Epidemiology Studies

Exposure was experimentally controlled
Exposure occurred prior to the outcome
Outcome was assessed on individual level rather than at the population level
A comparison group was used

Table C-12 Key Features of Study Design for Human-Controlled Exposure Studies

A comparison group was used or the subjects served as their own control
A sufficient number of subjects were tested
Appropriate methods were used to measure outcomes (i.e., clinically-confirmed outcome versus self-reported)
Appropriate statistical analyses were performed and reported or the data were reported in such a way to allow independent statistical analysis

Table C-13 Key Features of Study Design for Experimental Animal Studies

A concurrent control group was used
A sufficient number of animals per group were tested
Appropriate parameters were used to assess a potential adverse effect
Appropriate statistical analyses were performed and reported or the data were reported in such a way to allow independent statistical analysis

The presence or absence of the key features and the initial confidence levels for studies examining The presence or absence of the key features and the initial confidence levels for studies examining respiratory, gastrointestinal, renal, dermal, and ocular effects observed in the observational epidemiology, human-controlled exposure, and animal experimental studies are presented in Tables C-14, C-15, and C-16, respectively.

Table C-14 Presence of Key Features of Study Design for Molybdenum—Observational Epidemiology Studies

| Key features
Reference | Controlled exposure | Exposure prior to outcome | Outcomes assessed on an individual level | Comparison group | Initial study confidence
Outcome: Respiratory effects
Cohort studies
Ott et al. 2004 | No | Yes | Yes | No | Low
Walravens et al. 1979 | No | No | No | No | Very Low
Outcome: Hepatic effects
Cross-sectional studies
Mendy et al. 2012 | No | No | Yes | Yes | Low
Outcome: Alterations in uric acid levels
Cross-sectional studies
Koval’sky et al. 1961 | No | Yes | Yes | No | Low
Cohort studies
Walravens et al. 1979 | No | No | No | No | Very Low
Outcome: Reproductive effects
Cross-sectional studies
Lewis and Meeker 2015 | No | No | Yes | Yes | Low
Meeker et al. 2008 | No | No | Yes | Yes | Low
Meeker et al. 2010 | No | No | Yes | Yes | Low
Outcome: Developmental effects
Cross-sectional studies
Vazquez-Salas et al. 2014 | No | No | Yes | Yes | Low
Shirai et al. 2010 | No | No | Yes | Yes | Low

Table C-15 Presence of Key Features of Study Design for Molybdenum—Human-Controlled Exposure Studies

| Key feature
Reference | Concurrent control group or self-control | Sufficient number of subjects tested | Appropriate methods to measure outcome | Adequate data for statistical analysis | Initial study confidence
Outcome: Alterations in uric acid levels
Oral acute exposure
Deosthale and Gopalan 1974 | Yes | No | Yes | No | Low

Table C-16 Presence of Key Features of Study Design for Molybdenum—Experimental Animal Studies

| Key feature
Reference | Concurrent control group | Sufficient number of animals per group | Appropriate parameters to assess potential effect | Adequate data for statistical analysis | Initial study confidence
Outcome: Respiratory effects
Inhalation acute exposure
NTP 1997 (rat) | Yes | Yes | Yes | Yes | High
NTP 1997 (mouse) | Yes | Yes | Yes | Yes | High
Inhalation intermediate exposure
NTP 1997 (rat) | Yes | Yes | Yes | Yes | High
NTP 1997 (mouse) | Yes | Yes | Yes | Yes | High
Inhalation chronic exposure
NTP 1997 (rat) | Yes | Yes | Yes | Yes | High
NTP 1997 (mouse) | Yes | Yes | Yes | Yes | High
Outcome: Hepatic effects
Inhalation intermediate exposure
NTP 1997 (rat) | Yes | Yes | Yes | Yes | High
NTP 1997 (mouse) | Yes | Yes | Yes | Yes | High
Inhalation chronic exposure
NTP 1997 (rat) | Yes | Yes | Yes | Yes | High
NTP 1997 (mouse) | Yes | Yes | Yes | Yes | High
Oral acute exposure
Bersenyi et al. 2008 (rabbit, males) | Yes | No | Yes | Yes | Moderate
Bersenyi et al. 2008 (rabbit, females) | Yes | No | Yes | Yes | Moderate
Oral intermediate exposure
Murray et al. 2014a (rat) | Yes | Yes | Yes | Yes | High
Rana and Chauhan 2000 (rat) | Yes | Yes | No | Yes | Moderate
Rana and Kumar 1980b (rat) | Yes | Yes | No | Yes | Moderate
Rana and Kumar 1980c (rat) | Yes | Yes | No | Yes | Moderate
Rana and Kumar 1983 (rat) | Yes | Yes | No | Yes | Moderate
Rana and Prakash 1986 (rat) | Yes | Yes | No | Yes | Moderate
Rana et al. 1980 (rat) | Yes | Yes | No | No | Low
Rana et al. 1985 (rat) | Yes | Yes | No | Yes | Moderate
Outcome: Renal effects
Inhalation intermediate exposure
NTP 1997 (rat) | Yes | Yes | Yes | Yes | High
NTP 1997 (mouse) | Yes | Yes | Yes | Yes | High
Inhalation chronic exposure
NTP 1997 (rat) | Yes | Yes | Yes | Yes | High
NTP 1997 (mouse) | Yes | Yes | Yes | Yes | High
Oral acute exposure
Bersenyi et al. 2008 (rabbit, males) | Yes | No | Yes | Yes | Moderate
Bersenyi et al. 2008 (rabbit, females) | Yes | No | Yes | Yes | Moderate
Oral intermediate exposure
Bandyopadhyay et al. 1981 (rat) | Yes | No | Yes | No | Low
Bompart et al. 1990 (rat) | Yes | No | Yes | Yes | Moderate
Murray et al. 2014a (rat) | Yes | Yes | Yes | Yes | High
Murray et al. 2019 (rat) | Yes | Yes | Yes | Yes | High
Rana et al. 1980 (rat) | Yes | Yes | No | No | Low
Rana and Kumar 1980c | Yes | Yes | No | Yes | Moderate
Rana and Kumar 1983 (rat) | Yes | Yes | No | Yes | Moderate
Outcome: Alterations in uric acid levels
Oral intermediate exposure
Murray et al. 2014a (rat) | Yes | Yes | Yes | Yes | High
Outcome: Reproductive effects
Inhalation intermediate exposure
NTP 1997 (rat) | Yes | Yes | Yes | Yes | High
NTP 1997 (mouse) | Yes | Yes | Yes | Yes | High
Oral acute exposure
Zhang et al. 2013 (mouse) | Yes | Yes | No | Yes | Moderate
Zhai et al. 2013 (mouse) | Yes | Yes | No | Yes | Moderate
Bersenyi et al. 2008 (rabbit, males) | Yes | No | No | Yes | Low
Bersenyi et al. 2008 (rabbit, females) | Yes | No | No | No | Very Low
Oral intermediate exposure
Fungwe et al. 1990 (rat) | Yes | No | Yes | Yes | Moderate
Jeter and Davis 1954 (rat, adult) | Yes | No | No | No | Very Low
Murray et al. 2014a (rat) | Yes | Yes | Yes | Yes | High
Murray et al. 2019 (rat) | Yes | Yes | Yes | Yes | High
Pandey and Singh 2002 (rat) | Yes | Yes | No | Yes | Moderate
Pandey and Singh 2002 (rat, fertility study) | Yes | Yes | Yes | Yes | High
Outcome: Developmental effects
Oral intermediate exposure
Jeter and Davis 1954 (rat, weanling) | Yes | No | No | No | Very Low
Murray et al. 2014b (rat) | Yes | Yes | Yes | Yes | High
Murray et al. 2019 (rat) | Yes | Yes | Yes | Yes | High
Pandey and Singh 2002 (rat) | Yes | Yes | Yes | Yes | High

A summary of the initial confidence ratings for each outcome is presented in Table C-17. If individual studies for a particular outcome and study type had different study quality ratings, then the highest confidence rating for the group of studies was used to determine the initial confidence rating for the body of evidence; any exceptions were noted in Table C-17.

Table C-17 Initial Confidence Rating for Molybdenum Health Effects Studies

| Finding | Initial study confidence | Initial confidence rating
Outcome: Respiratory effects (inhalation only)
Inhalation acute exposure
Animal studies
NTP 1997 (rat) | No effect | High | High
NTP 1997 (mouse) | No effect | High | High
Inhalation intermediate exposure
Animal studies
NTP 1997 (rat) | No effect | High | High
NTP 1997 (mouse) | No effect | High | High
Inhalation chronic exposure
Human studies
Observational studies
Ott et al. 2004 | Effect | Low | Low
Walravens et al. 1979 | Effect | Very Low | Low
Animal studies
NTP 1997 (rat) | Effect | High | High
NTP 1997 (mouse) | Effect | High | High
Outcome: Hepatic effects
Inhalation intermediate exposure
Animal studies
NTP 1997 (rat) | No effect | High | High
NTP 1997 (mouse) | No effect | High | High
Inhalation chronic exposure
Animal studies
NTP 1997 (rat) | No effect | High | High
NTP 1997 (mouse) | No effect | High | High
Oral acute exposure
Animal studies
Bersenyi et al. 2008 (rabbit, males) | Effect | Moderate | Moderate
Bersenyi et al. 2008 (rabbit, females) | Effect | Moderate | Moderate
Oral intermediate exposure
Animal studies
Murray et al. 2014a (rat) | No effect | High | High
Rana and Chauhan 2000 (rat) | Effect | Moderate
Rana and Kumar 1980b (rat) | Effect | Moderate
Rana and Kumar 1980c (rat) | Effect | Moderate
Rana and Kumar 1983 (rat) | Effect | Moderate | Low
Rana and Prakash 1986 (rat) | Effect | Moderate
Rana et al. 1980 (rat) | Effect | Low
Rana et al. 1985 (rat) | Effect | Moderate
Oral chronic exposure
Human studies
Observational studies
Mendy et al. 2012 | Effect | Low | Low
Outcome: Renal effects
Inhalation intermediate exposure
Animal studies
NTP 1997 (rat) | No effect | High | High
NTP 1997 (mouse) | No effect | High | High
Inhalation chronic exposure
Animal studies
NTP 1997 (rat) | No effect | High | High
NTP 1997 (mouse) | No effect | High | High
Oral acute exposure
Animal studies
Bersenyi et al. 2008 (rabbit, males) | No effect | Moderate | Moderate
Bersenyi et al. 2008 (rabbit, females) | No effect | Moderate | Moderate
Oral intermediate exposure
Animal studies
Bandyopadhyay et al. 1981 (rat) | Effect | Low
Bompart et al. 1990 (rat) | Effect | Moderate
Murray et al. 2014a (rat) | Effect | High | High
Rana et al. 1980 (rat) | Effect | Low | High
Rana and Kumar 1980c | Effect | Moderate
Rana and Kumar 1983 (rat) | Effect | Moderate
Murray et al. 2019 (rat) | No effect | High | High
Outcome: Alterations in uric acid levels
Inhalation chronic exposure
Human studies
Observational studies
Walravens et al. 1979 | Effect | Very Low | Very Low
Oral acute exposure
Human studies
Controlled exposure
Deosthale and Gopalan 1974 | No Effect | Low | Low
Oral intermediate exposure
Animal studies
Murray et al. 2014a (rat) | No effect | High | High
Oral chronic exposure
Human studies
Observational studies
Koval’sky et al. 1961 | Effect | Low | Low
Outcome: Reproductive effects
Inhalation intermediate exposure
Animal studies
NTP 1997 (rat) | No effect | High | High
NTP 1997 (mouse) | No effect | High | High
Oral acute exposure
Animal studies
Zhang et al. 2013 (mouse) | Effect | Moderate
Zhai et al. 2013 (mouse) | Effect | Moderate | Moderate
Bersenyi et al. 2008 (male, rabbit) | Effect | Low
Bersenyi et al. 2008 (female, rabbit) | No effect | Very Low | Very low
Oral intermediate exposure
Animal studies
Fungwe et al. 1990 (rat) | Effect | Moderate
Jeter and Davis 1954 (rat, adult) | Effect | Very Low | High
Jeter and Davis 1954 (rat, weanling) | Effect | Very Low | High
Pandey and Singh 2002 (rat) | Effect | Moderate
Pandey and Singh 2002 (rat, fertility study) | Effect | High
Murray et al. 2014a (rat) | No effect | High | High
Murray et al. 2019 (rat) | No effect | High | High
Oral chronic exposure
Human studies
Observational studies
Lewis and Meeker 2015 | Effect | Low
Meeker et al. 2008 | Effect | Low | Low
Meeker et al. 2010 | Effect | Low
Outcome: Developmental effects
Oral intermediate exposure
Animal studies
Pandey and Singh 2002 (rat) | Effect | High | High
Jeter and Davis 1954 (rat, weanling) | No effect | Very Low
Murray et al. 2014b (rat) | No effect | High | High
Murray et al. 2019 (rat) | No effect | High
Oral chronic exposure
Human studies
Observational studies
Vazquez-Salas et al. 2014 | Effect | Low | Low
Shirai et al. 2010 | No effect | Low | Low

### C.6.2 Adjustment of the Confidence Rating

The initial confidence rating was then downgraded or upgraded depending on whether there were substantial issues that would decrease or increase confidence in the body of evidence. The nine properties of the body of evidence that were considered are listed below. The summaries of the assessment of the confidence in the body of evidence for respiratory, hepatic, renal, alterations in uric acid levels, reproductive, and developmental effects are presented in Table C-18. If the confidence ratings for a particular outcome were based on more than one type of human study, then the highest confidence rating was used for subsequent analyses. An overview of the confidence in the body of evidence for all health effects associated with molybdenum exposure is presented in Table C-19.

Five properties of the body of evidence were considered to determine whether the confidence rating should be downgraded:

- Risk of bias. Evaluation of whether there is substantial risk of bias across most of the studies examining the outcome. This evaluation used the risk of bias tier groupings for individual studies examining a particular outcome (Tables C-14, C-15, and C-16). Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for risk of bias:
  ○ No downgrade if most studies are in the risk of bias first tier
  ○ Downgrade one confidence level if most studies are in the risk of bias second tier
  ○ Downgrade two confidence levels if most studies are in the risk of bias third tier

Table C-18 Adjustments to the Initial Confidence in the Body of Evidence

| Initial confidence | Adjustments to the initial confidence rating | Final confidence
Outcome: Respiratory effects
Observational studies (effect) | Low | −1 risk of bias; −1 imprecision | Very low
Animal studies (effect) | High | None | High
Animal studies (no effect) | High | +1 magnitude | High
Outcome: Hepatic effects
Observational studies (effect) | Low | −1 risk of bias | Very low
Animal studies (effect) | Moderate | −1 indirectness (secondary outcomes); | Moderate
Animal studies (no effect) | High | None | High
Outcome: Renal effects
Animal studies | High | None | High
Animal studies | High | None | High
Outcome: Alterations in uric acid levels
Observational studies (effect) | Low | −1 risk of bias | Very low
Controlled exposure studies (no effect) | Low | None | Low
Animal studies (no effect) | High | None | High
Outcome: Reproductive effects
Observational studies (effect) | Low | None | Low
Animal studies (effect) | High | −1 inconsistency | Moderate
Animal studies (no effect) | High | None | High
Outcome: Developmental effects
Observational studies (effect) | Low | None | Low
Observational studies (no effect) | Low | None | Low
Animal studies | High | −1 inconsistency | Moderate
Animal studies | High | None | High

Table C-19 Confidence in the Body of Evidence for Molybdenum

| Confidence in body of evidence
Outcome | Human studies | Animal studies
Respiratory effects | Very low (effect) | High (effect); High (no effect)
Hepatic effects | Very low (effect) | Moderate (effect); High (no effect)
Renal effects | No data | High (effect); High (no effect)
Alterations in uric acid levels | Very low (effect); Low (no effect) | High (effect)
Reproductive Effects | Low (effect) | Moderate (effect); High (no effect)
Developmental effects | Low (effect); Low (no effect) | Moderate (effect); High (no effect)

- Unexplained inconsistency. Evaluation of whether there is inconsistency or large variability in the magnitude or direction of estimates of effect across studies that cannot be explained. Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for unexplained inconsistency:
  ○ No downgrade if there is little inconsistency across studies or if only one study evaluated the outcome
  ○ Downgrade one confidence level if there is variability across studies in the magnitude or direction of the effect
  ○ Downgrade two confidence levels if there is substantial variability across studies in the magnitude or direct of the effect
- Indirectness. Evaluation of four factors that can affect the applicability, generalizability, and relevance of the studies:
  ○ Relevance of the animal model to human health—unless otherwise indicated, studies in rats, mice, and other mammalian species are considered relevant to humans
  ○ Directness of the endpoints to the primary health outcome—examples of secondary outcomes or nonspecific outcomes include organ weight in the absence of histopathology or clinical chemistry findings in the absence of target tissue effects
  ○ Nature of the exposure in human studies and route of administration in animal studies—inhalation, oral, and dermal exposure routes are considered relevant unless there are compelling data to the contrary
  ○ Duration of treatment in animal studies and length of time between exposure and outcome assessment in animal and prospective human studies—this should be considered on an outcome-specific basis
  Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for indirectness:
  ○ No downgrade if none of the factors are considered indirect
  ○ Downgrade one confidence level if one of the factors is considered indirect
  ○ Downgrade two confidence levels if two or more of the factors are considered indirect
- Imprecision. Evaluation of the narrowness of the effect size estimates and whether the studies have adequate statistical power. Data are considered imprecise when the ratio of the upper to lower 95% CIs for most studies is ≥10 for tests of ratio measures (e.g., odds ratios) and ≥100 for absolute measures (e.g., percent control response). Adequate statistical power is determined if the study can detect a potentially biologically meaningful difference between groups (20% change from control response for categorical data or risk ratio of 1.5 for continuous data). Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for imprecision:
  ○ No downgrade if there are no serious imprecisions
  ○ Downgrade one confidence level for serious imprecisions
  ○ Downgrade two confidence levels for very serious imprecisions
- Publication bias. Evaluation of the concern that studies with statistically significant results are more likely to be published than studies without statistically significant results.
  ○ Downgrade one level of confidence for cases where there is serious concern with publication bias

Four properties of the body of evidence were considered to determine whether the confidence rating should be upgraded:

- Large magnitude of effect. Evaluation of whether the magnitude of effect is sufficiently large so that it is unlikely to have occurred as a result of bias from potential confounding factors.
  ○ Upgrade one confidence level if there is evidence of a large magnitude of effect in a few studies, provided that the studies have an overall low risk of bias and there is no serious unexplained inconsistency among the studies of similar dose or exposure levels; confidence can also be upgraded if there is one study examining the outcome, provided that the study has an overall low risk of bias
- Dose response. Evaluation of the dose-response relationships measured within a study and across studies. Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level for evidence of a monotonic dose-response gradient
  ○ Upgrade one confidence level for evidence of a non-monotonic dose-response gradient where there is prior knowledge that supports a non-monotonic dose-response and a nonmonotonic dose-response gradient is observed across studies
- Plausible confounding or other residual biases. This factor primarily applies to human studies and is an evaluation of unmeasured determinants of an outcome such as residual bias towards the null (e.g., “healthy worker” effect) or residual bias suggesting a spurious effect (e.g., recall bias). Below is the criterion used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level for evidence that residual confounding or bias would underestimate an apparent association or treatment effect (i.e., bias toward the null) or suggest a spurious effect when results suggest no effect
- Consistency in the body of evidence. Evaluation of consistency across animal models and species, consistency across independent studies of different human populations and exposure scenarios, and consistency across human study types. Below is the criterion used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level if there is a high degree of consistency in the database

## C.7 TRANSLATE CONFIDENCE RATING INTO LEVEL OF EVIDENCE OF HEALTH EFFECTS

In the seventh step of the systematic review of the health effects data for molybdenum, the confidence in the body of evidence for specific outcomes was translated to a level of evidence rating. The level of evidence rating reflected the confidence in the body of evidence and the direction of the effect (i.e., toxicity or no toxicity); route-specific differences were noted. The level of evidence for health effects was rated on a five-point scale:

- High level of evidence: High confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Moderate level of evidence: Moderate confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Low level of evidence: Low confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Evidence of no health effect: High confidence in the body of evidence that exposure to the substance is not associated with the health outcome
- Inadequate evidence: Low or moderate confidence in the body of evidence that exposure to the substance is not associated with the health outcome OR very low confidence in the body of evidence for an association between exposure to the substance and the health outcome

A summary of the level of evidence of health effects for molybdenum is presented in Table C-20.

Table C-20 Level of Evidence of Health Effects for Molybdenum

Outcome | Confidence in body of evidence | Direction of health effect | Level of evidence for health effect
Human studies
Respiratory effects (inhalation only) | Very low | Health effect | Inadequate
Hepatic effects | Very low | Health effect | Inadequate
Renal effects | No data | No data | No data
Alterations in uric acid levels | Low | Health effect | Inadequate
Reproductive effects | Low | Health effect | Low
Developmental effects | Low | Health effect | Low
Animal studies
Respiratory effects (inhalation only) | High | Health effect; No health effect | High; High
Hepatic effects | Moderate | Health effect; No health effect | Moderate; High
Renal effects | High | Health effect | High
Alterations in uric acid levels | High | No effect | Evidence of no health effect
Reproductive effects | Moderate | Health effect; No health effect | Moderate; High
Developmental effects^a^ | Moderate | Health effect; No health effect | High; Evidence of no health effect

## C.8 INTEGRATE EVIDENCE TO DEVELOP HAZARD IDENTIFICATION CONCLUSIONS

The final step involved the integration of the evidence streams for the human studies and animal studies to allow for a determination of hazard identification conclusions. For health effects, there were four hazard identification conclusion categories:

- Known to be a hazard to humans
- Presumed to be a hazard to humans
- Suspected to be a hazard to humans
- Not classifiable as to the hazard to humans

The initial hazard identification was based on the highest level of evidence in the human studies and the level of evidence in the animal studies; if there were no data for one evidence stream (human or animal), then the hazard identification was based on the one data stream (equivalent to treating the missing evidence stream as having low level of evidence). The hazard identification scheme is presented in and described below:

- Known: A health effect in this category would have:
  ○ High level of evidence for health effects in human studies AND a high, moderate, or low level of evidence in animal studies.
- Presumed: A health effect in this category would have:
  ○ Moderate level of evidence in human studies AND high or moderate level of evidence in animal studies OR
  ○ Low level of evidence in human studies AND high level of evidence in animal studies
- Suspected: A health effect in this category would have:
  ○ Moderate level of evidence in human studies AND low level of evidence in animal studies OR
  ○ Low level of evidence in human studies AND moderate level of evidence in animal studies
- Not classifiable: A health effect in this category would have:
  ○ Low level of evidence in human studies AND low level of evidence in animal studies

Figure C-1 Hazard Identification Scheme

Figure C-1 description

Other relevant data such as mechanistic or mode-of-action data were considered to raise or lower the level of the hazard identification conclusion by providing information that supported or opposed biological plausibility.

Two hazard identification conclusion categories were used when the data indicated that there may be no health effect in humans:

- Not identified to be a hazard in humans
- Inadequate to determine hazard to humans

If the human level of evidence conclusion of no health effect was supported by the animal evidence of no health effect, then the hazard identification conclusion category of “not identified” was used. If the human or animal level of evidence was considered inadequate, then a hazard identification conclusion category of “inadequate” was used. As with the hazard identification for health effects, the impact of other relevant data was also considered for no health effect data.

The hazard identification conclusions for molybdenum are listed below and summarized in Table C-21.

Table C-21 Hazard Identification Conclusions for Molybdenum

Outcome | Hazard identification
Respiratory effects | Presumed health effect following long-term inhalation exposure
Hepatic effects | Not classifiable as a hazard to humans
Renal effects | Presumed health effect
Alterations in uric acid levels | Not classifiable as a hazard to humans
Reproductive effects | Suspected health effect
Developmental effects | Not classifiable as a hazard to humans

### Presumed Health Effects

- Respiratory effects following long-term inhalation exposure to molybdenum oxides
  ○ Inadequate evidence from studies of molybdenum oxide workers (Ott et al. 2004; Walravens et al. 1979).
  ○ High level of evidence from chronic studies in rats and mice exposed to molybdenum trioxide (NTP 1997). Respiratory effects were not observed following acute- or intermediate-duration inhalation exposure.
- Renal effects
  ○ No data in humans.
  ○ High level of evidence of histological alterations in kidneys, alterations in renal function, and/or increased lipid levels in the kidneys in orally exposed rats (Bandyopadhyay et al. 1981; Bompart et al. 1990; Murray et al. 2014a; Rana and Kumar 1980c, 1983; Rana et al. 1980).

### Not Classifiable as a Hazard to Humans

- Hepatic effects
  ○ Inadequate evidence of increased risk of self-reported liver conditions from a cross-sectional study (Mendy et al. 2012).
  ○ High evidence of no histological alterations following intermediate or chronic inhalation exposure of rats and mice to molybdenum trioxide (NTP 1997), acute oral exposure of rabbits to ammonium heptamolybdate (Bersenyi et al. 2008), or intermediate oral exposure of rats to sodium molybdate (Murray et al. 2014a;).
  ○ Moderate evidence of increases in clinical chemistry parameters and/or liver lipid levels in rabbits following acute oral exposure (Bersenyi et al. 2008) or rats exposed orally exposed to high doses (Rana and Chauhan 2000; Rana and Kumar 1980b, 1980c, 1983; Rana and Prakash 1986; Rana et al. 1980, 1985).
  ○ The hazard identification for hepatic effects was downgraded to Not Classifiable because the toxicological significance of the alterations in serum enzyme levels and lipid levels were not known and well-designed inhalation and oral laboratory animal studies have not reported histological alterations.
- Alterations in uric acid levels
  ○ Low evidence of an effect in cross-sectional studies (Koval’skiy et al. 1961; Walravens et al. 1979).
  ○ High confidence in an animal study not finding an effect (Murray et al. 2014a).
- Reproductive effects
  ○ Low level of evidence of male reproductive effects in cross-sectional studies (Lewis and Meeker 2015; Meeker et al. 2008, 2010).
  ○ Two high-quality, intermediate-duration (Murray et al. 2014a) and 2-generation (Murray et al. 2019) studies have not reported reproductive effects.
  ○ There is a moderate level of evidence of male and/or female reproductive effects in orally exposed rats (Fungwe et al. 1990; Pandey and Singh 2002), mice (Zhai et al. 2013; Zhang et al. 2013), and rabbits (Bersenyi et al. 2008).
- Developmental effects
  ○ Low evidence of an effect in a cross-sectional study. Two cross-sectional studies reported no alterations in newborn body weight (Shirai et al. 2010; Vazquez-Salas et al. 2014); one study reported decreases in psychomotor development indices (Vazquez-Salas et al. 2014).
  ○ Three studies in rats did not find alterations in resorptions, post-implantation losses, or fetal body weights (Jeter and Davis 1954; Murray et al. 2014b, 2019); the initial confidence levels for two of these studies were high and the third study was very low. A fourth study (initial high confidence level) involving male-only exposure found decreases in number of live fetuses and fetal body weights (Pandey and Singh 2002). The animal studies had different study designs (male only, female only, male and female exposure) making a comparison across studies difficult. Additionally, none of the animal studies evaluated potential neurodevelopmental effects, which were observed in an epidemiology study. Thus, the available data were not considered adequate for drawing a conclusion on the potential developmental toxicity of molybdenum in humans.