# APPENDIX B LITERATURE SEARCH FRAMEWORK FOR MOLYBDENUM

The objective of the toxicological profile is to evaluate the potential for human exposure and the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to molybdenum.

## B.1 LITERATURE SEARCH AND SCREEN

A literature search and screen was conducted to identify studies examining health effects, toxicokinetics, mechanisms of action, susceptible populations, biomarkers, chemical interactions, physical and chemical properties, production, use, environmental fate, environmental releases, and environmental and biological monitoring data for molybdenum. ATSDR primarily focused on peer-reviewed articles without publication date or language restrictions. Non-peer-reviewed studies that were considered relevant to the assessment of the health effects of molybdenum have undergone peer review by at least three ATSDR-selected experts who have been screened for conflict of interest. The inclusion criteria used to identify relevant studies examining the health effects of molybdenum are presented in Table B-1.

Table B-1 Inclusion Criteria for the Literature Search and Screen

Health Effects
Species
Human
Laboratory mammals
Route of exposure
Inhalation
Oral
Dermal (or ocular)
Parenteral (these studies will be considered supporting data)
Health outcome
Death
Systemic effects
Body weight effects
Respiratory effects
Cardiovascular effects
Gastrointestinal effects
Hematological effects
Musculoskeletal effects
Hepatic effects
Renal effects
Dermal effects
Ocular effects
Endocrine effects
Immunological effects
Neurological effects
Reproductive effects
Developmental effects
Other noncancer effects
Cancer
Toxicokinetics
Absorption
Distribution
Metabolism
Excretion
PBPK models
Biomarkers
Biomarkers of exposure
Biomarkers of effect
Interactions with other chemicals
Potential for human exposure
Releases to the environment
Air
Water
Soil
Environmental fate
Transport and partitioning
Transformation and degradation
Environmental monitoring
Air
Water
Sediment and soil
Other media
Biomonitoring
General populations
Occupation populations

### B.1.1 Literature Search

The current literature search was intended to update the draft toxicological profile for molybdenum released for public comment in 2017. The following main databases were searched in January 2018:

- PubMed
- National Library of Medicine’s TOXLINE
- Scientific and Technical Information Network’s TOXCENTER

The search strategy used the chemical names, Chemical Abstracts Service (CAS) numbers, synonyms, Medical Subject Headings (MeSH) headings, and keywords for molybdenum. The query strings used for the literature search are presented in Table B-2.

The search was augmented by searching the Toxic Substances Control Act Test Submissions (TSCATS), NTP website, and National Institute of Health Research Portfolio Online Reporting Tools Expenditures and Results (NIH RePORTER) databases using the queries presented in Table B-3. Additional databases were searched in the creation of various tables and figures, such as the TRI Explorer, the Substance Priority List (SPL) resource page, and other items as needed. Regulations applicable to molybdenum were identified by searching international and U.S. agency websites and documents.

Review articles were identified and used for the purpose of providing background information and identifying additional references. ATSDR also identified reports from the grey literature, which included unpublished research reports, technical reports from government agencies, conference proceedings and abstracts, and theses and dissertations.

Table B-2 Database Query Strings

Database search date | Query string
PubMed
01/2018 | (((“Molybdenum/toxicity”[mh] OR “Molybdenum/adverse effects”[mh] OR “Molybdenum/poisoning”[mh] OR “Molybdenum/pharmacokinetics”[mh]) OR (“Molybdenum”[mh] AND (“environmental exposure”[mh] OR ci[sh])) OR (“Molybdenum”[mh] AND toxicokinetics[mh:noexp]) OR (“Molybdenum/blood”[mh] OR “Molybdenum/cerebrospinal fluid”[mh] OR “Molybdenum/urine”[mh]) OR (“Molybdenum”[mh] AND (“endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh])) OR (“Molybdenum”[mh] AND (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic ”[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“Molybdenum/antagonists and inhibitors”[mh]) OR (“Molybdenum/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“Molybdenum”[mh] AND cancer[sb]) OR (“Molybdenum/pharmacology”[majr])) AND (2013/12/01 : 3000[dp] OR 2014/12/01 : 3000[mhda])) OR ((“1317-33-5”[rn] OR “12033-29-3”[rn] OR “12033-33-9”[rn] OR “11098-99-0”[rn] OR “18868-43-4”[rn] OR “1313-27-5”[rn] OR “1313-29-7”[rn] OR “11098-84-3”[rn] OR “27546-07-2”[rn] OR “12054-85-2”[rn]; OR “15060-55-6”[rn] OR “7631-95-0”[rn] OR “10102-40-6”[rn] OR “7789-82-4”[rn] OR; “12011-97-1”[rn] OR “11119-46-3”[rn] OR “11062-51-4”[rn] OR “10241-05-1”[rn] OR “1309-56-4”[rn] OR “7783-77-9”[rn] OR “13939-06-5”[rn] OR “14221-06-8”[rn] OR “13814-74-9”[rn] OR “12027-67-7”[rn] OR “13106-76-8”[rn]) AND ((“Disulfides/toxicity”[mh] OR “Disulfides/adverse effects”[mh] OR “Disulfides/poisoning”[mh] OR “Disulfides/pharmacokinetics”[mh]) OR (“Disulfides/blood”[mh] OR “Disulfides/cerebrospinal fluid”[mh] OR “Disulfides/urine”[mh]) OR (“Disulfides/antagonists and inhibitors”[mh]) OR (“Disulfides/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“Disulfides/pharmacology”[majr]) OR (“Chlorides/toxicity”[mh] OR “Chlorides/adverse effects”[mh] OR “Chlorides/poisoning”[mh] OR “Chlorides/pharmacokinetics”[mh]) OR (“Chlorides/blood”[mh] OR “Chlorides/cerebrospinal fluid”[mh] OR “Chlorides/urine”[mh]) OR (“Chlorides/antagonists and inhibitors”[mh]) OR (“Chlorides/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“Chlorides/pharmacology”[majr]) OR (“Oxides/toxicity”[mh] OR “Oxides/adverse effects”[mh] OR “Oxides/poisoning”[mh] OR “Oxides/pharmacokinetics”[mh]) OR (“Oxides/blood”[mh] OR “Oxides/cerebrospinal fluid”[mh] OR “Oxides/urine”[mh]) OR; (“Oxides/antagonists and inhibitors”[mh]) OR (“Oxides/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“Oxides/pharmacology”[majr]) OR ((“disulfides”[mh] OR “chlorides”[mh] OR “oxides”[mh]) AND (“environmental exposure”[mh] OR ci[sh])) OR ((“disulfides”[mh] OR “chlorides”[mh] OR “oxides”[mh]) AND toxicokinetics[mh:noexp]) OR ((“disulfides”[mh] OR “chlorides”[mh] OR “oxides”[mh]) AND (“endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh])) OR ((“disulfides”[mh] OR “chlorides”[mh] OR “oxides”[mh]) AND (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic ”[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR ((“disulfides”[mh] OR “chlorides”[mh] OR “oxides”[mh]) AND cancer[sb])) AND (2013/12/01 : 3000[dp] OR 2014/12/01 : 3000[mhda])) OR “12027-67-7”[rn] OR (((“7439-98-7”[rn] OR “1317-33-5”[rn] OR “12033-29-3”[rn] OR “12033-33-9”[rn]; OR “11098-99-0”[rn] OR “18868-43-4”[rn] OR “1313-27-5”[rn] OR “1313-29-7”[rn] OR; “11098-84-3”[rn] OR “27546-07-2”[rn] OR “12054-85-2”[rn] OR “15060-55-6”[rn] OR “7631-95-0”[rn] OR “10102-40-6”[rn] OR “7789-82-4”[rn] OR “12011-97-1”[rn] OR “11119-46-3”[rn] OR “11062-51-4”[rn] OR “10241-05-1”[rn] OR “1309-56-4”[rn] OR “7783-77-9”[rn]; OR “13939-06-5”[rn] OR “14221-06-8”[rn] OR “13814-74-9”[rn] OR “12027-67-7”[rn] OR; “13106-76-8”[rn]) NOT (“molybdenum”[mh] OR “disulfides”[mh] OR “chlorides”[mh] OR “oxides”[mh])) AND (2013/12/01 : 3000[dp] OR 2014/12/01 : 3000[mhda])) OR ((“Ammonium molybdenum sulfide”[tw] OR “Ammonium tetrasulfidomolybdate(2-)”[tw] OR “Ammonium tetrathiomolybdate”[tw] OR “Ammonium thiomolybdate(VI)”[tw] OR “ATTM”[tw] OR “Bis(ammonium)tetrathiomolybdate(2-)”[tw] OR “Calcium molybdate”[tw] OR “Calcium molybdate(VI)”[tw] OR “Calcium molybdenate”[tw] OR “Calcium molybdenum oxide”[tw] OR “Coprexa”[tw] OR “Diammonium tetrakis(sulfido)molybdate(2-)”[tw] OR “Diammonium tetrakis(thioxo)molybdate”[tw] OR “Diammonium tetrasulfidomolybdate”[tw] OR “Diammonium tetrathiomolybdate”[tw] OR “Diammonium tetrathiomolybdate(2-)”[tw] OR “Diammonium tetrathiooxomolybdate(2-)”[tw] OR “Diammonium tetrathioxomolybdate(2-)”[tw] OR “Diammonium thiomolybdate”[tw] OR “Dimolybdenum tetraacetate”[tw] OR “Dimolybdenum trioxide”[tw] OR “Dodecachlorohexamolybdenum”[tw] OR “Hexafluoromolybdenum”[tw] OR “Hexamolybdenum dodecachloride”[tw] OR “MC 400WR”[tw] OR “Molybdate, calcium”[tw] OR “Molybdenite”[tw] OR “Molybdenum anhydride”[tw] OR “Molybdenum carbide”[tw] OR “Molybdenum chloride”[tw] OR “Molybdenum chloride oxide”[tw] OR “Molybdenum dioxide”[tw] OR “Molybdenum fluoride”[tw] OR “Molybdenum hexafluoride”[tw] OR “Molybdenum monocarbide”[tw] OR “Molybdenum oxide”[tw] OR “Molybdenum oxychloride”[tw] OR “Molybdenum oxytrichloride”[tw] OR “Molybdenum sesquioxide”[tw] OR “Molybdenum sulfide”[tw] OR “Molybdenum trichloride monoxide”[tw] OR “Molybdenum trichloride oxide”[tw] OR “Molybdenum trisulfide”[tw] OR “Molybdenum(6+) fluoride”[tw] OR “Molybdenum(II) acetate”[tw] OR “Molybdenum(IV) oxide”[tw] OR “Molybdic acid, calcium salt”[tw] OR “Octachlorohexamolybdenum(4+) tetrachloride”[tw] OR “Tetraacetatodimolybdenum”[tw] OR “tetrakis(acetato)di-Molybdenum”[tw] OR “Tetrakis(acetato)dimolybdenum”[tw] OR “Tetrakis(acetato)molybdenum”[tw] OR “Tetrakis(mu-(acetato-O:O’))dimolybdenum”[tw]; OR “tetrakis(mu-acetato)di-Molybdenum”[tw] OR “Tetrakis(mu-acetato)dimolybdenum”[tw] OR “tetrakis[mu-(acetato-O:O’)]di-Molybdenum”[tw] OR “Thiomolybdic acid (H2MoS4), diammonium salt”[tw] OR “Thiomolybdic acid, diammonium salt”[tw] OR “Tiomolibdate diammonium”[tw] OR “Trichlorooxomolybdenum”[tw] OR “Trichlorooxomolybdenum(V)”[tw]) AND (2013/12/01 : 3000[dp] OR 2014/12/01 : 3000[crdat] OR 2014/12/01 : 3000[edat])) OR (((“3N5”[tw] OR “A Powder”[tw] OR; “Ammonium dimolybdate”[tw] OR “Ammonium heptamolybdate”[tw] OR “Ammonium heptamolybdate tetrahydrate”[tw] OR “Ammonium molibdate”[tw] OR “Ammonium molibdenum oxide”[tw] OR “Ammonium molybdate”[tw] OR “Ammonium molybdate hydrate”[tw] OR “Ammonium molybdate tetrahydrate”[tw] OR “Ammonium molybdate(VI)”[tw] OR “Ammonium molybdenum oxide”[tw] OR “Ammonium molybdenum sulfide”[tw] OR “ammonium paramolybdate”[tw] OR “Ammonium paramolybdate tetrahydrate”[tw] OR “Ammonium tetrasulfidomolybdate(2-)”[tw] OR “Ammonium tetrathiomolybdate”[tw] OR “Ammonium thiomolybdate(VI)”[tw] OR “Amperit 105.054”[tw] OR “Amperit 106.2”[tw] OR “ATTM”[tw] OR “Bis(ammonium)tetrathiomolybdate(2-)”[tw] OR “Bouen SKN 301”[tw] OR “C-Powder”[tw] OR “Calcium molybdate”[tw] OR “Calcium molybdate(VI)”[tw] OR “Calcium molybdenate”[tw] OR “Calcium molybdenum oxide”[tw] OR “Coprexa”[tw] OR “DAG 206”[tw] OR “DAG 325”[tw] OR “DAG-V 657”[tw] OR “Defric coat HMB 2”[tw] OR “Diammonium dimolybdate”[tw] OR “Diammonium tetrakis(sulfido)molybdate(2-)”[tw] OR “Diammonium tetrakis(thioxo)molybdate”[tw] OR “Diammonium tetrasulfidomolybdate”[tw] OR “Diammonium tetrathiomolybdate”[tw] OR “Diammonium tetrathiomolybdate(2-)”[tw] OR “Diammonium tetrathiooxomolybdate(2-)”[tw] OR “Diammonium tetrathioxomolybdate(2-)”[tw] OR “Diammonium thiomolybdate”[tw] OR “Dimolybdenum tetraacetate”[tw] OR “Dimolybdenum trioxide”[tw] OR “dimolybdenum trisulfide ”[tw] OR “Disodium molybdate”[tw] OR “Disodium molybdate dihydrate”[tw] OR “Disodium tetraoxomolybdate”[tw] OR “DM 1 (sulfide)”[tw] OR “DMI 7”[tw] OR “Dodecachlorohexamolybdenum”[tw] OR “Hexaammonium heptamolybdate tetrahydrate”[tw] OR “Hexaammonium molybdate tetrahydrate”[tw] OR “Hexacarbonylmolybdenum”[tw] OR “Hexafluoromolybdenum”[tw] OR “Hexamolybdenum dodecachloride”[tw] OR “JCPDS 35-0609”[tw] OR “Liqui-Moly LM 11”[tw] OR “Liqui-Moly LM 2”[tw] OR “Liqui-Moly Z Powder”[tw] OR “LM 13”[tw] OR “MC 400WR”[tw] OR “MChVL”[tw] OR “MD 40”[tw] OR “Metco 63”[tw] OR “MF 000”[tw] OR “MIPO-M 15”[tw] OR; “Mo 1202T”[tw] OR “Mo-1202T”[tw] OR “Moly Fine Powder Y”[tw] OR “Moly Powder B”[tw] OR “Moly Powder C”[tw] OR “Moly Powder PA”[tw] OR “Moly Powder PB”[tw] OR “Moly Powder PS”[tw] OR “Molybdate (Mo2O72-), diammonium”[tw] OR “Molybdate (MoO42-), disodium, dihydrate, (T-4)-”[tw] OR “Molybdate, calcium”[tw] OR “Molybdena”[tw] OR “Molybdenite”[tw] OR “Molybdenum”[tw] OR “Molybdenum anhydride”[tw] OR “Molybdenum bisulfide”[tw] OR “Molybdenum carbide”[tw] OR “Molybdenum carbonyl”[tw] OR “Molybdenum chloride”[tw] OR “Molybdenum chloride oxide”[tw] OR “Molybdenum dioxide”[tw] OR “Molybdenum disulfide”[tw] OR “Molybdenum disulphide”[tw] OR “Molybdenum fluoride”[tw] OR “Molybdenum hexacarbonyl”[tw] OR “Molybdenum hexafluoride”[tw] OR “Molybdenum metallicum”[tw] OR “Molybdenum monocarbide”[tw] OR “Molybdenum oxide”[tw] OR “Molybdenum oxychloride”[tw] OR “Molybdenum oxytrichloride”[tw] OR “Molybdenum pentachloride”[tw] OR “Molybdenum peroxide”[tw] OR “Molybdenum sesquioxide”[tw] OR “Molybdenum sesquisulfide”[tw] OR “Molybdenum sodium oxide”[tw] OR “Molybdenum sulfide”[tw] OR “Molybdenum sulphide”[tw] OR “Molybdenum trichloride monoxide”[tw] OR “Molybdenum trichloride oxide”[tw] OR “Molybdenum trioxide”[tw] OR “Molybdenum trioxide pentamer”[tw] OR “Molybdenum trioxide tetramer”[tw] OR “Molybdenum trisulfide”[tw] OR “Molybdenum(6+) fluoride”[tw] OR “Molybdenum(II) acetate”[tw] OR “Molybdenum(II) chloride”[tw] OR “molybdenum(III) sulfide”[tw] OR “molybdenum(IV) oxide”[tw] OR “Molybdenum(IV) sulfide”[tw] OR “Molybdenum(V) chloride”[tw] OR “Molybdenum(VI) oxide”[tw] OR “Molybdenum(VI) trioxide”[tw] OR “Molybdenumperoxide”[tw] OR “Molybdic acid (H2Mo2O7), diammonium salt”[tw] OR “Molybdic acid (H2MoO4), calcium salt (1:1)”[tw] OR “Molybdic acid anhydride”[tw] OR “Molybdic acid, ammonium salt”[tw] OR “Molybdic acid, calcium salt”[tw] OR “Molybdic acid, disodium salt”[tw] OR “Molybdic acid, disodium salt, dihydrate”[tw] OR “Molybdic anhydride”[tw] OR “Molybdic oxide”[tw] OR “Molybdic trioxide”[tw] OR “Molycolloid CF 626”[tw] OR “Molyform 15”[tw] OR “Molyhibit 100”[tw] OR “Molyka R”[tw] OR “Molyka R-L 3”[tw] OR “Molyke R”[tw] OR “Molykote”[tw] OR “Molykote Microsize Powder”[tw] OR “Molykote Z”[tw] OR “Molykote Z Powder”[tw] OR “Molysulfide”[tw] OR “MOP-P 100”[tw] OR “Mopol M”[tw] OR “Mopol S”[tw] OR “Motimol”[tw] OR “MVCh 1”[tw] OR “Natural molybdenite”[tw] OR “Natural molybdite”[tw] OR “NeoZ”[tw] OR “Nichimoly C”[tw] OR “Octachlorohexamolybdenum(4+) tetrachloride”[tw] OR “OKS 110”[tw] OR “PA Powder”[tw] OR “Pentachloromolybdenum Molybdenite”[tw] OR “Pigment Black 34”[tw] OR “Pol-U”[tw] OR “Powder PA”[tw] OR “RAC 01”[tw] OR “SGC 15”[tw] OR “Sodium molybdate”[tw] OR “Sodium molybdate dihydrate”[tw] OR “Sodium molybdate(VI)”[tw] OR “Sodium molybdate(VI) dihydrate”[tw] OR “Sodium molybdenate”[tw] OR “Sodium molybdenum oxide”[tw] OR “Sodium tetraoxomolybdate(2-)”[tw] OR “Solvest 390A”[tw] OR “Sumipowder PA”[tw] OR “T-Powder”[tw] OR “Tetraacetatodimolybdenum”[tw] OR “tetrakis(acetato)di-Molybdenum”[tw] OR “Tetrakis(acetato)dimolybdenum”[tw] OR “Tetrakis(acetato)molybdenum”[tw] OR “Tetrakis(mu-(acetato-O:O’))dimolybdenum”[tw] OR “tetrakis(mu-acetato)di-Molybdenum”[tw] OR “Tetrakis(mu-acetato)dimolybdenum”[tw] OR “tetrakis[mu-(acetato-O:O’)]di-Molybdenum”[tw] OR “Thiomolybdic acid, diammonium salt”[tw] OR “Tiomolibdate diammonium”[tw] OR “TMOIO”[tw] OR “Trichlorooxomolybdenum”[tw] OR “Trichlorooxomolybdenum(V)”[tw] OR “TsM1”[tw] OR “UP 10”[tw] OR “UP 50”[tw] OR (“Hexaammonium heptamolybdate”[tw] OR “Hexammonium heptamolybdat”[tw] OR “Hexammonium tetracosaoxoheptamolybdate”[tw] OR “Molybdate (Mo7O24), hexammonium”[tw] OR “Molybdate (Mo7O246-), ammonium (1:6)”[tw] OR “Molybdate (Mo7O246-), hexaammonium”[tw] OR “Molybdate, hexaammonium”[tw] OR “Molybdic acid (H6Mo7O24), hexaammonium salt”[tw] OR “Molybdic acid, hexaammonium salt”[tw] OR “Diammonium molybdate”[tw] OR “Diammonium tetraoxomolybdate(2-)”[tw] OR “Molybdate (MoO42-), ammonium (1:2), (T-4)-”[tw] OR “Molybdate (MoO42-), diammonium, (beta-4)-”[tw] OR “Molybdate (MoO42-), diammonium, (T-4)-”[tw] OR “Molybdic acid (H2MoO4), diammonium salt”[tw] OR “Molybdic acid, diammonium salt”[tw])) NOT medline[sb]) AND (2013/12/01 : 3000[dp] OR 2014/12/01 : 3000[crdat] OR 2014/12/01 : 3000[edat]))
Toxline
01/2018 | Date limit 2013 to present:
| 7439-98-7[rn] OR 1317-33-5[rn] OR 12033-29-3[rn] OR 12033-33-9[rn] OR 11098-99-0[rn] OR 18868-43-4[rn] OR 1313-27-5[rn] OR 1313-29-7[rn] OR 11098-84-3[rn] OR 27546-07-2[rn] OR 12054-85-2[rn] OR 15060-55-6[rn] OR 7631-95-0[rn] OR 10102-40-6[rn] OR; 7789-82-4[rn] OR 12011-97-1[rn] OR 11119-46-3[rn] OR 11062-51-4[rn] OR 10241-05-1[rn] OR 1309-56-4[rn] OR 7783-77-9[rn] OR 13939-06-5[rn] OR 14221-06-8[rn] OR; 13814-74-9[rn]
| “3N5” OR “Ammonium dimolybdate” OR “Ammonium heptamolybdate” OR “Ammonium heptamolybdate tetrahydrate” OR “Ammonium molibdate” OR “Ammonium molibdenum oxide” OR “Ammonium molybdate” OR “Ammonium molybdate hydrate” OR “Ammonium molybdate tetrahydrate” OR “Ammonium molybdate(VI)” OR “Ammonium molybdenum oxide”
| “Ammonium molybdenum sulfide” OR “ammonium paramolybdate” OR “Ammonium paramolybdate tetrahydrate” OR “Ammonium tetrasulfidomolybdate(2-)” OR “Ammonium tetrathiomolybdate” OR “Ammonium thiomolybdate(VI)” OR “Amperit 105.054” OR “Amperit 106.2” OR “ATTM” OR “Bis(ammonium)tetrathiomolybdate(2-)” OR “Bouen SKN 301” OR “C-Powder” OR “Calcium molybdate”
| “Calcium molybdate(VI)” OR “Calcium molybdenate” OR “Calcium molybdenum oxide” OR “Coprexa” OR “DAG 206” OR “DAG 325” OR “DAG-V 657” OR “Defric coat HMB 2” OR; “Diammonium dimolybdate” OR “Diammonium tetrakis(sulfido)molybdate(2-)” OR “Diammonium tetrakis(thioxo)molybdate” OR “Diammonium tetrasulfidomolybdate” OR “Diammonium tetrathiomolybdate”
| “Diammonium tetrathiomolybdate(2-)” OR “Diammonium tetrathiooxomolybdate(2-)” OR “Diammonium tetrathioxomolybdate(2-)” OR “Diammonium thiomolybdate” OR “Dimolybdenum tetraacetate” OR “Dimolybdenum trioxide” OR “dimolybdenum trisulfide ” OR “Disodium molybdate” OR “Disodium molybdate dihydrate” OR “Disodium tetraoxomolybdate” OR “DM 1 (sulfide)” OR “DMI 7”
| “Dodecachlorohexamolybdenum” OR “Hexaammonium heptamolybdate tetrahydrate” OR “Hexaammonium molybdate tetrahydrate” OR “Hexacarbonylmolybdenum” OR “Hexafluoromolybdenum” OR “Hexamolybdenum dodecachloride” OR “JCPDS 35-0609” OR “Liqui-Moly LM 11” OR “Liqui-Moly LM 2” OR “Liqui-Moly Z Powder” OR “LM 13” OR “M 5” OR “MC 400WR”
| “MChVL” OR “MD 40” OR “Metco 63” OR “MF 000” OR “MFR” OR “MIPO-M 15” OR “Mo; 1202T” OR “Mo-1202T” OR “Moly Fine Powder Y” OR “Moly Powder B” OR “Moly Powder C” OR “Moly Powder PA” OR “Moly Powder PB” OR “Moly Powder PS” OR “Molybdate (Mo2O72-), diammonium” OR “Molybdate (MoO42-), disodium, dihydrate, (T-4)-” OR “Molybdate, calcium” OR “Molybdena” OR “Molybdenite”
| “Molybdenum” OR “Molybdenum anhydride” OR “Molybdenum bisulfide” OR “Molybdenum carbide” OR “Molybdenum carbonyl” OR “Molybdenum chloride” OR “Molybdenum chloride oxide” OR “Molybdenum dioxide” OR “Molybdenum disulfide” OR “Molybdenum disulphide” OR “Molybdenum fluoride” OR “Molybdenum hexacarbonyl” OR “Molybdenum hexafluoride”
| “Molybdenum metallicum” OR “Molybdenum monocarbide” OR “Molybdenum oxide” OR “Molybdenum oxychloride” OR “Molybdenum oxytrichloride” OR “Molybdenum pentachloride” OR “Molybdenum peroxide” OR “Molybdenum sesquioxide” OR “Molybdenum sesquisulfide” OR “Molybdenum sodium oxide” OR “Molybdenum sulfide” OR “Molybdenum sulphide” OR “Molybdenum trichloride monoxide”
| “Molybdenum trichloride oxide” OR “Molybdenum trioxide” OR “Molybdenum trioxide pentamer” OR “Molybdenum trioxide tetramer” OR “Molybdenum trisulfide” OR “Molybdenum(6+) fluoride” OR “Molybdenum(II) acetate” OR “Molybdenum(II) chloride” OR “molybdenum(III) sulfide” OR “molybdenum(IV) oxide” OR “Molybdenum(IV) sulfide” OR “Molybdenum(V) chloride”
| “Molybdenum(VI) oxide” OR “Molybdenum(VI) trioxide” OR “Molybdenumperoxide” OR “Molybdic acid (H2Mo2O7), diammonium salt” OR “Molybdic acid (H2MoO4), calcium salt (1:1)” OR “Molybdic acid anhydride” OR “Molybdic acid, ammonium salt” OR “Molybdic acid, calcium salt” OR “Molybdic acid, disodium salt” OR “Molybdic acid, disodium salt, dihydrate” OR “Molybdic anhydride”
| “Molybdic oxide” OR “Molybdic trioxide” OR “Molycolloid CF 626” OR “Molyform 15” OR “Molyhibit 100” OR “Molyka R” OR “Molyka R-L 3” OR “Molyke R” OR “Molykote” OR “Molykote Microsize Powder” OR “Molykote Z” OR “Molykote Z Powder” OR “Molysulfide”
| OR “MOP-P 100” OR “Mopol M” OR “Mopol S” OR “Motimol” OR “MVCh 1” OR “Natural molybdenite” OR “Natural molybdite” OR “NeoZ”
| “Nichimoly C” OR “Octachlorohexamolybdenum(4+) tetrachloride” OR “OKS 110” OR “PA Powder” OR “Pentachloromolybdenum Molybdenite” OR “Pigment Black 34” OR “Pol-U” OR “Powder PA” OR “RAC 01” OR “SGC 15” OR “Sodium molybdate” OR “Sodium molybdate dihydrate” OR “Sodium molybdate(VI)” OR “Sodium molybdate(VI) dihydrate” OR “Sodium molybdenate”
| “Sodium molybdenum oxide” OR “Sodium tetraoxomolybdate(2-)” OR “Solvest 390A” OR “Sumipowder PA” OR “T-Powder” OR “Tetraacetatodimolybdenum” OR “tetrakis(acetato)di-Molybdenum” OR “Tetrakis(acetato)dimolybdenum” OR “Tetrakis(acetato)molybdenum” OR “Tetrakis(mu-(acetato-O:O’))dimolybdenum” OR “tetrakis(μ-acetato)di-Molybdenum” OR “Tetrakis(μ-acetato)dimolybdenum”
| “tetrakis[μ-(acetato-O:O’)]di-Molybdenum” OR “Thiomolybdic acid, diammonium salt” OR “Tiomolibdate diammonium” OR “TMOIO” OR “Trichlorooxomolybdenum” OR “Trichlorooxomolybdenum(V)” OR “TsM1”
| No date limit:
| “Hexaammonium heptamolybdate” OR “Hexammonium heptamolybdat” OR “Hexammonium tetracosaoxoheptamolybdate” OR “Molybdate (Mo7O24), hexammonium” OR “Molybdate (Mo7O246-), ammonium (1:6)” OR “Molybdate (Mo7O246-), hexaammonium” OR “Molybdate, hexaammonium” OR “Molybdic acid (H6Mo7O24), hexaammonium salt” OR “Molybdic acid, hexaammonium salt” OR 12027-67-7[rn]
| “Diammonium molybdate” OR “Diammonium tetraoxomolybdate(2-)” OR “Molybdate (MoO42-), ammonium (1:2), (T-4)-” OR “Molybdate (MoO42-), diammonium, (beta-4)-” OR “Molybdate (MoO42-), diammonium, (T-4)-” OR “Molybdic acid (H2MoO4), diammonium salt” OR “Molybdic acid, diammonium salt” OR 13106-76-8[rn]
Toxcenter
01/2018 | (FILE ’HOME’ ENTERED AT 14:16:56 ON 12 JAN 2018); FILE ’TOXCENTER’ ENTERED AT 14:17:07 ON 12 JAN 2018 CHARGED TO COST=EH011.05.LB.02.05; L1 34132 SEA FILE=TOXCENTER 7439-98-7 OR 1317-33-5 OR 12033-29-3 OR; 12033-33-9 OR 11098-99-0 OR 18868-43-4 OR 1313-27-5 OR; 1313-29-7 OR 11098-84-3 OR 27546-07-2 OR 12054-85-2 OR; 15060-55-6 OR 7631-95-0 OR 10102-40-6; L2 523 SEA FILE=TOXCENTER 7789-82-4 OR 12011-97-1 OR 11119-46-3 OR; 11062-51-4 OR 10241-05-1 OR 1309-56-4 OR 7783-77-9 OR 13939-06-5 OR 14221-06-8 OR 13814-74-9; L3 1148 SEA FILE=TOXCENTER 12027-67-7 OR 13106-76-8; L4 34486 SEA FILE=TOXCENTER L1 OR L2; L5 636 SEA FILE=TOXCENTER L3 NOT L4; L6 35122 SEA FILE=TOXCENTER L1 OR L2 OR L3; L7 22953 SEA FILE=TOXCENTER L6 NOT PATENT/DT; L8 22927 SEA FILE=TOXCENTER L7 NOT TSCATS/FS; ACT TOXQUERY/Q; --------; L9 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?); L10 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT, IT); L11 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50); L12 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT; L13 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?); L14 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?); L15 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS OR; DIETARY OR DRINKING(W)WATER?); L16 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE)); L17 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?); L18 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM?; OR; OVUM?); L19 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?); L20 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?); L21 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR SPERMATOB? OR SPERMATOC? OR SPERMATOG?); L22 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR; SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?); L23 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?); L24 QUE (ENDOCRIN? AND DISRUPT?); L25 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?); L26 QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?); L27 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?); L28 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR NEOPLAS?); L29 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?); L30 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?); L31 QUE (NEPHROTOX? OR HEPATOTOX?); L32 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?); L33 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?); L34 QUE L9 OR L10 OR L11 OR L12 OR L13 OR L14 OR L15 OR L16 OR L17; OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26; OR L27 OR L28 OR L29 OR L30 OR L31 OR L32 OR L33; L35 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE; OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR; SWINE; OR PORCINE OR MONKEY? OR MACAQUE?); L36 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA; OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE); L37 QUE L34 OR L35 OR L36; L38 QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL? OR; PRIMATES OR PRIMATE?); L39 QUE L37 OR L38; --------; L40 8795 SEA FILE=TOXCENTER L8 AND L39; L41 1436 SEA FILE=TOXCENTER L40 AND ED>=20141201; L42 1422 SEA FILE=TOXCENTER L41 AND PY>2012; L43 184 SEA FILE=TOXCENTER L40 AND L3; L44 1597 SEA FILE=TOXCENTER L41 OR L43; L45 0 SEA FILE=TOXCENTER L44 AND MEDLINE/SB; L46 269 SEA FILE=TOXCENTER L44 AND MEDLINE/FS; L47 263 SEA FILE=TOXCENTER L44 AND BIOSIS/FS; L48 1050 SEA FILE=TOXCENTER L44 AND CAPLUS/FS; L49 15 SEA FILE=TOXCENTER L44 NOT (L46 OR L47 OR L48); L50 1425 DUP REM L46 L47 L49 L48 (172 DUPLICATES REMOVED) ANSWERS ’1-1425’ FROM FILE TOXCENTER; L*** DEL 269 S L44 AND MEDLINE/FS; L*** DEL 269 S L44 AND MEDLINE/FS; L51 269 SEA FILE=TOXCENTER L50; L*** DEL 263 S L44 AND BIOSIS/FS; L*** DEL 263 S L44 AND BIOSIS/FS; L52 234 SEA FILE=TOXCENTER L50; L*** DEL 1050 S L44 AND CAPLUS/FS; L*** DEL 1050 S L44 AND CAPLUS/FS; L53 908 SEA FILE=TOXCENTER L50; L*** DEL 15 S L44 NOT (L46 OR L47 OR L48); L*** DEL 15 S L44 NOT (L46 OR L47 OR L48); L54 14 SEA FILE=TOXCENTER L50; L55 211 SEA FILE=TOXCENTER (L51 OR L52 OR L53 OR L54) AND BIOSIS/FS AND ED>=20141201; L*** DEL 269 S L44 AND MEDLINE/FS; L*** DEL 269 S L44 AND MEDLINE/FS; L56 269 SEA FILE=TOXCENTER L50; L*** DEL 263 S L44 AND BIOSIS/FS; L*** DEL 263 S L44 AND BIOSIS/FS; L57 234 SEA FILE=TOXCENTER L50; L*** DEL 1050 S L44 AND CAPLUS/FS; L*** DEL 1050 S L44 AND CAPLUS/FS; L58 908 SEA FILE=TOXCENTER L50; L*** DEL 15 S L44 NOT (L46 OR L47 OR L48); L*** DEL 15 S L44 NOT (L46 OR L47 OR L48); L59 14 SEA FILE=TOXCENTER L50; L60 826 SEA FILE=TOXCENTER (L56 OR L57 OR L58 OR L59) AND CAPLUS/FS AND ED>=20141201; L*** DEL 269 S L44 AND MEDLINE/FS; L*** DEL 269 S L44 AND MEDLINE/FS; L61 269 SEA FILE=TOXCENTER L50; L*** DEL 263 S L44 AND BIOSIS/FS; L*** DEL 263 S L44 AND BIOSIS/FS; L62 234 SEA FILE=TOXCENTER L50; L*** DEL 1050 S L44 AND CAPLUS/FS; L*** DEL 1050 S L44 AND CAPLUS/FS; L63 908 SEA FILE=TOXCENTER L50; L*** DEL 15 S L44 NOT (L46 OR L47 OR L48); L*** DEL 15 S L44 NOT (L46 OR L47 OR L48); L64 14 SEA FILE=TOXCENTER L50; L65 0 SEA FILE=TOXCENTER (L61 OR L62 OR L63 OR L64) NOT (CAPLUS/FS OR MEDLINE/FS OR BIOSIS/FS) AND ED>=20141201; L*** DEL 269 S L44 AND MEDLINE/FS; L*** DEL 269 S L44 AND MEDLINE/FS; L66 269 SEA FILE=TOXCENTER L50; L*** DEL 263 S L44 AND BIOSIS/FS; L*** DEL 263 S L44 AND BIOSIS/FS; L67 234 SEA FILE=TOXCENTER L50; L*** DEL 1050 S L44 AND CAPLUS/FS; L*** DEL 1050 S L44 AND CAPLUS/FS L68 908 SEA FILE=TOXCENTER L50; L*** DEL 15 S L44 NOT (L46 OR L47 OR L48); L*** DEL 15 S L44 NOT (L46 OR L47 OR L48); L69 14 SEA FILE=TOXCENTER L50; L70 150 SEA FILE=TOXCENTER (L66 OR L67 OR L68 OR L69) NOT ED>=20141201; L71 23 SEA FILE=TOXCENTER L70 AND BIOSIS/FS; L72 14 SEA FILE=TOXCENTER L70 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS); L73 82 SEA FILE=TOXCENTER L70 AND CAPLUS/FS; L74 52 SEA FILE=TOXCENTER L60 AND ?MOLYB?/TI; L75 29 SEA FILE=TOXCENTER L73 AND ?MOLYB?/TI; D SCAN L55; L76 37 SEA FILE=TOXCENTER L71 OR L72 D SCAN L76; D SCAN L74 D SCAN L75; L*** DEL 269 S L44 AND MEDLINE/FS; L*** DEL 269 S L44 AND MEDLINE/FS; L77 269 SEA FILE=TOXCENTER L50 L*** DEL 263 S L44 AND BIOSIS/FS; L*** DEL 263 S L44 AND BIOSIS/FS; L78 234 SEA FILE=TOXCENTER L50; L*** DEL 1050 S L44 AND CAPLUS/FS; L*** DEL 1050 S L44 AND CAPLUS/FS; L79 908 SEA FILE=TOXCENTER L50; L*** DEL 15 S L44 NOT (L46 OR L47 OR L48); L*** DEL 15 S L44 NOT (L46 OR L47 OR L48) L80 14 SEA FILE=TOXCENTER L50; L81 1275 SEA FILE=TOXCENTER (L77 OR L78 OR L79 OR L80) AND ED>=20141201; L82 1265 SEA FILE=TOXCENTER L81 AND (L1 OR L2); L83 1012 SEA FILE=TOXCENTER L81 NOT (L55 OR L74); L84 84 SEA FILE=TOXCENTER L70 NOT (L76 OR L75); D SCAN L84; D SCAN L83; (FILE ’HOME’ ENTERED AT 20:36:59 ON 14 JAN 2018); FILE ’TOXCENTER’ ENTERED AT 20:37:09 ON 14 JAN 2018 CHARGED TO COST=EH011.05.LB.02.05; ACT MOLY1/A
| L1 ( 34132)SEA FILE=TOXCENTER 7439-98-7 OR 1317-33-5 OR; 12033-29-3 OR 12033-33-9 OR 11098-99-0 OR 18868-43-4 OR 1313-27-5 OR; 1313-29-7 OR 11098-84-3 OR 27546-07-2 OR 12054-85-2 OR; 15060-55-6 OR 7631-95-0 OR 10102-40-6; L2 ( 523)SEA FILE=TOXCENTER 7789-82-4 OR 12011-97-1 OR 11119-46-3 OR 11062-51-4 OR 10241-05-1 OR 1309-56-4 OR 7783-77-9 OR 13939-06-5 OR 14221-06-8 OR 13814-74-9; L3 ( 1148)SEA FILE=TOXCENTER 12027-67-7 OR 13106-76-8 L4 ( 35122)SEA FILE=TOXCENTER L1 OR L2 OR L3; L5 ( 22953)SEA FILE=TOXCENTER L4 NOT PATENT/DT; L6 ( 22927)SEA FILE=TOXCENTER L5 NOT TSCATS/FS; L7 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?); L8 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT, IT); L9 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50); L10 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT; L11 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?); L12 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?); L13 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS; OR; DIETARY OR DRINKING(W)WATER?); L14 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE)); L15 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?); L16 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM?; OR; OVUM?); L17 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?); L18 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?); L19 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR; SPERMATOB? OR SPERMATOC? OR SPERMATOG?); L20 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR; SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?) L21 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?); L22 QUE (ENDOCRIN? AND DISRUPT?); L23 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?); L24 QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?); L25 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?); L26 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR; NEOPLAS?); L27 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?); L28 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?); L29 QUE (NEPHROTOX? OR HEPATOTOX?); L30 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?); L31 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?); L32 QUE L7 OR L8 OR L9 OR L10 OR L11 OR L12 OR L13 OR L14 OR L15 OR L16 OR L17 OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26 OR L27 OR L28 OR L29 OR L30 OR L31; L33 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE; OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR; SWINE; OR PORCINE OR MONKEY? OR MACAQUE?); L34 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA; OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE); L35 QUE L32 OR L33 OR L34; L36 QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL? OR; PRIMATES OR PRIMATE?); L37 QUE L35 OR L36; L38 ( 8795)SEA FILE=TOXCENTER L6 AND L37; L39 ( 1436)SEA FILE=TOXCENTER L38 AND ED>=20141201; L40 ( 184)SEA FILE=TOXCENTER L38 AND L3; L41 ( 1597)SEA FILE=TOXCENTER L39 OR L40; L42 ( 269)SEA FILE=TOXCENTER L41 AND MEDLINE/FS; L43 ( 263)SEA FILE=TOXCENTER L41 AND BIOSIS/FS; L44 ( 1050)SEA FILE=TOXCENTER L41 AND CAPLUS/FS; L45 ( 15)SEA FILE=TOXCENTER L41 NOT (L42 OR L43 OR L44); L46 ( 1425)DUP REM L42 L43 L45 L44 (172 DUPLICATES REMOVED); L47 ( 269)SEA FILE=TOXCENTER L46; L48 ( 234)SEA FILE=TOXCENTER L46; L49 ( 908)SEA FILE=TOXCENTER L46; L50 ( 14)SEA FILE=TOXCENTER L46; L51 ( 211)SEA FILE=TOXCENTER (L47 OR L48 OR L49 OR L50) AND BIOSIS/FS AND ED>=20141201; L52 ( 269)SEA FILE=TOXCENTER L46; L53 ( 234)SEA FILE=TOXCENTER L46; L54 ( 908)SEA FILE=TOXCENTER L46; L55 ( 14)SEA FILE=TOXCENTER L46; L56 ( 826)SEA FILE=TOXCENTER (L52 OR L53 OR L54 OR L55) AND CAPLUS/FS AND ED>=20141201; L57 ( 52)SEA FILE=TOXCENTER L56 AND ?MOLYB?/TI; L58 ( 269)SEA FILE=TOXCENTER L46; L59 ( 234)SEA FILE=TOXCENTER L46; L60 ( 908)SEA FILE=TOXCENTER L46; L61 ( 14)SEA FILE=TOXCENTER L46; L62 ( 1275)SEA FILE=TOXCENTER (L58 OR L59 OR L60 OR L61) AND ED>=20141201; L63 1012 SEA FILE=TOXCENTER L62 NOT (L51 OR L57); --------; L64 97 SEA FILE=TOXCENTER L63 AND (MOLYB?/TI OR DIMOLYB?/TI OR DODECACHLOROHEXAMOLYB?/TI OR HEPTAMOLYB?/TI OR; HEXACARBONYLMOLY; B?/TI OR HEXAFLUOROMOLYB?/TI OR HEXAMOLYB?/TI OR OCTACHLOROHEXA; MOLYB?/TI OR PARAMOLYB?/TI); L65 5 SEA FILE=TOXCENTER L63 AND (PENTACHLOROMOLYB?/TI OR TETRAACETAT; ODIMOLYB?/TI OR TETRAOXOMOLYB?/TI OR TETRASULFIDOMOLYB?/TI; OR; TETRATHIOMOLYB?/TI OR TETRATHIOOXOMOLYB?/TI OR THIOMOLYB?/TI OR TRICHLOROOXOMOLYB?/TI); L66 1 SEA FILE=TOXCENTER L63 AND (“3N5”/TI OR “AMMONIUM MOLIBDATE”/TI; OR “AMMONIUM MOLIBDENUM OXIDE”/TI OR “AMPERIT 105.054”/TI OR “AMPERIT 106.2”/TI OR “ATTM”/TI OR “BIS(AMMONIUM)TETRATHIOMOLYB DATE(2-)”/TI OR “BOUEN SKN 301”/TI); L67 0 SEA FILE=TOXCENTER L63 AND (“C-POWDER”/TI OR “COPREXA”/TI OR “DAG 206”/TI OR “DAG 325”/TI OR “DAG-V 657”/TI OR “DEFRIC COAT; HMB 2”/TI OR “DM 1 (SULFIDE)”/TI OR “DMI 7”/TI OR “JCPDS 35-0609”/TI OR “LIQUI-MOLY LM 11”/TI OR “LIQUI-MOLY LM 2”/TI); L68 0 SEA FILE=TOXCENTER L63 AND (“LIQUI-MOLY Z POWDER”/TI OR “LM 13”/TI OR “MC 400WR”/TI OR “MCHVL”/TI OR “MD 40”/TI OR “METCO 63”/TI OR “MF 000”/TI OR “MIPO-M 15”/TI OR “MO 1202T”/TI OR “MO-1202T”/TI OR “MOLY FINE POWDER Y”/TI); L69 0 SEA FILE=TOXCENTER L63 AND (“MOLY POWDER B”/TI OR “MOLY POWDER; C”/TI OR “MOLY POWDER PA”/TI OR “MOLY POWDER PB”/TI OR “MOLY POWDER PS”/TI OR “MOLYCOLLOID CF 626”/TI OR “MOLYFORM 15”/TI OR “MOLYHIBIT 100”/TI OR “MOLYKA R”/TI OR “MOLYKA R-L 3”/TI); L70 0 SEA FILE=TOXCENTER L63 AND (“MOLYKE R”/TI OR “MOLYKOTE”/TI OR “MOLYKOTE MICROSIZE POWDER”/TI OR “MOLYKOTE Z”/TI OR “MOLYKOTE; Z POWDER”/TI OR “MOLYSULFIDE”/TI OR “MOP-P 100”/TI OR “MOPOL M”/TI OR “MOPOL S”/TI OR “MOTIMOL”/TI OR “MVCH 1”/TI); L71 0 SEA FILE=TOXCENTER L63 AND (“NEOZ”/TI OR “NICHIMOLY C”/TI OR; “OKS 110”/TI OR “PA POWDER”/TI OR “PIGMENT BLACK 34”/TI OR “POL-U”/TI OR “POWDER PA”/TI OR “RAC 01”/TI OR “SGC 15”/TI OR “SOLVEST 390A”/TI OR “SUMIPOWDER PA”/TI OR “T-POWDER”/TI OR “TIOMOLIBDATE DIAMMONIUM”/TI OR “TMOIO”/TI OR “TSM1”/TI); L72 103 SEA FILE=TOXCENTER L64 OR L65 OR L66; D SCAN L72; ACT MOLY2/A; --------; L76 ( 34132)SEA FILE=TOXCENTER 7439-98-7 OR 1317-33-5 OR; 12033-29-3 OR 12033-33-9 OR 11098-99-0 OR 18868-43-4 OR 1313-27-5 OR; 1313-29-7 OR 11098-84-3 OR 27546-07-2 OR 12054-85-2 OR; 15060-55-6 OR 7631-95-0 OR 10102-40-6; L77 ( 523)SEA FILE=TOXCENTER 7789-82-4 OR 12011-97-1 OR 11119-46-3 OR 11062-51-4 OR 10241-05-1 OR 1309-56-4 OR 7783-77-9 OR 13939-06-5 OR 14221-06-8 OR 13814-74-9; L78 ( 1148)SEA FILE=TOXCENTER 12027-67-7 OR 13106-76-8; L79 ( 35122)SEA FILE=TOXCENTER L76 OR L77 OR L78; L80 ( 22953)SEA FILE=TOXCENTER L79 NOT PATENT/DT; L81 ( 22927)SEA FILE=TOXCENTER L80 NOT TSCATS/FS; L82 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?); L83 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT, IT); L84 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50); L85 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT; L86 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?); L87 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?); L88 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS; OR; DIETARY OR DRINKING(W)WATER?); L89 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE)); L90 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?); L91 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM?; OR; OVUM?); L92 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?); L93 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR; TERATOGEN?); L94 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR; SPERMATOB? OR SPERMATOC? OR SPERMATOG?); L95 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR; SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?); L96 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?); L97 QUE (ENDOCRIN? AND DISRUPT?); L98 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?); L99 QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?); L100 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?) L101 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER?; OR; NEOPLAS?); L102 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?); L103 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?); L104 QUE (NEPHROTOX? OR HEPATOTOX?); L105 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?); L106 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?); L107 QUE L82 OR L83 OR L84 OR L85 OR L86 OR L87 OR L88 OR L89 OR L90 OR L91 OR L92 OR L93 OR L94 OR L95 OR L96 OR L97 OR L98 OR L99 OR L100 OR L101 OR L102 OR L103 OR L104 OR L105 OR L106; L108 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE; OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR; SWINE; OR PORCINE OR MONKEY? OR MACAQUE?); L109 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA; OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE) L110 QUE L107 OR L108 OR L109; L111 QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL?; OR; PRIMATES OR PRIMATE?); L112 QUE L110 OR L111; L113( 8795)SEA FILE=TOXCENTER L81 AND L112; L114( 1436)SEA FILE=TOXCENTER L113 AND ED>=20141201; L115( 184)SEA FILE=TOXCENTER L113 AND L78; L116( 1597)SEA FILE=TOXCENTER L114 OR L115; L117( 269)SEA FILE=TOXCENTER L116 AND MEDLINE/FS; L118( 263)SEA FILE=TOXCENTER L116 AND BIOSIS/FS; L119( 1050)SEA FILE=TOXCENTER L116 AND CAPLUS/FS; L120( 15)SEA FILE=TOXCENTER L116 NOT (L117 OR L118 OR L119); L121( 1425)DUP REM L117 L118 L120 L119 (172 DUPLICATES REMOVED); L122( 269)SEA FILE=TOXCENTER L121; L123( 234)SEA FILE=TOXCENTER L121; L124( 908)SEA FILE=TOXCENTER L121; L125( 14)SEA FILE=TOXCENTER L121; L126( 150)SEA FILE=TOXCENTER (L122 OR L123 OR L124 OR L125) NOT ED>=20141; L127( 23)SEA FILE=TOXCENTER L126 AND BIOSIS/FS; L128( 14)SEA FILE=TOXCENTER L126 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/; L129( 82)SEA FILE=TOXCENTER L126 AND CAPLUS/FS; L130( 29)SEA FILE=TOXCENTER L129 AND ?MOLYB?/TI; L131( 37)SEA FILE=TOXCENTER L127 OR L128; L132 84 SEA FILE=TOXCENTER L126 NOT (L131 OR L130); L133 15 SEA FILE=TOXCENTER L132 AND (MOLYB?/TI OR DIMOLYB?/TI OR DODECACHLOROHEXAMOLYB?/TI OR HEPTAMOLYB?/TI OR; HEXACARBONYLMOLY; B?/TI OR HEXAFLUOROMOLYB?/TI OR HEXAMOLYB?/TI OR OCTACHLOROHEXA; MOLYB?/TI OR PARAMOLYB?/TI); L134 0 SEA FILE=TOXCENTER L1L32 AND (PENTACHLOROMOLYB?/TI OR TETRAACET; ATODIMOLYB?/TI OR TETRAOXOMOLYB?/TI OR TETRASULFIDOMOLYB?/TI; OR TETRATHIOMOLYB?/TI OR TETRATHIOOXOMOLYB?/TI OR THIOMOLYB?/TI; OR TRICHLOROOXOMOLYB?/TI); L135 0 SEA FILE=TOXCENTER L132 AND (“3N5”/TI OR “AMMONIUM MOLIBDATE”/T; I OR “AMMONIUM MOLIBDENUM OXIDE”/TI OR “AMPERIT 105.054”/TI OR “AMPERIT 106.2”/TI OR “ATTM”/TI OR “BIS(AMMONIUM)TETRATHIOMOLYB DATE(2-)”/TI OR “BOUEN SKN 301”/TI); L136 0 SEA FILE=TOXCENTER L132 AND (“C-POWDER”/TI OR “COPREXA”/TI OR; “DAG 206”/TI OR “DAG 325”/TI OR “DAG-V 657”/TI OR “DEFRIC COAT HMB 2”/TI OR “DM 1 (SULFIDE)”/TI OR “DMI 7”/TI OR “JCPDS 35-0609”/TI OR “LIQUI-MOLY LM 11”/TI OR “LIQUI-MOLY LM 2”/TI); L137 0 SEA FILE=TOXCENTER L132 AND (“LIQUI-MOLY Z POWDER”/TI OR “LM 13”/TI OR “MC 400WR”/TI OR “MCHVL”/TI OR “MD 40”/TI OR “METCO 63”/TI OR “MF 000”/TI OR “MIPO-M 15”/TI OR “MO 1202T”/TI OR “MO-1202T”/TI OR “MOLY FINE POWDER Y”/TI); L138 0 SEA FILE=TOXCENTER L132 AND (“MOLY POWDER B”/TI OR “MOLY POWDER C”/TI OR “MOLY POWDER PA”/TI OR “MOLY POWDER PB”/TI OR “MOLY POWDER PS”/TI OR “MOLYCOLLOID CF 626”/TI OR “MOLYFORM 15”/TI OR “MOLYHIBIT 100”/TI OR “MOLYKA R”/TI OR “MOLYKA R-L 3”/TI); L139 0 SEA FILE=TOXCENTER L132 AND (“MOLYKE R”/TI OR “MOLYKOTE”/TI OR; “MOLYKOTE MICROSIZE POWDER”/TI OR “MOLYKOTE Z”/TI OR “MOLYKOTE; Z POWDER”/TI OR “MOLYSULFIDE”/TI OR “MOP-P 100”/TI OR “MOPOL M”/TI OR “MOPOL S”/TI OR “MOTIMOL”/TI OR “MVCH 1”/TI); L140 0 SEA FILE=TOXCENTER L132 AND (“NEOZ”/TI OR “NICHIMOLY C”/TI OR “OKS 110”/TI OR “PA POWDER”/TI OR “PIGMENT BLACK 34”/TI OR; “POL-U”/TI OR “POWDER PA”/TI OR “RAC 01”/TI OR “SGC 15”/TI OR “SOLVEST 390A”/TI OR “SUMIPOWDER PA”/TI OR “T-POWDER”/TI OR “TIOMOLIBDATE DIAMMONIUM”/TI OR “TMOIO”/TI OR “TSM1”/TI); D SCAN L133

Table B-3 Strategies to Augment the Literature Search

Source | Query and number screened when available
TSCATS ^a^
01/2018 | Compounds searched: 7439-98-7, 1317-33-5, 12033-29-3, 12033-33-9, 11098-99-0, 18868-43-4, 1313-27-5, 1313-29-7, 11098-84-3, 27546-07-2, 12054-85-2, 15060-55-6, 7631-95-0, 10102-40-6, 7789-82-4, 12011-97-1, 11119-46-3, 11062-51-4, 10241-05-1, 1309-56-4, 7783-77-9, 13939-06-5, 14221-06-8, 13814-74-9, 12027-67-7, 13106-76-8
NTP
01/2018 | 14^th^ ROC (https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html):
| 7439-98-7 OR 1317-33-5 OR 12033-29-3 OR 12033-33-9 OR 11098-99-0 OR 18868-43-4 OR 1313-27-5 OR 1313-29-7 OR 11098-84-3 OR 27546-07-2 OR 12054-85-2; OR 15060-55-6 OR 7631-95-0 OR 10102-40-6 OR 7789-82-4 OR 12011-97-1 OR; 11119-46-3 OR 11062-51-4 OR 10241-05-1 OR 1309-56-4 OR 7783-77-9 OR 13939-06-5 OR 14221-06-8 OR 13814-74-9 OR 12027-67-7 OR 13106-76-8
| molybdenum OR molybdate OR molybdic OR dimolybdate OR dimolybdenum OR dodecachlorohexamolybdenum OR heptamolybdate OR hexacarbonylmolybdenum OR hexafluoromolybdenum OR hexamolybdenum OR molibdate OR molibdenum OR octachlorohexamolybdenum OR paramolybdate OR pentachloromolybdenum OR tetraacetatodimolybdenum OR tetraoxomolybdate OR tetrasulfidomolybdate OR tetrathiomolybdate OR tetrathiooxomolybdate OR thiomolybdate OR thiomolybdic OR tiomolibdate OR trichlorooxomolybdenum OR pigment black 34
| NTP Site Search (http://ntpsearch.niehs.nih.gov/home)) with Content Types “Reports & Publications”, “Systematic Review” or “Testing Status”:
| 7439-98-7 OR 1317-33-5 OR 12033-29-3 OR 12033-33-9 OR 11098-99-0 OR 18868-43-4 OR 1313-27-5 OR 1313-29-7 OR 11098-84-3 OR 27546-07-2 OR 12054-85-2; OR 15060-55-6 OR 7631-95-0 OR 10102-40-6 OR 7789-82-4 OR 12011-97-1 OR; 11119-46-3 OR 11062-51-4 OR 10241-05-1 OR 1309-56-4 OR 7783-77-9 OR 13939-06-5 OR 14221-06-8 OR 13814-74-9 OR 12027-67-7 OR 13106-76-8
| molybdenum OR molybdate OR molybdic OR dimolybdate OR dimolybdenum OR dodecachlorohexamolybdenum OR heptamolybdate OR hexacarbonylmolybdenum OR hexafluoromolybdenum OR hexamolybdenum OR molibdate OR molibdenum OR octachlorohexamolybdenum OR paramolybdate OR pentachloromolybdenum OR tetraacetatodimolybdenum OR tetraoxomolybdate OR tetrasulfidomolybdate OR tetrathiomolybdate OR tetrathiooxomolybdate OR thiomolybdate OR thiomolybdic OR tiomolibdate OR trichlorooxomolybdenum OR pigment black 34
Regulations.gov
01/2018 | Notices or rules:; 7439-98-7, 1317-33-5, 12033-29-3, 12033-33-9, 11098-99-0, 18868-43-4, 1313-27-5, 1313-29-7, 11098-84-3, 27546-07-2, 12054-85-2, 15060-55-6, 7631-95-0, 10102-40-6, 7789-82-4, 12011-97-1, 11119-46-3, 11062-51-4, 10241-05-1, 1309-56-4, 7783-77-9, 13939-06-5, 14221-06-8, 13814-74-9, 12027-67-7, 13106-76-8
NIH RePORTER
04/2019 | Text Search: “3N5” OR “Ammonium dimolybdate” OR “Ammonium heptamolybdate” OR “Ammonium heptamolybdate tetrahydrate” OR “Ammonium molibdate” OR “Ammonium molibdenum oxide” OR “Ammonium molybdate” OR “Ammonium molybdate hydrate” OR “Ammonium molybdate tetrahydrate” OR “Ammonium molybdate(VI)” OR “Ammonium molybdenum oxide” OR “Ammonium molybdenum sulfide” OR “ammonium paramolybdate” OR “Ammonium paramolybdate tetrahydrate” OR “Ammonium tetrasulfidomolybdate(2-)” OR “Ammonium tetrathiomolybdate” OR “Ammonium thiomolybdate(VI)” OR “Amperit 105.054” OR “Amperit 106.2” OR “ATTM” OR “Bis(ammonium)tetrathiomolybdate(2-)” OR “Bouen SKN 301” OR “C-Powder” OR “Calcium molybdate” OR “Calcium molybdate(VI)” OR “Calcium molybdenate” OR “Calcium molybdenum oxide” OR “Coprexa” OR “DAG 206” OR “DAG 325” OR “DAG-V 657” OR “Defric coat HMB 2” OR “Diammonium dimolybdate” OR “Diammonium tetrakis(sulfido)molybdate(2-)” OR “Diammonium tetrakis(thioxo)molybdate” OR “Diammonium tetrasulfidomolybdate” OR “Diammonium tetrathiomolybdate” OR “Diammonium tetrathiomolybdate(2-)” OR “Diammonium tetrathiooxomolybdate(2-)” OR “Diammonium tetrathioxomolybdate(2-)” OR “Diammonium thiomolybdate” OR “Dimolybdenum tetraacetate” OR “Dimolybdenum trioxide” OR “dimolybdenum trisulfide ” OR “Disodium molybdate” OR “Disodium molybdate dihydrate” OR “Disodium tetraoxomolybdate” OR “DM 1 (sulfide)” OR “DMI 7” OR “Dodecachlorohexamolybdenum” OR “Hexaammonium heptamolybdate tetrahydrate” OR “Hexaammonium molybdate tetrahydrate” OR “Hexacarbonylmolybdenum” OR “Hexafluoromolybdenum” OR “Hexamolybdenum dodecachloride” OR “JCPDS 35-0609” OR “Liqui-Moly LM 11” OR “Liqui-Moly LM 2” OR “Liqui-Moly Z Powder” OR “LM 13” OR “MC 400WR” OR “MChVL” OR “MD 40” OR “Metco 63” OR “MF 000” OR “MIPO-M 15” OR “Mo 1202T” OR “Mo-1202T” OR “Moly Fine Powder Y” OR “Moly Powder B” OR “Moly Powder C” OR “Moly Powder PA” OR “Moly Powder PB” OR “Moly Powder PS” OR “Molybdate (Mo2O72-), diammonium” OR “Molybdate (MoO42-), disodium, dihydrate, (T-4)-” OR “Molybdate, calcium” OR “Molybdena” OR “Molybdenite” OR “Molybdenum” OR “Molybdenum anhydride” OR “Molybdenum bisulfide” OR “Molybdenum carbide” OR “Molybdenum carbonyl” OR “Molybdenum chloride” OR “Molybdenum chloride oxide” OR “Molybdenum dioxide” OR “Molybdenum disulfide” OR “Molybdenum disulphide” OR “Molybdenum fluoride” OR “Molybdenum hexacarbonyl” OR “Molybdenum hexafluoride” OR “Molybdenum metallicum” OR “Molybdenum monocarbide” OR “Molybdenum oxide” OR “Molybdenum oxychloride” (Advanced), Search in: Projects AdminIC: All, Fiscal Year: Active Projects; Text Search: “Molybdenum oxytrichloride” OR “Molybdenum pentachloride” OR “Molybdenum peroxide” OR “Molybdenum sesquioxide” OR “Molybdenum sesquisulfide” OR “Molybdenum sodium oxide” OR “Molybdenum sulfide” OR “Molybdenum sulphide” OR “Molybdenum trichloride monoxide” OR “Molybdenum trichloride oxide” OR “Molybdenum trioxide” OR “Molybdenum trioxide pentamer” OR “Molybdenum trioxide tetramer” OR “Molybdenum trisulfide” OR “Molybdenum(6) fluoride” OR “Molybdenum(II) acetate” OR “Molybdenum(II) chloride” OR “molybdenum(III) sulfide” OR “molybdenum(IV) oxide” OR “Molybdenum(IV) sulfide” OR “Molybdenum(V) chloride” OR “Molybdenum(VI) oxide” OR “Molybdenum(VI) trioxide” OR “Molybdenumperoxide” OR “Molybdic acid (H2Mo2O7), diammonium salt” OR “Molybdic acid (H2MoO4), calcium salt (1:1)” OR “Molybdic acid anhydride” OR “Molybdic acid, ammonium salt” OR “Molybdic acid, calcium salt” OR “Molybdic acid, disodium salt” OR “Molybdic acid, disodium salt, dihydrate” OR “Molybdic anhydride” OR “Molybdic oxide” OR “Molybdic trioxide” OR “Molycolloid CF 626” OR “Molyform 15” OR “Molyhibit 100” OR “Molyka R” OR “Molyka R-L 3” OR “Molyke R” OR “Molykote” OR “Molykote Microsize Powder” OR “Molykote Z” OR “Molykote Z Powder” OR “Molysulfide” OR “MOP-P 100” OR “Mopol M” OR “Mopol S” OR “Motimol” OR “MVCh 1” OR “Natural molybdenite” OR “Natural molybdite” OR “NeoZ” OR “Nichimoly C” OR “Octachlorohexamolybdenum(4) tetrachloride” OR “OKS 110” OR “PA Powder” OR “Pentachloromolybdenum Molybdenite” OR “Pigment Black 34” OR “Pol-U” OR “Powder PA” OR “RAC 01” OR “SGC 15” OR “Sodium molybdate” OR “Sodium molybdate dihydrate” OR “Sodium molybdate(VI)” OR “Sodium molybdate(VI) dihydrate” OR “Sodium molybdenate” OR “Sodium molybdenum oxide” OR “Sodium tetraoxomolybdate(2-)” OR “Solvest 390A” OR “Sumipowder PA” OR; “Tetraacetatodimolybdenum” OR “tetrakis(acetato)di-Molybdenum” OR “Tetrakis(acetato)dimolybdenum” OR “Tetrakis(acetato)molybdenum” OR “Tetrakis(mu-(acetato-O:O’))dimolybdenum” OR “tetrakis(mu-acetato)di-Molybdenum” OR “Tetrakis(mu-acetato)dimolybdenum” OR “tetrakis[mu-(acetato-O:O’)]di-Molybdenum” OR “Thiomolybdic acid, diammonium salt” OR “Tiomolibdate diammonium” OR “TMOIO” OR “Trichlorooxomolybdenum” OR “Trichlorooxomolybdenum(V)” OR “TsM1” OR “Hexaammonium heptamolybdate” OR “Hexammonium heptamolybdat” OR “Hexammonium tetracosaoxoheptamolybdate” OR “Molybdate (Mo7O24), hexammonium” OR “Molybdate (Mo7O246-), ammonium (1:6)” OR “Molybdate (Mo7O246-), hexaammonium” (Advanced), Search in: Projects Admin IC: All, Fiscal Year: Active Projects; Text Search: “Molybdate, hexaammonium” OR “Molybdic acid (H6Mo7O24), hexaammonium salt” OR “Molybdic acid, hexaammonium salt” OR “Diammonium molybdate” OR “Diammonium tetraoxomolybdate(2-)” OR “Molybdate (MoO42-), ammonium (1:2), (T-4)-” OR “Molybdate (MoO42-), diammonium, (beta-4)-” OR “Molybdate (MoO42-), diammonium, (T-4)-” OR “Molybdic acid (H2MoO4), diammonium salt” OR “Molybdic acid, diammonium salt” (Advanced), Search in: Projects Admin IC: All, Fiscal Year: Active Projects; Text Search: molybdenum OR molybdate OR molybdic OR dimolybdate OR dimolybdenum OR dodecachlorohexamolybdenum OR heptamolybdate OR hexacarbonylmolybdenum OR hexafluoromolybdenum OR hexamolybdenum OR molibdate OR molibdenum OR octachlorohexamolybdenum OR paramolybdate OR pentachloromolybdenum OR tetraacetatodimolybdenum OR tetraoxomolybdate OR tetrasulfidomolybdate OR tetrathiomolybdate OR tetrathiooxomolybdate OR thiomolybdate OR thiomolybdic OR tiomolibdate OR trichlorooxomolybdenum OR pigment black 34 (Advanced), Search in: Projects AdminIC: All, Fiscal Year: Active Projects
Other | Identified throughout the assessment process

a Several versions of the TSCATS database were searched, as needed, by CASRN including TSCATS1 via Toxline (no date limit), TSCATS2 via https://yosemite.epa.gov/oppts/epatscat8.nsf/ReportSearch?OpenForm (date restricted by EPA receipt date), and TSCATS via CDAT (date restricted by ‘Mail Received Date Range’), as well as google for recent TSCA submissions.

The 2018 results were:

- Number of records identified from PubMed, TOXLINE, and TOXCENTER (after duplicate removal): 2,394
- Number of records identified from other strategies: 114
- Total number of records to undergo literature screening: 2,508

### B.1.2 Literature Screening

A two-step process was used to screen the literature search to identify relevant studies on molybdenum:

- Title and abstract screen
- Full text screen

Title and Abstract Screen. Within the reference library, titles and abstracts were screened manually for relevance. Studies that were considered relevant (see Table B-1 for inclusion criteria) were moved to the second step of the literature screening process. Studies were excluded when the title and abstract clearly indicated that the study was not relevant to the toxicological profile.

- Number of titles and abstracts screened: 2,508
- Number of studies considered relevant and moved to the next step: 129

Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the title and abstract screen step. Each study was reviewed to determine whether it was relevant for inclusion in the toxicological profile.

- Number of studies undergoing full text review: 129
- Number of studies cited in the pre-public draft of the toxicological profile: 235
- Total number of studies cited in the profile: 337

A summary of the results of the literature search and screening is presented in Figure B-1.

Figure B-1 January 2018 Literature Search Results and Screen for Molybdenum

Figure B-1 description