# CHAPTER 8 REFERENCES

Abraham R, Benitz KF, Mankes R. 1983. Ploidy patterns in hepatic tumors induced by mirex. Exp Mol Pathol 38(2):271–282. 10.1016/0014-4800(83)90092-8.6832349
Abston PA, Yarbrough JD. 1976. The in vivo effect of mirex on soluble hepatic enzymes in the rat. Pestic Biochem Physiol 6(2):192–199. 10.1016/0048-3575(76)90039-0.
ACGIH. 2016. In: TLVs and BEIs based on the documentation of the threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists, 223–250.
Adir J, Caplan YH, Thompson BC. 1978. Kepone serum half-life in humans. Life Sci 22(8):699–702. 10.1016/0024-3205(78)90494-0.76277
Adler CP, Ringlage WP, Bohm N. 1981. [DNA content and cell number in heart and liver of children. Comparable biochemical, cytophotometric and histological investigations]. Pathol Res Pract 172(1–2):25–41. (German)
Agarwal AK, Mehendale HM. 1982. Potentiation of bromotrichloromethane hepatotoxicity and lethality by chlordecone preexposure in the rat. Fundam Appl Toxicol 2(4):161–167. 10.1016/s0272-0590(82)80040-7.6193023
Agarwal AK, Mehendale HM. 1983a. Potentiation of CCl4 hepatotoxicity and lethality by chlordecone in female rats. Toxicology 26(3–4):231–242. 10.1016/0300-483x(83)90084-7.6190268
Agarwal AK, Mehendale HM. 1984a. Excessive hepatic accumulation of intracellular Ca2+ in chlordecone potentiated CCl4 toxicity. Toxicology 30(1):17–24. 10.1016/0300-483x(84)90058-1.6199871
Agarwal AK, Mehendale HM. 1984c. CCl4-induced alterations in Ca++ homeostasis in chlordecone and phenobarbital pretreated animals. Life Sci 34(2):141–148. 10.1016/0024-3205(84)90584-8.6198578
Agarwal AK, Mehendale HM. 1984d. Perturbation of calcium homeostasis by CCl4 in rats pretreated with chlordecone and phenobarbital. Environ Health Perspect 57:289–291. 10.1289/ehp.8457289.6209127
Agarwal AK, Mehendale HM. 1986. Effect of chlordecone on carbon tetrachloride-induced increase in calcium uptake in isolated perfused rat liver. Toxicol Appl Pharmacol 83(2):342–348. 10.1016/0041-008x(86)90311-x.2421457
Albertson TE, Joy RM, Stark LG. 1985. Chlorinated hydrocarbon pesticides and amygdaloid kindling. Neurobehav Toxicol Teratol 7(3):233–237.2412143
Aldous CN, Chetty CS, Desaiah D. 1983. Alterations in tissue distribution of chlordecone (Kepone) in the rat following phenobarbital or SKF-525A administration. Journal of Toxicology and Environmental Health Part A 11(3):365–372. 10.1080/15287398309530350.
Aldous CN, Chetty CS, Mehendale HM, 1984. Lack of effects of chlordecone on synthesis rates, steady state levels and metabolites of catecholamines in rat brain. Neurotoxicology 5(2):59–65.
Ali SF, Hong JS, Wilson WE, 1982. Subchronic dietary exposure of rats to chlordecone (Kepone) modifies levels of hypothalamic beta-endorphin. Neurotoxicology 3(2):119–124.6186956
Allan RJ, Ball AJ. 1990. An overview of toxic contaminants in water and sediments of the Great Lakes. Part I. Water Pollut Res J Can 25(4):387–505. 10.2166/wqrj.1990.021.
Aminov Z, Haase R, Rej R, 2016. Diabetes prevalence in relation to serum concentrations of polychlorinated biphenyl (PCB) congener groups and three chlorinated pesticides in a native American population. Environ Health Perspect 124(9):1376–1383. 10.1289/ehp.1509902.27035469
Andrade PS, Wheeler WB. 1974. Biodegradation of mirex by sewage sludge organisms. Bull Environ Contam Toxicol 11(5):415–416. 10.1007/bf01685296.4433826
Andrade P, Wheeler WB, Carlson DA. 1975. Identification of a mirex metabolite. Bull Environ Contam Toxicol 14(4):473–479. 10.1007/bf01705515.1191801
Araki A, Miyashita C, Mitsui T, 2018. Prenatal organochlorine pesticide exposure and the disruption of steroids and reproductive hormones in cord blood: The Hokkaido study. Environ Int 110:1–13. 10.1016/j.enviint.2017.10.006.29055783
Arimoto R. 1989. Atmospheric deposition of chemical contaminants to the Great Lakes. J Great Lakes Res 15(2):339–356. 10.1016/S0380-1330(89)71487-8.
Aronstam RS, Hong JS. 1986. Interactions of chlordecone (Kepone) and mirex with the nicotinic acetylcholine receptor - ion channel complex. Toxicol Lett 30(3):247–251. 10.1016/0378-4274(86)90162-1.2422792
Aslanzadeh J, Hedrick HG. 1985. Search for mirex-degrading soil microorganisms. Soil Sci 139(4):369–374.
Atallah YH, Dorough HW. 1975. Insecticide residues in cigarette smoke. Transfer and fate in rats. J Agric Food Chem 23(1):64–71. 10.1021/jf60197a019.1133280
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
ATSDR. 2019. Mirex and chlordecone. SPL data. Agency for Toxic Substances and Disease Registry.
Bacci E, Cerejeira MJ, Gaggi C, 1990. Bioconcentration of organic chemical vapours in plant leaves: The azalea model. Chemosphere 21(4):525–535. 10.1016/0045-6535(90)90023-M.
Baggett JM, Thureson-Klein A, Klein RL. 1980. Effects of chlordecone on the adrenal medulla of the rat. Toxicol Appl Pharmacol 52(2):313–322. 10.1016/0041-008x(80)90118-0.6153821
Bahner LH, Wilson AJ, Sheppard JM, 1977. Kepone^®^ bioconcentration, accumulation, loss, and transfer through estuarine food chains. Chesapeake Sci 18(3):299–308. 10.2307/1350804.
Baker RC, Coons LB, Mailman RB, 1972. Induction of hepatic mixed function oxidases by the insecticide, mirex. Environ Res 5(4):418–424. 10.1016/0013-9351(72)90043-6.4651616
Bale SS. 1983. Cytological effects of Kepone on Chinese hamster cells. J Hered 74(2):123–124. 10.1093/oxfordjournals.jhered.a109737.6188778
Bansal SK, Desaiah D. 1982. Effects of chlordecone and its structural analogs on p-nitrophenyl phosphatase. Toxicol Lett 12(2–3):83–90. 10.1016/0378-4274(82)90168-0.6180526
Bansal SK, Desaiah D. 1985. Chlordecone toxicity: effect of withdrawal of treatment on ATPase inhibition. Neurotoxicology 6(3):103–107.2413407
Barnes DG, Dourson M. 1988. Reference dose (RfD): description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486. 10.1016/0273-2300(88)90047-5.3222488
Baughman GL, Paris DF. 1981. Microbial bioconcentration of organic pollutants from aquatic systems - A critical review. Crit Rev Microbiol 8(3):205–228. 10.3109/10408418109085079.7009060
Belfiore C, Yang RS, Chubb LS, 2007. Hepatic sequestration of chlordecone and hexafluoroacetone evaluated by pharmacokinetic modeling. Toxicology 234(1–2):59–72. 10.1016/j.tox.2007.02.002.17382449
Bell AN, Mehendale HM. 1985. The effect of dietary exposure to a mirex plus chlordecone combination on CCl4 hepatotoxicity. Fundam Appl Toxicol 5(4):679–687. 10.1016/0272-0590(85)90192-7.2412926
Bell AN, Mehendale HM. 1987. Comparative changes in hepatic DNA, RNA, protein, lipid, and glycogen induced by a subtoxic dose of CCl4 in chlordecone, mirex, and phenobarbital pretreated rats. Toxicol Lett 35(2–3):191–200. 10.1016/0378-4274(87)90206-2.2435023
Bell AN, Young RA, Lockard VG, 1988. Protection of chlordecone-potentiated carbon tetrachloride hepatotoxicity and lethality by partial hepatectomy. Arch Toxicol 61(5):392–405. 10.1007/bf00334621.2456051
Benachour N, Moslemi S, Sipahutar H, 2007. Cytotoxic effects and aromatase inhibition by xenobiotic endocrine disrupters alone and in combination. Toxicol Appl Pharmacol 222(2):129–140. 10.1016/j.taap.2007.03.033.17599374
Bender MA, Huggett RJ. 1984. Fate and effects of Kepone in the James River. Rev Environ Toxicol 1:5–51.
Berman EF, Schaus P, Fujimoto JM. 1986. Comparison of the inhibition of biliary excretion produced by certain inducing agents including 2,3,7,8-tetrachlorodibenzo-p-dioxin. J Toxicol Environ Health 17(4):395–403. 10.1080/15287398609530834.2421000
Bjorge C, Brunborg G, Wiger R, 1996. A comparative study of chemically induced DNA damage in isolated human and rat testicular cells. Reprod Toxicol 10(6):509–519. 10.1016/s0890-6238(96)00138-4.8946565
Blain RB, Reeves R, Ewald KA, 1999. Susceptibility to chlordecone-carbon tetrachloride induced hepatotoxicity and lethality is both age and sex dependent. Toxicol Sci 50(2):280–286.10478865
Blanke RV, Fariss MW, Guzelian PS, 1978. Identification of a reduced form of chlordecone (Kepone) in human stool. Bull Environ Contam Toxicol 20(6):782–785. 10.1007/bf01683600.86368
Bloomquist JR, Adams PM, Soderlund DM. 1986. Inhibition of gamma-aminobutyric acid-stimulated chloride flux in mouse brain vesicles by polychlorocycloalkane and pyrethroid insecticides. Neurotoxicology 7(3):11–20.2434890
Bolger R, Wiese TE, Ervin K, 1998. Rapid screening of environmental chemicals for estrogen receptor binding capacity. Environ Health Perspect 106(9):551–557.9721254
Bondy SC, Halsall LC. 1988. GM1 ganglioside enhances synaptosomal resistance to chemically induced damage. Neurosci Lett 84(2):229–233. 10.1016/0304-3940(88)90413-2.2448709
Bondy SC, McKee M. 1990. Prevention of chemically induced synaptosomal changes. J Neurosci Res 25(2):229–235. 10.1002/jnr.490250211.1690820
Bondy SC, Martin J, Halsall LC, 1989. Increased fragility of neuronal membranes with aging. Exp Neurol 103(1):61–63. 10.1016/0014-4886(89)90185-4.2463937
Borgmann U, Whittle DM. 1991. Contaminant concentration trends in Lake Ontario lake trout (Salvelinus namaycush): 1977 to 1988. J Great Lakes Res 17(3):368–381. 10.1016/s0380-1330(91)71373-7.
Borsetti AP, Roach JA. 1978. Identification of Kepone alteration products in soil and mullet. Bull Environ Contam Toxicol 20(2):241–247. 10.1007/bf01683515.81083
Borzelleca JF, Skalsky HL. 1980. The excretion of pesticides in saliva and its value in assessing exposure. J Environ Sci Health B 15(6):843–866. 10.1080/03601238009372220.6160176
Boucher O, Simard MN, Muckle G, 2013. Exposure to an organochlorine pesticide (chlordecone) and development of 18-month-old infants. Neurotoxicology 35:162–168. 10.1016/j.neuro.2013.01.007.23376090
Boyer PD, Chance B, Ernster L, 1977. Oxidative phosphorylation and photophosphorylation. Annu Rev Biochem 46(1):955–966.18361775
Boylan JJ, Egle JL, Guzelian PS. 1978. Cholestyramine: use as a new therapeutic approach for chlordecone (Kepone) poisoning. Science 199(4331):893–895. 10.1126/science.74852.74852
Boylan JJ, Cohn WJ, Egle JL, 1979. Excretion of chlordecone by the gastrointestinal tract: evidence for a nonbiliary mechanism. Clin Pharmacol Ther 25(5 Pt 1):579–585. 10.1002/cpt1979255part1579.86403
Britton RS, Dolak JA, Glende EA, 1987. Potentiation of carbon tetrachloride hepatotoxicity by chlordecone: dose-response relationships and increased covalent binding in vivo. J Biochem Toxicol 2:43–55. 10.1002/jbt.2570020105.2469794
Brower GR, Ramkrishnadas R. 1982. Industrial wastes: Solid wastes and water quality. J Water Pollut Control Fed 54(6):749–754.
Brown LD, Yarbrough JD. 1988. Mirex uptake and tissue disposition in intact and adrenalectomized rats. Toxicol Appl Pharmacol 92(3):343–350. 10.1016/0041-008x(88)90174-3.3353985
Brown HE, Salamanca S, Stewart G, 1991. Chlordecone (Kepone) on the night of proestrus inhibits female sexual behavior in CDF-344 rats. Toxicol Appl Pharmacol 110(1):97–106. 10.1016/0041-008x(91)90293-n.1714637
Budavari S, O’Neil MJ, Smith A, eds. 1989. Mirex. In: The Merck index: An encyclopedia of chemicals, drugs, and biologicals. 11th ed. Rahway, NJ: Merck and Co., Inc., 321, 977.
Buelke-Sam J, Byrd RA, Nelson CJ. 1983. Blood flow during pregnancy in the rat: III. Alterations following mirex treatment. Teratology 27(3):401–409. 10.1002/tera.1420270314.6879462
Bulger WH, Muccitelli RM, Kupfer D. 1979. Studies on the estrogenic activity of chlordecone (Kepone) in the rat: effects on uterine estrogen receptor. Mol Pharmacol 15(3):515–524.91089
Bungay PM, Dedrick RL, Matthews HB. 1979. Pharmacokinetics of halogenated hydrocarbons. Ann N Y Acad Sci 320:257–270.88202
Bungay PM, Dedrick RL, Matthews HB. 1981. Enteric transport of chlordecone (Kepone) in the rat. J Pharm Biopharm 9(3):309–341. 10.1007/bf01059269.
Burse VW, Head SL, McClure PC, 1989. Partitioning of mirex between adipose tissue and serum. J Agric Food Chem 37:692–699.
Bush B, Snow J, Conner S, 1983. Mirex in human milk in upstate New York. Arch Environ Contam Toxicol 12(6):739–746. 10.1007/bf01060759.6651347
Butler PA. 1973. Residues in fish, wildlife, and estuaries; organochlorine residues in estuarine mollusks, 1965–72 - National Pesticide Monitoring Program. Pestic Monit J 6(4):238–362.4124585
Butler Walker J, Seddon L, McMullen E, 2003. Organochlorine levels in maternal and umbilical cord blood plasma in Arctic Canada. Sci Total Environ 302(1–3):27–52.12526896
Byrd RA, Kimmel CA, Morris MD, 1981. Altered pattern of prenatal toxicity in rats due to different treatment schedules with mirex. Toxicol Appl Pharmacol 60(2):213–219. 10.1016/0041-008x(91)90225-4.7281184
Byrd RA, Young JF, Kimmel CA, 1982. Computer simulation of mirex pharmacokinetics in the rat. Toxicol Appl Pharmacol 66(2):182–192. 10.1016/0041-008x(82)90283-6.7164097
Cai ZW, Mehendale HM. 1990. Lethal effects of CCl4 and its metabolism by Mongolian gerbils pretreated with chlordecone, phenobarbital, or mirex. Toxicol Appl Pharmacol 104(3):511–520. 10.1016/0041-008x(90)90173-r.1696756
Cai Z, Mehendale HM. 1991a. Hepatotoxicity and lethality of halomethanes in Mongolian gerbils pretreated with chlordecone, phenobarbital or mirex. Arch Toxicol 65(3):204–212. 10.1007/bf02307310.1711308
Cai ZW, Mehendale HM. 1991b. Protection from CCl4 toxicity by prestimulation of hepatocellular regeneration in partially hepatectomized gerbils. Biochem Pharmacol 42(3):633–644. 10.1016/0006-2952(91)90327-2.1859467
Cai Z, Mehendale HM. 1993. Resiliency to amplification of carbon tetrachloride hepatotoxicity by chlordecone during postnatal development in rats. Pediatr Res 33(3):225–232. 10.1203/00006450-199303000-00003.7681558
Caldwell V, Loch-Caruso R. 1992. Chlordecone rapidly and reversibly inhibits gap junctional communication in human embryonic palatal mesenchyme cells. In Vitro Toxicology 5(2):113–122.
Cannon SB, Kimbrough RD. 1979. Short-term chlordecone toxicity in rats including effects on reproduction, pathological organ changes, and their reversibility. Toxicol Appl Pharmacol 47(3):469–476. 10.1016/0041-008X(79)90517-9.87035
Cannon SB, Veazey JM, Jackson RS, 1978. Epidemic Kepone poisoning in chemical workers. Am J Epidemiol 107(6):529–537. 10.1093/oxfordjournals.aje.a112572.78669
Caplan YH, Thompson BC, Hebb JH. 1979. A method for the determination of chlordecone (Kepone) in human serum and blood. J Anal Toxicol 3(5):202–205. 10.1093/jat/3.5.202.
Carlson DA, Konyha KD, Wheeler WB, 1976. Mirex in the environment: its degradation to Kepone and related compounds. Science 194(4268):939–941. 10.1126/science.62396.62396
Carpenter HM, Hedstrom OR, Siddens LK, 1996. Ultrastructural, protein, and lipid changes in liver associated with chlordecone treatment of mice. Toxicol Sci 34(1):157–164. 10.1093/toxsci/34.1.157.
CDC. 2019. Fourth report on human exposure to environmental chemicals, updated tables, (January 2019). Atlanta, GA: Centers for Disease Control and Prevention. https://www.cdc.gov/exposurereport/pdf/FourthReport_UpdatedTables_Volume1_Jan2019-508.pdf. September 1, 2020.
Chadwick R, Copeland M, Rosenstein L. 1979. The effect of Kepone exposure during gestation and lactation on the metabolism of lindane by weanling rats. Toxicol Lett 4(4):247–252. 10.1016/0378-4274(79)90060-2.
Chadwick RW, Chadwick CJ, Freal JJ, 1977. Comparative enzyme induction and lindane metabolism in rats pre-treated with various organochlorine pesticides. Xenobiotica 7(4):235–246. 10.3109/00498257709035781.68630
Chambers JE, Trevathan CA. 1983. Effect of mirex, dechlorinated mirex derivatives and chlordecone on microsomal mixed-function oxidase activity and other hepatic parameters. Toxicol Lett 16(1–2):109–115. 10.1016/0378-4274(83)90018-8.6188242
Chambers JE, Case RS, Alley EG, 1982. Short-term fate of mirex and 2,8-dihydromirex in rats. J Agric Food Chem 30(5):878–882. 10.1021/jf00113a020.7142591
Chang-Tsui YYH, Ho IK. 1979. Effects of Kepone (chlordecone) on synaptosomal g-aminobutyric acid uptake in the mouse. Neurotoxicology 1(2):357–367.
Chang-Tsui YYH, Ho IK. 1980. Effect of Kepone (chlordecone) on synaptosomal catecholamine uptake in the mouse. Neurotoxicology 1(3):643–651.
Charles AK, Rosenbaum DP, Ashok L, 1985. Uptake and disposition of mirex in hepatocytes and subcellular fractions in CD1 mouse liver. J Toxicol Environ Health 15(3–4):395–403. 10.1080/15287398509530667.4032488
Chaudhury S, Mehendale HM. 1991. Amplification of CCl4 toxicity by chlordecone: destruction of rat hepatic microsomal cytochrome P-450 subpopulation. J Toxicol Environ Health 32(3):277–294. 10.1080/15287399109531482.1705986
Chen PH, Tilson HA, Marbury GD, 1985. Effect of chlordecone (Kepone) on the rat brain concentration of 3-methoxy-4-hydroxyphenylglycol: evidence for a possible involvement of the norepinephrine system in chlordecone-induced tremor. Toxicol Appl Pharmacol 77(1):158–164. 10.1016/0041-008x(85)90276-5.2578231
Chernoff N, Rogers EH. 1976. Fetal toxicity of Kepone in rats and mice. Toxicol Appl Pharmacol 38(1):189–194. 10.1016/0041-008x(76)90172-1.62421
Chernoff N, Kavlock RJ. 1982. An in vivo teratology screen utilizing pregnant mice. J Toxicol Environ Health 10(4–5):541–550. 10.1080/15287398209530275.7161814
Chernoff N, Stevens JT, Rogers EH. 1979a. Perinatal toxicology of mirex administered in the diet: I. Viability, growth, cataractogenicity and tissue levels. Toxicol Lett 4(4):263–268. 10.1016/0378-4274(79)90063-8.
Chernoff N, Linder RE, Scotti TM, 1979b. Fetotoxicity and cataractogenicity of mirex in rats and mice with notes on Kepone. Environ Res 18(2):257–269. 10.1016/0013-9351(79)90102-6.92402
Chetty CS, Aldous CN, Desaiah D. 1983a. Sensitivity of rat brain ATPase system to structurally related organochlorine pesticides. Indian J Comp Anim Physiol 1(1):107–113.
Chetty SC, Aldous CN, Rashatwar SS, 1983b. Effect of chlordecone on pH and temperature dependent substrate activation kinetics of rat brain synaptosomal ATPases. Biochem Pharmacol 32(21):3205–3211. 10.1016/0006-2952(83)90205-8.6196030
Chetty KN, Walker J, Brown K, 1993a. The effects of dietary calcium and chlordecone on cholinesterase, triglycerides, low density lipoproteins, and cholesterol in serum of rat. Arch Environ Contam Toxicol 24(3):365–367. 10.1007/bf01128735.7682401
Chetty KN, Walker J, Brown K, 1993b. Influence of dietary calcium on chlordecone-induced biochemical changes in serum of rat. Ecotoxicol Environ Saf 26(2):248–252. 10.1006/eesa.1993.1053.7504618
Chetty KN, Brown K, Walker J, 1993c. Effects of chlordecone and malnutrition on immune response in rats. Life Sci 52(18):PL175–180. 10.1016/0024-3205(93)90114-i.
Chu I, Villeneuve DC, Becking GC, 1980a. Tissue distribution and elimination of 2,8-dihydromirex in the rat. J Toxicol Environ Health 6(4):713–721. 10.1080/15287398009529890.7420475
Chu I, Villeneuve DC, Becking GC, 1980b. Short-term study of the combined effects of mirex, photomirex, and Kepone with halogenated biphenyls in rats. J Toxicol Environ Health 6(2):421–432. 10.1080/15287398009529861.6156243
Chu I, Villeneuve DC, Secours V, 1980c. 2,8-Dihydromirex: a twenty-eight day sub-acute toxicity study in the rat. J Environ Sci Health B 15(1):87–107. 10.1080/03601238009372166.7358950
Chu I, Villeneuve DC, MacDonald BL, 1981a. Reversibility of the toxicological changes induced by photomirex and mirex. Toxicology 21(3):235–250. 10.1016/0300-483x(81)90159-1.7292508
Chu I, Villeneuve DC, Secours VE, 1981b. Effects of photomirex and mirex on reproduction in the rat. Toxicol Appl Pharmacol 60(3):549–556. 10.1016/0041-008x(81)90341-0.7292493
Cianflone DJ, Hewitt WR, Villeneuve DC, 1980. Role of biotransformation in the alterations of chloroform hepatotoxicity produced by Kepone and mirex. Toxicol Appl Pharmacol 53(1):140–149. 10.1016/0041-008x(80)90391-9.6155715
Clark JA, DeVault D, Bowden R, 1984. Contaminant analysis of fillets from Great Lakes Coho Salmon, 1980. J Great Lakes Res 19:38–47. 10.1016/S0380-1330(84)71805-3.
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Codru N, Schymura MJ, Negoita S, 2007. Diabetes in relation to serum levels of polychlorinated biphenyls and chlorinated pesticides in adult Native Americans. Environ Health Perspect 115(10):1442–1447. 10.1289/ehp.10315.17938733
Cohn WJ, Boylan JJ, Blanke RV, 1978. Treatment of chlordecone (Kepone) toxicity with cholestyramine. Results of a controlled clinical trial. N Engl J Med 298(5):243–248. 10.1056/NEJM197802022980504.74014
Colwell RR, McNicol LA, Omdorff SA, 1981. Microbial degradation of Kepone in the Chesapeake Bay. College Park, MD: University of Maryland.
Comba ME, Norstrom RJ, Macdonald CR, 1993. A Lake Ontario-Gulf of St. Lawrence dynamic mass budget for mirex. Environ Sci Technol 27(10):2198–2206. 10.1021/es00047a029.
Connell DW, Markwell RD. 1990. Bioaccumulation in the soil to earthworm system. Chemosphere 20(1–2):91–100. 10.1016/0045-6535(90)90089-c.
Cook LL, Edens FW, Tilson HA. 1988a. Possible brainstem involvement in the modification of thermoregulatory processes by chlordecone in rats. Neuropharmacology 27(9):871–879. 10.1016/0028-3908(88)90113-x.2460795
Cook LL, Edens FW, Tilson HA. 1988b. Pharmacological evaluation of central adrenergic involvement in chlordecone-induced hypothermia. Neuropharmacology 27(9):881–887. 10.1016/0028-3908(88)90114-1.2460796
Cordier S, Bouquet E, Warembourg C, 2015. Perinatal exposure to chlordecone, thyroid hormone status and neurodevelopment in infants: the Timoun cohort study in Guadeloupe (French West Indies). Environ Res 138:271–278. 10.1016/j.envres.2015.02.021.25747818
Cordier S, Forget-Dubois N, Desrochers-Couture M, 2019. Prenatal and childhood exposure to chlordecone and sex-typed toy preference of 7-year-old Guadeloupean children. Environ Sci Pollut Res Int 10.1007/s11356-019-05686-x.
Costet N, Pele F, Comets E, 2015. Perinatal exposure to chlordecone and infant growth. Environ Res 142:123–134. 10.1016/j.envres.2015.06.023.26133809
Cripe CR, Livingston RJ. 1977. Dynamics of mirex and its principal photoproducts in a simulated marsh system. Arch Environ Contam Toxicol 5(3):295–303. 10.1007/bf02220911.869586
Curtis LR. 1988. Chlordecone is a potent in vitro inhibitor of oligomycin-insensitive Mg2+ - ATPase of rat bile canaliculi-enriched fraction. J Biochem Toxicol 3:321–328. 10.1002/jbt.2570030409.2466998
Curtis LR, Mehendale HM. 1979. The effects of Kepone pretreatment on biliary excretion of xenobiotics in the male rat. Toxicol Appl Pharmacol 47(2):295–303. 10.1016/0041-008X(79)90324-7.88085
Curtis LR, Mehendale HM. 1980. Specificity of chlordecone-induced potentiation of carbon tetrachloride hepatotoxicity. Drug Metab Dispos 8(1):23–27.6153597
Curtis LR, Mehendale HM. 1981. Hepatobiliary dysfunction and inhibition of adenosine triphosphatase activity of bile canaliculi-enriched fractions following in vivo mirex, photomirex, and chlordecone exposures. Toxicol Appl Pharmacol 61(3):429–440. 10.1016/0041-008X(81)90366-5.6173935
Curtis LR, Hoyt D. 1984. Impaired biliary excretion of taurocholate associated with increased biliary tree permeability in mirex- or chlordecone-pretreated rats. J Pharmacol Exp Ther 231(3):495–501.6209385
Curtis LR, Williams WL, Mehendale HM. 1979. Potentiation of the hepatotoxicity of carbon tetrachloride following preexposure to chlordecone (Kepone) in the male rat. Toxicol Appl Pharmacol 51(2):283–293. 10.1016/0041-008x(79)90471-x.93792
Curtis LR, Thureson-Klein AK, Mehendale HM. 1981. Ultrastructural and biochemical correlates of the specificity of chlordecone-potentiated carbon tetrachloride hepatotoxicity. J Toxicol Environ Health 7(3–4):499–517. 10.1080/15287398109529997.6169839
Cutshall NH, Larsen IL, Nichols MM. 1981. Man-made radionuclides confirm rapid burial of Kepone in James River sediments. Science 213(4506):440–442. 10.1126/science.213.4506.440.17760190
Dahlstrom-King L, Couture J, Plaa GL. 1992. Influence of agents affecting monooxygenase activity on taurolithocholic acid-induced cholestasis. Toxicol Lett 63(3):243–252. 10.1016/0378-4274(92)90087-z.1283232
Dai D, Cao Y, Falls G, 2001. Modulation of mouse P450 isoforms CYP1A2, CYP2B10, CYP2E1, and CYP3A by the environmental chemicals mirex, 2,2-bis (p-chlorophenyl)-1,1-dichloroethylene, vinclozolin, and flutamide. Pestic Biochem Physiol 70(2):127–141.
Dallaire R, Muckle G, Rouget F, 2012. Cognitive, visual, and motor development of 7-month-old Guadeloupean infants exposed to chlordecone. Environ Res 118:79–85. 10.1016/j.envres.2012.07.006.22910562
Dalu A, Mehendale HM. 1996. Efficient tissue repair underlies the resiliency of postnatally developing rats to chlordecone + CCl4 hepatotoxicity. Toxicology 111(1–3):29–42.8711744
Dalu A, Rao PS, Mehendale HM. 1998. Colchicine antimitosis abolishes resiliency of postnatally developing rats to chlordecone-amplified carbon tetrachloride hepatotoxicity and lethality. Environ Health Perspect 106(9):597–606.9721260
Dalu A, Cronin GM, Lyn-Cook BD, 1995. Age-related differences in TGF-alpha and proto-oncogenes expression in rat liver after a low dose of carbon tetrachloride. J Biochem Toxicol 10(5):259–264.8847708
Das SK, Paria BC, Johnson DC, 1997. Embryo-uterine interactions during implantation: potential sites of interference by environmental toxins. In: Comprehensive toxicology. Vol. 10. London, England: Elsevier Science, 317–328.
Davies K. 1990. Human exposure pathways to selected organochlorines and PCBs in Toronto and Southern Ontario. Adv Environ Sci Technol 23:525–540.
Davis ME, Mehendale HM. 1980. Functional and biochemical correlates of chlordecone exposure and its enhancement of CCl4 hepatotoxicity. Toxicology 15(2):91–103. 10.1016/0300-483x(80)90003-7.6154986
Davison KL, Mollenhauer HH, Younger RL, 1976. Mirex-induced hepatic changes in chickens, Japanese quail, and rats. Arch Environ Contam Toxicol 4(4):469–482.999336
de La Cruz AA, Naqvi SM. 1973. Mirex incorporation in the environment: Uptake in aquatic organisms and effects on the rates of photosynthesis and respiration. Arch Environ Contam Toxicol 1(3):255–264. 10.1007/bf01985748.4776416
de la Cruz AA, Rajanna B. 1975. Mirex incorporation in the environment: uptake and distribution in crop seedlings. Bull Environ Contam Toxicol 14(01):38–42. 10.1007/bf01685595.1170909
Denham M, Schell LM, Deane G, 2005. Relationship of lead, mercury, mirex, dichlorodiphenyldichloroethylene, hexachlorobenzene, and polychlorinated biphenyls to timing of menarche among Akwesasne Mohawk girls. Pediatrics 115(2):e127–134. 10.1542/peds.2004-1161.15653789
Desaiah D. 1980. Comparative effects of chlordecone and mirex on rat cardiac ATPases and binding of 3H-catecholamines. J Environ Pathol Toxicol 4(1):237–248.
Desaiah D. 1981. Interaction of chlordecone with biological membranes. J Toxicol Environ Health 8(5–6):719–730. 10.1080/15287398109530108.6175765
Desaiah D. 1985. Chlordecone interaction with catecholamine binding and uptake in rat brain synaptosomes. Neurotoxicology 6(1):159–165.
Desaiah D, Chetty CS, Rao KS. 1985. Chlordecone inhibition of calmodulin activated calcium ATPase in rat brain synaptosomes. J Toxicol Environ Health 16(2):189–195. 10.1080/15287398509530732.2416942
Desaiah D, Gilliland T, Ho IK, 1980b. Inhibition of mouse brain synaptosomal ATPases and ouabain binding by chlordecone. Toxicol Lett 6(4–5):275–285.6158768
Desaiah D, Pentyala SN, Trottman CH, 1991. Combined effects of carbon tetrachloride and chlordecone on calmodulin activity in gerbil brain. J Toxicol Environ Health 34(2):219–228. 10.1080/15287399109531561.1717700
DeZearn MB, Oberacker DA. 1980. Detoxification of materials by microwave plasma. In: Safe handling of chemical carcinogens, mutagens, teratogens, and highly toxic substances Vol. 2. 595–615.
DHHS. 1991. Mirex and chlordecone. Sixth annual report on carcinogens. Rockville, MD: U.S. Department of Health and Human Services. 238–240, 261–262.
Dietz DD, McMillan DE. 1979. Comparative effects of mirex and Kepone on schedule-controlled behavior in the rat. I. Multiple fixed-ratio 12 fixed-interval 2-min schedule. Neurotoxicology 1(2):369–385.
DOE. 2016a. Table 3: Protective Action Criteria (PAC) Rev. 29 based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. May 2016. Oak Ridge, TN: U.S. Department of Energy. https://sp.eota.energy.gov/pac/teel/Revision_29_Table3.pdf. February 28, 2017.
DOE. 2016b. Protective Action Criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29 for Chemicals of Concern - May 2016. Oak Ridge, TN: U.S. Department of Energy. https://energy.gov/ehss/protective-action-criteria-pac-aegls-erpgs-teels-rev-29-chemicals-concern-may-2016. March 2, 2017.
Domine D, Devillers J, Chastrette M, 1992. Multivariate structure-property relationships (MSPR) of pesticides. Pestic Sci 35(1):73–82. 10.1002/ps.2780350110.
Dorough HW, Ivie GW. 1974. Fate of mirex-14C during and after a 28-day feeding period to a lactating cow. J Environ Qual 3(1):65–67. 10.2134/jeq1974.00472425000300010018x.
Dorough HW, Atallah YH. 1975. Cigarette smoke as a source of pesticide exposure. Bull Environ Contam Toxicol 13(1):101–107. 10.1007/bf01684872.805606
Durham RW, Oliver BG. 1983. History of Lake Ontario contamination from the Niagara River by sediment radiodating and chlorinated hydrocarbon analysis. J Great Lakes Res 9(2):160–168. 10.1016/S0380-1330(83)71885-X.
Egle JL, Guzelian PS, Borzelleca JF. 1979. Time course of the acute toxic effects of sublethal doses of chlordecone (Kepone). Toxicol Appl Pharmacol 48(3):533–536. 10.1016/0041-008x(79)90436-8.89713
Egle JL, Fernandez JB, Guzelian PS, 1978. Distribution and excretion of chlordecone (Kepone) in the rat. Drug Metab Dispos 6(1):91–95.74312
Eisenreich SJ, Looney BB, Thornton JD. 1981. Airborne organic contaminants in the Great Lakes ecosystem. Environ Sci Technol 15(1):30–38. 10.1021/es00083a002.
Eisenreich SJ, Capel PD, Robbins JA, 1989. Accumulation and diagenesis of chlorinated hydrocarbons in lacustrine sediments. Environ Sci Technol 23(9):1116–1126. 10.1021/es00067a009.
Elder VA, Proctor BL, Hites RA. 1981. Organic compounds near dumpsites in Niagara Falls, New York. Biomed Mass Spectrom 8(9):409–415. 10.1002/bms.1200080910.7306676
Elgin J, Jovanovich L, Vahed S, 1990. Alteration of hepatic lipid by mirex in rats. Pestic Biochem Physiol 38(3):273–285. 10.1016/0048-3575(90)90099-N.
El-Masri HA, Thomas RS, Benjamin SA, 1995. Physiologically based pharmacokinetic/pharmacodynamic modeling of chemical mixtures and possible applications in risk assessment. Toxicology 2(3):275–282.
Emeville E, Giton F, Giusti A, 2013. Persistent organochlorine pollutants with endocrine activity and blood steroid hormone levels in middle-aged men. PLoS ONE 8(6):e66460. 10.1371/journal.pone.0066460.23785499
End DW, Carchman RA, Dewey WL. 1981. Neurochemical correlates of chlordecone neurotoxicity. J Toxicol Environ Health 8(5–6):707–718. 10.1080/15287398109530107.6175764
End DW, Carchman RA, Ameen R, 1979. Inhibition of rat brain mitochondrial calcium transport by chlordecone. Toxicol Appl Pharmacol 51(1):189–196. 10.1016/0041-008x(79)90021-8.93321
Environment Canada. 1992. Toxic chemicals in the Great Lakes and associated effects. Volume II: Effects. Ottawa, Canada: Department of Fisheries and Oceans. 17–67.
EPA. 1976. Kepone: Position document 3. Arlington, VA: U.S. Environmental Protection Agency. PB80216773. EPABPRD8062.
EPA. 1978a. Reviews of the environmental effects of pollutants: I. Mirex and Kepone. Cincinnati, OH: U.S. Environmental Protection Agency. EPA600i78013. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=91013VXH.txt. April 6, 2020.
EPA. 1978b. Designation of hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 116.4. https://www.govinfo.gov/app/details/CFR-2011-title40-vol22/CFR-2011-title40-vol22-sec116-4. April 6, 2020.
EPA. 1980. Levels of chemical contaminants in nonoccupationally exposed US residents. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA600180002. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9100PGR6.txt. April 6, 2020.
EPA. 1981. The potential atmospheric impact of chemicals released to the environment: Proceedings of four workshops. Washington, DC: U.S. Environmental Protection Agency. PB82119447.
EPA. 1982. Determination of the environmental impact of several substitute chemicals in agriculturally affected wetlands. Washington, DC: U.S. Environmental Protection Agency. EPA600482052. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9101KT95.txt. April 6, 2020.
EPA. 1986a. Final report on the evaluation of four toxic chemicals in an ‘in vivo/in vitro’ toxicological screen: Acrylamide, chlordecone, cyclophosphamide, and diethylstilbestrol. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA600186002. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=2000TRTQ.txt. March 25, 2020.
EPA. 1986b. Determination of reportable quantities for hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 117. https://www.ecfr.gov/cgi-bin/text-idx?SID=7889bcd1c745ef35317754d6578ca9eb&mc=true&node=pt40.24.117&rgn=div5. April 6, 2020.
EPA. 1988. Recommendations for and documentation of biological values for use in risk assessment. U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/risk/recordisplay.cfm?deid=34855. September 3, 2020.
EPA. 1992. Definitions. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 300.5. https://www.ecfr.gov/cgi-bin/retrieveECFR?gp=&SID=095dc9d1d7e05f8fd83fdf5b4f674a2b&mc=true&r=PART&n=pt40.30. 300. April 6, 2020.
EPA. 1993. National listing of state fish and shellfish consumption advisories and bans Research Triangle Park, NC: U.S. Environmental Protection Agency. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=901I0700.txt. April 7, 2020.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. EPA260B05001.
EPA. 2009a. National study of chemical residues in lake fish tissue. Washington, DC: U.S. Environmental Protection Agency. EPA823R09006. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P1005P2Z.txt. September 1, 2020.
EPA. 2009b. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency. EPA816F090004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf (https://www.epa.gov/sites/production/files/2016). September 7, 2017.
EPA. 2012. Drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency. EPA822S12001. https://www.epa.gov/sites/production/files/2015-09/documents/dwstandards2012.pdf. April 25, 2013.
EPA. 2016. Acute Exposure Guideline Levels (AEGLs) values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2016-03/documents/compiled_aegl_update_.pdf. September 8, 2017.
Epstein SS. 1978. Kepone - hazard evaluation. Sci Total Environ 9(1):1–62. 10.1016/0048-9697(78)90002-5.74851
Eroschenko VP, Mousa MA. 1979. Neonatal administration of insecticide chlordecone and its effects on the development of the reproductive tract in the female mouse. Toxicol Appl Pharmacol 49(1):151–159. 10.1016/0041-008x(79)90286-2.89714
Ervin MG, Yarbrough JD. 1983. Adrenalectomy and the adaptive liver response in mirex-treated rats. Pestic Biochem Physiol 20(3):330–339. 10.1016/0048-3575(83)90107-4.
Ervin MG, Yarbrough JD. 1985. Mirex-induced liver enlargement in rats is dependent upon an intact pituitary-adrenalcortical axis. Life Sci 36(2):139–145. 10.1016/0024-3205(85)90092-x.2981382
Everett CJ, Matheson EM. 2010. Biomarkers of pesticide exposure and diabetes in the 1999–2004 national health and nutrition examination survey. Environ Int 36(4):398–401. 10.1016/j.envint.2010.02.010.20299099
Fabacher DL, Hodgson E. 1976. Induction of hepatic mixed-function oxidase enzymes in adult and neonatal mice by Kepone and mirex. Toxicol Appl Pharmacol 38(1):71–77. 10.1016/0041-008x(76)90161-7.62422
Fariss MW, Blanke RV, Saady JJ, 1980. Demonstration of major metabolic pathways for chlordecone (Kepone) in humans. Drug Metab Dispos 8(6):434–438.6161768
Faroon OM, Mehendale HM. 1990. Bromotrichloromethane hepatotoxicity. The role of stimulated hepatocellular regeneration in recovery: biochemical and histopathological studies in control and chlordecone pretreated male rats. Toxicol Pathol 18(4 Pt 2):667–677. 10.1177/019262339001800426.1709515
Faroon OM, Henry RW, Soni MG, 1991. Potentiation of BrCCl3 hepatotoxicity by chlordecone: Biochemical and ultrastructural study. Toxicol Appl Pharmacol 110(2):185–197. 10.1016/S0041-008X(05)80001-8.1716382
FDA. 1990. Residues in foods 1989: Monitoring programs: Regulatory monitoring. J Assoc Off Anal Chem 73:127A–146A.
FDA. 1991. Residues in foods: FDA monitoring program: Regulatory monitoring. J Assoc Off Anal Chem 74:121A–141A.
FDA. 1992. Residue monitoring: FDA monitoring programs. J AOAC Int 75:135A–156A.
FDA. 1993. Residue monitoring: FDA monitoring program: Regulatory monitoring. J AOAC Int 76:127A–148A.
FDA. 2013. Everything added to food in the United States (EAFUS). Washington, DC: U.S. Food and Drug Administration. http://www.accessdata.fda.gov/scripts/fcn/fcnnavigation.cfm?rpt=eafuslisting. January 8, 2014.
FDA. 2019. Pesticide residue monitoring 2017 report and data. U.S. Food and Drug Administration. https://www.fda.gov/food/pesticides/pesticide-residue-monitoring-2017-report-and-data. September 1, 2020.
Fenster L, Eskenazi B, Anderson M, 2006. Association of in utero organochlorine pesticide exposure and fetal growth and length of gestation in an agricultural population. Environ Health Perspect 114(4):597–602.16581552
Fernandez MF, Olmos B, Granada A, 2007. Human exposure to endocrine-disrupting chemicals and prenatal risk factors for cryptorchidism and hypospadias: a nested case-control study. Environ Health Perspect 115 Suppl 1:8–14. 10.1289/ehp.9351.18174944
Fitzgerald EF, Hwang SA, Deres DA, 2001. The association between local fish consumption and DDE, mirex, and HCB concentrations in the breast milk of Mohawk women at Akwesasne. J Expo Anal Environ Epidemiol 11(5):381–388. 10.1038/sj.jea.7500180.11687911
Foley RE. 1992. Organochlorine residues in New York waterfowl harvested by hunters in 1983–1984. Environ Monit Assess 21(1):37–48. 10.1007/BF00400056.24234343
Folmar LC. 1978. In vitro inhibition of rat brain ATPase pNPPase, and ATP-32Pi exchange by chlorinated-diphenyl ethanes and cyclodiene insecticides. Bull Environ Contam Toxicol 19(4):481–488. 10.1007/bf01685830.207378
Fouse BL, Hodgson E. 1987. Effect of chlordecone and mirex on the acute hepatotoxicity of acetaminophen in mice. Gen Pharmacol 18(6):623–630. 10.1016/0306-3623(87)90035-8.2444490
Francis BM, Metcalf RL. 1984. Evaluation of mirex, photomirex and chlordecone in the terrestrial aquatic laboratory model ecosystem. Environ Health Perspect 54:341–346. 10.1289/ehp.8454341.6203732
Frank R, Rasper J, Smout MS, 1988. Organochlorine residues in adipose tissues, blood and milk from Ontario residents, 1976–1985. Can J Public Health 79(3):150–158.3135931
Freitag D, Ballhorn L, Geyer H, 1985. Environmental hazard profile of organic chemicals: An experimental method for the assessment of the behaviour of organic chemicals in the ecosphere by means of simple laboratory tests with 14C labelled chemicals. Chemosphere 14(10):1589–1616. 10.1016/0045-6535(85)90014-1.
Fujimori K, Nabeshima T, Ho IK, 1982a. Effects of oral administration of chlordecone and mirex on brain biogenic amines in mice. Neurotoxicology 3(2):143–148.6186959
Fujimori K, Benet H, Mehendale HM, 1982b. Comparison of brain discrete area distributions of chlordecone and mirex in the mouse. Neurotoxicology 3(2):125–129.6186957
Fujimori K, Ho IK, Mehendale HM, 1983. Comparative toxicology of mirex, photomirex and chlordecone after oral administration to the mouse. Environ Toxicol Chem 2(1):49–60. 10.1002/etc.5620020106.
Fujimori K, Benet H, Mehendale HM, 1986. In vivo and in vitro synthesis, release, and uptake of [3-H]-dopamine in mouse striatal slices after in vivo exposure to chlordecone. J Biochem Toxicol 1(4):1–12. 10.1002/jbt.2570010402.
Fulfs J, Abraham R, Drobeck B, 1977. Species differences in the hepatic response to mirex: ultrastructural and histochemical studies. Ecotoxicol Environ Saf 1(3):327–342. 10.1016/0147-6513(77)90024-0.213253
Gaines TB. 1969. Acute toxicity of pesticides. Toxicol Appl Pharmacol 14(3):515–534. 10.1016/0041-008x(69)90013-1.5787520
Gaines TB, Kimbrough RD. 1970. Oral toxicity of mirex in adult and suckling rats. With notes on the ultrastructure of liver changes. Arch Environ Health 21(1):7–14. 10.1080/00039896.1970.10667184.5422329
Galloway SM, Armstrong MJ, Reuben C, 1987. Chromosome aberrations and sister chromatid exchanges in Chinese hamster ovary cells: evaluations of 108 chemicals. Environ Mol Mutagen 10 Suppl 10:1–175. 10.1002/em.2850100502.3319609
Gebauer MB, Weseloh DV. 1993. Accumulation of organic contaminants in sentinel mallards utilizing confined disposal facilities at Hamilton Harbour, Lake Ontario, Canada. Arch Environ Contam Toxicol 25(2) 10.1007/bf00212135.
Gellert RJ. 1978. Kepone, mirex, dieldrin, and aldrin: estrogenic activity and the induction of persistent vaginal estrus and anovulation in rats following neonatal treatment. Environ Res 16(1–3):131–138. 10.1016/0013-9351(78)90150-0.79483
Gellert RJ, Wilson C. 1979. Reproductive function in rats exposed prenatally to pesticides and polychlorinated biphenyls (PCB). Environ Res 18(2):437–443. 10.1016/0013-9351(79)90119-1.92403
Gely-Pernot A, Hao C, Legoff L, 2018. Gestational exposure to chlordecone promotes transgenerational changes in the murine reproductive system of males. Scientific Reports 8(1):10274. 10.1038/s41598-018-28670-w.29980752
George SE, Claxton LD. 1988. Biotransformation of chlordecone by Pseudomonas species. Xenobiotica 18(4):407–416. 10.3109/00498258809041677.2456645
George SE, King LC, Claxton LD. 1986. High-performance liquid chromatography separation of chlordecone and its metabolites. Chromatographia 22(1):165–167. 10.1007/bf02257320.
Gerhart JM, Hong J, Tilson HA. 1983. Studies on the possible sites of chlordecone-induced tremor in rats. Toxicol Appl Pharmacol 70(3):382–389. 10.1016/0041-008X(83)90156-4.6195770
Gerhart JM, Hong JS, Tilson HA. 1985. Studies on the mechanism of chlordecone-induced tremor in rats. Neurotoxicology 6(1):211–229.2581196
Gerhart JM, Hong JS, Uphouse LL, 1982. Chlordecone-induced tremor: quantification and pharmacological analysis. Toxicol Appl Pharmacol 66(2):234–243. 10.1016/0041-008x(82)90288-5.6187105
Germain A, Langlois C. 1988. Pollution of the water and suspended sediments of the St. Lawrence River (Ontario, Quebec, Canada) by organochlorine pesticides, polychlorinated biphenyls, and other priority pollutants. Water Pollut Res J Can 23:602–614. (French)
Gibson JR, Ivie GW, Dorough HW. 1972. Fate of mirex and its major photodecomposition product in rats. J Agric Food Chem 20(6):1246–1248. 10.1021/jf60184a046.5083533
Gilliom RJ, Clifton DG. 1990. Organochlorine pesticide residues in bed sediments of the San Joaquin River, California. J Am Water Resour Assoc 26(1):11–24. 10.1111/j.1752-1688.1990.tb01346.x.
Glende EA, Lee PY. 1985. Isopropanol and chlordecone potentiation of carbon tetrachloride liver injury: retention of potentiating action in hepatocyte suspensions prepared from rats given isopropanol or chlordecone. Exp Mol Pathol 42(2):167–174. 10.1016/0014-4800(85)90025-5.2579844
Good EE, Ware GW, Miller DF. 1965. Effects of insecticides on reproduction in the laboratory mouse. I. Kepone. J Econ Entomol 58(4):754–757. 10.1093/jee/58.4.754.5826350
Grabowski CT. 1981. Plasma proteins and colloid osmotic pressure of blood of rat fetuses prenatally exposed to mirex. J Toxicol Environ Health 7(5):705–714. 10.1080/15287398109530013.7265304
Grabowski CT. 1983. Persistent cardiovascular problems in newborn rats prenatally exposed to sub-teratogenic doses of the pesticide, mirex. Dev Toxicol Environ Sci 11:537–540.6677501
Grabowski CT, Payne DB. 1980. An electrocardiographic study of cardiovascular problems in mirex-fed rat fetuses. Teratology 22(2):167–177. 10.1002/tera.1420220205.7444805
Grabowski CT, Payne DB. 1983a. The causes of perinatal death induced by prenatal exposure of rats to the pesticide, mirex. Part II: Postnatal observations. J Toxicol Environ Health 11(2):301–315. 10.1080/15287398309530343.
Grabowski CT, Payne DB. 1983b. The causes of perinatal death induced by prenatal exposure of rats to the pesticide, mirex. Part I: Pre-parturition observations of the cardiovascular system. Teratology 27(1):7–11. 10.1002/tera.1420270103.6845220
Gray LE, Kavlock RJ. 1984. An extended evaluation of an in vivo teratology screen utilizing postnatal growth and viability in the mouse. Teratog Carcinog Mutagen 4(5):403–426. 10.1002/tcm.1770040504.6150557
Gray LE, Kavlock RJ, Ostby J, 1983. Assessment of the utility of postnatal testing following prenatal exposure to forty chemicals. Prog Clin Biol Res 140:39–72.6672841
Greenberg MM, Anderson R, Keene J, 1982. Empirical test of the association between gross contamination of wells with toxic substances and surrounding land use. Environ Sci Technol 16(1):14–19. 10.1021/es00095a007.
Greer JS, Griwatz GH. 1980. Ultimate disposal of hazardous materials by reaction with liquid sodium. Control of hazardous material spills. In: Proceedings of the 1980 National conference on control of hazardous material spills. Louisville, KY: Vanderbilt University, 416–420.
Greizerstein HB, Stinson C, Mendola P, 1999. Comparison of PCB congeners and pesticide levels between serum and milk from lactating women. Environ Res 80(3):280–286. 10.1006/enrs.1999.3956.10092447
Grindler NM, Allsworth JE, Macones GA, 2015. Persistent organic pollutants and early menopause in U.S. women. PLoS ONE 10(1):e0116057. 10.1371/journal.pone.0116057.25629726
Guo H, Jin Y, Cheng Y, 2014. Prenatal exposure to organochlorine pesticides and infant birth weight in China. Chemosphere 110:1–7. 10.1016/j.chemosphere.2014.02.017.24880592
Guzelian PS. 1982a. Chlordecone poisoning: a case study in approaches for detoxification of humans exposed to environmental chemicals. Drug Metab Rev 13(4):663–679. 10.3109/03602538209011091.6181951
Guzelian PS. 1982b. Comparative toxicology of chlordecone (Kepone) in humans and experimental animals. Annu Rev Pharmacol Toxicol 22:89–113. 10.1146/annurev.pa.22.040182.000513.6177278
Guzelian PS. 1985. Clinical evaluation of liver structure and function in humans exposed to halogenated hydrocarbons. Environ Health Perspect 60:159–164. 10.1289/ehp.8560159.2411535
Guzelian PS, Vranian G, Boylan JJ, 1980. Liver structure and function in patients poisoned with chlordecone (Kepone). Gastroenterology 78(2):206–213.6153073
Guzelian P, Mutter L, Fariss M, 1981. Metabolism and biliary excretion of chlordecone (Kepone) in humans. In: Khan MAQ, Stanton RH, eds. Toxicology of halogenated hydrocarbons. Pergamon, 315–325. 10.1016/B978-0-08-027530-7.50029-7.
Hall L, Fisher H, Sumler M, 1988. Dose response of skin absorption in young and adult rats. In: Mansdorf R, Sager R, Neilsen A, eds. Performance of protective clothing. Vol. 989. West Conshohocken, PA: ASTM International, 177–194. 10.1520/STP26284S.
Hammond B, Katzenellenbogen BS, Krauthammer N, 1979. Estrogenic activity of the insecticide chlordecone (Kepone) and interaction with uterine estrogen receptors. Proc Natl Acad Sci USA 76(12):6641–6645. 10.1073/pnas.76.12.6641.93289
Hammond B, Bahr J, Dial O, 1978. Reproductive toxicology of mirex and kepone (Abstract). Fed Proc Am Soc Exp Biol 37(3):501.
Han X, Meng L, Li Y, 2019. Supplemental data: Associations between exposure to persistent organic pollutants and thyroid function in a case-control study of East China. Environ Sci Technol 10.1021/acs.est.9b02810.
Hawker DW, Connell DW. 1986. Bioconcentration of lipophilic compounds by some aquatic organisms. Ecotoxicol Environ Saf 11(2):184–197. 10.1016/0147-6513(86)90063-1.3709407
Heatherington A, Fisher HL, Sumler MR, 1998. Percutaneous absorption and disposition of [14C]chlordecone in young and adult female rats. Environ Res 79(2):138–155. 10.1006/enrs.1998.3862.9841813
Hebert CE, Glooschenko V, Haffner GD, 1993. Organic contaminants in snapping turtle (Chelydra serpentina) populations from southern Ontario, Canada. Arch Environ Contam Toxicol 24(1):35–43. 10.1007/bf01061087.
Hebert CE, Norstrom RJ, Simon M, 1994. Temporal trends and sources of PCDDs and PCDFs in the great lakes: herring gull egg monitoring, 1981–1991. Environ Sci Technol 28(7):1268–1277. 10.1021/es00056a014.22176318
Hegarty JM, Glende EA, Recknagel RO. 1986. Potentiation by chlordecone of the defect in hepatic microsomal calcium sequestration induced by carbon tetrachloride. J Biochem Toxicol 1(2):73–78. 10.1002/jbt.2570010207.2482892
Herr DW, Gallus JA, Tilson HA. 1987. Pharmacological modification of tremor and enhanced acoustic startle by chlordecone and p,p′-DDT. Psychopharmacology (Berl) 91(3):320–325. 10.1007/bf00518184.2436248
Hervé D, Costet N, Kadhel P, 2016. Prenatal exposure to chlordecone, gestational weight gain, and birth weight in a Guadeloupean birth cohort. Environ Res 151:436–444. 10.1016/j.envres.2016.08.004.27560981
Hewitt LA, Hewitt WR, Plaa GL. 1983. Fractional hepatic localization of 14CHCl3 in mice and rats treated with chlordecone or mirex. Fundam Appl Toxicol 3(6):489–495. 10.1016/s0272-0590(83)80093-1.6198233
Hewitt LA, Ayotte P, Plaa GL. 1986a. Modifications in rat hepatobiliary function following treatment with acetone, 2-butanone, 2-hexanone, mirex, or chlordecone and subsequently exposed to chloroform. Toxicol Appl Pharmacol 83(3):465–473. 10.1016/0041-008x(86)90229-2.2422788
Hewitt LA, Caillé G, Plaa GL. 1986b. Temporal relationships between biotransformation, detoxication, and chlordecone potentiation of chloroform-induced hepatotoxicity. Can J Physiol Pharmacol 64(4):477–482. 10.1139/y86-077.2425914
Hewitt WR, Miyajima H, Cote MG, 1979. Acute alteration of chloroform-induced hepato- and nephrotoxicity by mirex and Kepone. Toxicol Appl Pharmacol 48(3):509–527. 10.1016/0041-008x(79)90434-4.89712
Hewitt LA, Palmason C, Masson S, 1990. Evidence for the involvement of organelles in the mechanism of ketone-potentiated chloroform-induced hepatotoxicity. Liver 10(1):35–48. 10.1111/j.1600-0676.1990.tb00433.x.2308479
Hill EP, Dent DM. 1985. Mirex residues in seven groups of aquatic and terrestrial mammals. Arch Environ Contam Toxicol 14(1):7–12. 10.1007/bf01055755.3977406
Hoff RM, Muir DCG, Grift NP. 1992. Annual cycle of polychlorinated biphenyls and organohalogen pesticides in air in southern Ontario. 1. Air concentration data. Environ Sci Technol 26(2):266–275. 10.1021/es00026a005.
Holden C. 1976. Mirex: persistent pesticide on its way out. Science 194(4262):301–303. 10.1126/science.194.4262.301.17738037
Holloman ME, Layton BR, Kennedy MV, 1975. Identification of the major thermal degradation products of the insecticide mirex. J Agric Food Chem 23(5):1011–1012. 10.1021/jf60201a045.1159173
Holt RL, Cruse S, Greer ES. 1986. Pesticide and polychlorinated biphenyl residues in human adipose tissue from Northeast Louisiana. Bull Environ Contam Toxicol 36(5):651–655. 10.1007/bf01623564.2423161
Hong JS, Tilson HA, Uphouse LL, 1984. Effects of chlordecone exposure on brain neurotransmitters: possible involvement of the serotonin system in chlordecone-elicited tremor. Toxicol Appl Pharmacol 73(2):336–344. 10.1016/0041-008x(84)90339-9.6200957
Hong JS, Herr DW, Hudson PM, 1986. Neurochemical effects of DDT in rat brain in vivo. Arch Toxicol Suppl 9:14–26. 10.1007/978-3-642-71248-7_2.2434059
Hoskins B, Ho IK. 1982. Chlordecone-induced alterations in content and subcellular distribution of calcium in mouse brain. J Toxicol Environ Health 9(4):535–544. 10.1080/15287398209530186.6180171
Houk VS, DeMarini DM. 1987. Induction of prophage lambda by chlorinated pesticides. Mutat Res 182(4):193–201. 10.1016/0165-1161(87)90061-6.2956515
Houston TE, Mutter LC, Blanke RV, 1981. Chlordecone alcohol formation in the Mongolian gerbil (Meriones unguiculatus): A model for human metabolism of chlordecone (Kepone). Fundam Appl Toxicol 1(3):293–298. 10.1016/s0272-0590(81)80132-7.6192032
Howard PH, Michalenko EM, Sage GW, 1991. Chlordecone. In: Handbook of environmental fate and exposure data for organic chemicals. New York, NY: Lewis Publishers, 110–118.
Hsu YN, Lin MT, Hong JS, 1986. Effect of chlordecone exposure on thermoregulation in the rat. Pharmacology 32(5):292–300. 10.1159/000138182.2424036
Huang ES, Nelson FR. 1986. Anti-estrogenic action of chlordecone in rat pituitary gonadotrophs in vitro. Toxicol Appl Pharmacol 82(1):62–69. 10.1016/0041-008x(86)90438-2.2418533
Huang TP, Ho IK, Mehendale HM. 1980. Assessment of neurotoxicity induced by oral administration of chlordecone (Kepone) in the mouse. Neurotoxicology 2(1):113–124.
Huber JJ. 1965. Some physiological effects of the insecticide Kepone in the laboratory mouse. Toxicol Appl Pharmacol 7(4):516–524. 10.1016/0041-008X(65)90036-0.5839388
Huckins JN, Stalling DL, Petty JD, 1982. Fate of Kepone and mirex in the aquatic environment. J Agric Food Chem 30(6):1020–1027. 10.1021/jf00114a004.
Huff JE, Gerstner HB. 1978. Kepone: A literature summary. J Environ Pathol Toxicol 1(4):377–395.82598
Huggett RJ, Bender ME. 1980. Kepone in the James river. Environ Sci Technol 14(8):918–923. 10.1021/es60168a001.22296535
Hwang EC, van Woert MH. 1979. Serotonin-norepinephrine interactions in the tremorolytic actions of phenoxybenzamine and trazodone. Pharmacol Biochem Behav 10(1):27–29. 10.1016/0091-3057(79)90164-3.312503
IARC. 1979. Some halogenated hydrocarbons. IARC monographs on the evaluation of carcinogenic risk of chemicals to humans. Lyon, France: World Health Organization. Vol. 20, 67–81. https://publications.iarc.fr/Book-And-Report-Series/Iarc-Monographs-On-The-Identification-Of-Carcinogenic-Hazards-To-Humans/Some-Halogenated-Hydrocarbons-1979. April 6, 2020.
Iijima M, Cote MG, Plaa GL. 1983. A semiquantitative morphologic assessment of chlordecone-potentiated chloroform hepatotoxicity. Toxicol Lett 17(3–4):307–314. 10.1016/0378-4274(83)90243-6.6194577
Ikegwuonu FI, Mehendale HM. 1991. Biochemical assessment of the genotoxicity of the in vitro interaction between chlordecone and carbon tetrachloride in rat hepatocytes. J Appl Toxicol 11(4):303–310. 10.1002/jat.2550110413.1719056
Innes JRM, Ulland BM, Valerio MG, 1969. Bioassay of pesticides and industrial chemicals for tumorigenicity in mice: A preliminary note. J Natl Cancer Inst 42(6):1101–1114. 10.1093/jnci/42.6.1101.5793189
IRIS. 1992. Mirex. Integrated Risk Information System. Chemical assessment summary. U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0251_summary.pdf. October 18, 2017.
IRIS. 2009. Chlordecone (Kepone). Integrated Risk Information System. Chemical assessment summary. U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/1017_summary.pdf. October 18, 2017.
IRPTC. 1985. Treatment and disposal methods for waste chemicals. Geneva, Switzerland: International Register of Potentially Toxic Chemicals.
Itoh H, Iwasaki M, Hanaoka T, 2009. Serum organochlorines and breast cancer risk in Japanese women: a case-control study. Cancer Causes Control 20(5):567–580. 10.1007/s10552-008-9265-z.19031103
Iverson F. 1976. Induction of paraoxon dealkylation by hexachlorobenzene (HCB) and mirex. J Agric Food Chem 24(6):1238–1241. 10.1021/jf60208a007.1002907
Ivie GW, Dorough HW, Alley EG. 1974b. Photodecomposition of mirex on silica gel chromatoplates exposed to natural and artificial light. J Agric Food Chem 22(6):933–935. 10.1021/jf60196a047.4372264
Ivie GW, Gibson JR, Bryant HE, 1974a. Accumulation, distribution, and excretion of mirex-14C in animals exposed for long periods to the insecticide in the diet. J Agric Food Chem 22(4):646–653. 10.1021/jf60194a054.4840917
Jinna RR, Uzodinma JE, Desaiah D. 1989. Age-related changes in rat brain ATPases during treatment with chlordecone. J Toxicol Environ Health 27(2):199–208. 10.1080/15287398909531291.2471839
Johnson DC. 1996. Estradiol-chlordecone (Kepone) interactions: additive effect of combinations for uterotropic and embryo implantation functions. Toxicol Lett 89(1):57–64.8952712
Johnson DC, Banerjee S, Chatterjee S. 1995. Estradiol and chlordecone (Kepone) decrease adenosine 3’5’-cyclic monophosphate concentrations in the ovariectomized immature rat uterus. Proc Soc Exp Biol Med 210(1):33–38.7545817
Johnson DC, Sen M, Kogo H, 1990. Initiation of embryo implantation and maintenance of early pregnancy in the rat by chlordecone (Kepone). Proc Soc Exp Biol Med 195(1):44–50. 10.3181/00379727-195-43116.1697969
Jones AS, Hodges CS. 1974. Persistence of mirex and its effects on soil microorganisms. J Agric Food Chem 22(3):435–439. 10.1021/jf60193a037.4840507
Jordan JE, Grice T, Mishra SK, 1981. Acute chlordecone toxicity in rats: a relationship between tremor and ATPase activities. Neurotoxicology 2(2):355–364.6172757
Jovanovich L, Levin S, Khan MA. 1987. Significance of mirex-caused hypoglycemia and hyperlipidemia in rats. J Biochem Toxicol 2:203–213. 10.1002/jbt.2570020305.3508472
Kadhel P, Monfort C, Costet N, 2014. Chlordecone exposure, length of gestation, and risk of preterm birth. Am J Epidemiol 179(5):536–544. 10.1093/aje/kwt313.24401561
Kaiser KLE. 1978. Pesticide Report: The rise and fall of mirex. Environ Sci Technol 12(5):520–528. 10.1021/es60141a005.
Kaiser KLE, Lum KR, Comba ME, 1990. Organic trace contaminants in St. Lawrence River water and suspended sediments, 1985–1987. Sci Total Environ 97–98:23–40. 10.1016/0048-9697(90)90228-M.
Kaminsky R, Kaiser K, Hites R. 1983. Fates of organic compounds from Niagara Falls dumpsites in Lake Ontario. J Great Lakes Res 9:183–189. 10.1016/S0380-1330(83)71887-3.
Karl PI, Yarbrough JD. 1984. A comparison of mirex-induced liver growth to liver regeneration. Toxicol Lett 23(1):127–133. 10.1016/0378-4274(84)90018-3.6485013
Kavlock RJ, Chernoff N, Rogers EH. 1985. The effect of acute maternal toxicity on fetal development in the mouse. Teratog Carcinog Mutagen 5(1):3–13. 10.1002/tcm.1770050103.2859660
Kavlock RJ, Short RD, Chernoff N. 1987a. Further evaluation of an in vivo teratology screen. Teratog Carcinog Mutagen 7(1):7–16. 10.1002/tcm.1770070104.2884745
Kavlock RJ, Chernoff N, Rogers E, 1980. Comparative tissue distribution of mirex and chlordecone in fetal and neonatal rats. Pestic Biochem Physiol 14(3):227–235. 10.1016/0048-3575(80)90029-2.
Kavlock RJ, Chernoff N, Rogers E, 1982. An analysis of fetotoxicity using biochemical endpoints of organ differentiation. Teratology 26(2):183–194. 10.1002/tera.1420260211.7157194
Kenaga EE. 1980. Predicted bioconcentration factors and soil sorption coefficients of pesticides and other chemicals. Ecotoxicol Environ Saf 4(1):26–38. 10.1016/0147-6513(80)90005-6.7379718
Kendall MW. 1974. Acute hepatotoxic effects of mirex in the rat. Bull Environ Contam Toxicol 12(5):617–621. 10.1007/bf01684928.4433908
Kendall MW. 1979. Light and electron microscopic observations of the acute sublethal hepatotoxic effects of mirex in the rat. Arch Environ Contam Toxicol 8(1):25–41. 10.1007/bf01055138.533307
Khera KS. 1976. Distribution, metabolism and perinatal toxicity of pesticides with reference to food safety evaluation: Review of selected literature. Adv Mod Toxicol Part 1:369–420.
Kilzer L, Scheunert I, Geyer H, 1979. Laboratory screening of the volatilization rates of organic chemicals from water and soil. Chemosphere 8(10):751–761. 10.1016/0045-6535(79)90036-5.
Kim TW, Smart RC. 1995. Lack of effect of retinoic acid and fluocinolone acetonide on mirex tumor promotion indicates a novel mirex mechanism. Carcinogenesis 16(9):2199–2204.7554075
Kim HT, Kim KS, Kim JS, 1985. Levels of polychlorinated biphenyls (PCBs), DDE, and mirex in waterfowl collected in New York State, 1981–1982. Arch Environ Contam Toxicol 14(1):13–18. 10.1007/bf01055756.3919655
Kim T, Porter KL, Foley JF, 1997. Evidence that mirex promotes a unique population of epidermal cells that cannot be distinguished by their mutant Ha-ras genotype. Mol Carcinog 20(1):115–124.9328442
Kitchin KT, Brown JL. 1989. Biochemical studies of promoters of carcinogenesis in rat liver. Teratog Carcinog Mutagen 9(5):273–285. 10.1002/tcm.1770090503.2575289
Klingensmith JS, Mehendale HM. 1981. Potentiation of brominated halomethane hepatotoxicity by chlordecone in the male rat. Toxicol Appl Pharmacol 61(3):378–384. 10.1016/0041-008x(81)90359-8.6173934
Klingensmith JS, Mehendale HM. 1982a. Chlordecone-induced fat depletion in the male rat. J Toxicol Environ Health 10(1):121–129. 10.1080/15287398209530236.6182302
Klingensmith JS, Mehendale HM. 1982b. Potentiation of CCl4 lethality by chlordecone. Toxicol Lett 11(1–2):149–154. 10.1016/0378-4274(82)90120-5.6178186
Klingensmith JS, Mehendale HM. 1983a. Destruction of hepatic mixed-function oxygenase parameters by CCl4 in rats following acute treatment with chlordecone, mirex, and phenobarbital. Life Sci 33(23):2339–2348. 10.1016/0024-3205(83)90268-0.6196592
Klingensmith JS, Mehendale HM. 1983b. Hepatic microsomal metabolism of CCl4 after pretreatment with chlordecone, mirex, or phenobarbital in male rats. Drug Metab Dispos 11(4):329–334.6193935
Klingensmith JS, Lockard V, Mehendale HM. 1983. Acute hepatotoxicity and lethality of CCl4 in chlordecone-pretreated rats. Exp Mol Pathol 39(1):1–10. 10.1016/0014-4800(83)90036-9.6192011
Kloskowski R, Scheunert I, Klein W, 1981. Laboratory screening of distribution, conversion and mineralization of chemicals in the soil-plant-system and comparison to outdoor experimental data. Chemosphere 10(10):1089–1100. 10.1016/0045-6535(81)90178-8.
Knishkowy B, Baker EL. 1986. Transmission of occupational disease to family contacts. Am J Ind Med 9(6):543–550. 10.1002/ajim.4700090606.2426943
Kocarek TA, Schuetz EG, Guzelian PS. 1991. Selective induction of cytochrome P450e by Kepone (chlordecone) in primary cultures of adult rat hepatocytes. Mol Pharmacol 40(2):203–210.1715015
Kodavanti PR, Kodavanti UP, Mehendale HM. 1991. Carbon tetrachloride-induced alterations of hepatic calmodulin and free calcium levels in rats pretreated with chlordecone. Hepatology 13(2):230–238.1704867
Kodavanti PR, Mehrotra BD, Chetty SC, 1988. Effect of selected insecticides on rat brain synaptosomal adenylate cyclase and phosphodiesterase. J Toxicol Environ Health 25(2):207–215. 10.1080/15287398809531202.2845111
Kodavanti PR, Mehrotra BD, Chetty SC, 1989a. Inhibition of calmodulin activated adenylate cyclase in rat brain by selected insecticides. Neurotoxicology 10(2):219–228.2616064
Kodavanti PR, Joshi UM, Mehendale HM, 1989b. Chlordecone (Kepone)-potentiated carbon tetrachloride hepatotoxicity in partially hepatectomized rats - a histomorphometric study. J Appl Toxicol 9(6):367–375. 10.1002/jat.2550090602.2482307
Kodavanti PR, Cameron JA, Yallapragada PR, 1990a. Effect of chlordecone (Kepone) on calcium transport mechanisms in rat heart sarcoplasmic reticulum. Pharmacol Toxicol 67(3):227–234. 10.1111/j.1600-0773.1990.tb00818.x.1701552
Komulainen H, Bondy SC. 1987. Modulation of levels of free calcium within synaptosomes by organochlorine insecticides. J Pharmacol Exp Ther 241(2):575–581.2437290
Koutros S, Langseth H, Grimsrud TK, 2015a. Prediagnostic serum organochlorine concentrations and metastatic prostate cancer: A nested case-control study in the Norwegian Janus Serum Bank cohort. Environ Health Perspect 123(9):867–872. 10.1289/ehp.1408245.25734605
Koutros S, Langseth H, Grimsrud TK, 2015b. Supplemental data: Prediagnostic serum organochlorine concentrations and metastatic prostate cancer: A nested case-control study in the Norwegian Janus Serum Bank cohort. . Environ Health Perspect 123(9):867–872.25734605
Krishnan K, Anderson ME, Clewell HJ, 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kuhn EP, Suflita JM. 1989. Dehalogenation of pesticides by anaerobic microorganisms in soils and groundwater - A review. In: Reactions and Movement of Organic Chemicals in Soils. Vol. 22. Soil Science Society of America Special Publication, 111–180. 10.2136/sssaspecpub22.c6.
Kuiper GG, Lemmen JG, Carlsson B, 1998. Interaction of estrogenic chemicals and phytoestrogens with estrogen receptor beta. Endocrinology 139(10):4252–4263. 10.1210/endo.139.10.6216.9751507
Kutz F, Strassman S, Yobs A. 1979. Survey of pesticide residues and their metabolites in the general population of the United States. In: Rao KR, ed. Pentachlorophenol. Boston, MA: Springer, 267–274.
Kutz FW, Yobs AR, Johnson WG, 1974. Mirex residues in human adipose tissue. Environ Entomol 3(5):882–884. 10.1093/ee/3.5.882.
Kutz FW, Strassman SC, Stroup CR, 1985. The human body burden of mirex in the southeastern United States. J Toxicol Environ Health 15(3–4):385–394. 10.1080/15287398509530666.4032487
Laessig SA, Auger AP, McCarthy MM, 2007. Effects of prenatal chlordecone on sexually differentiated behavior in adult rats. Neurotoxicol Teratol 29(2):255–263. 10.1016/j.ntt.2006.10.003.17169529
Lal R, Saxena DM. 1982. Accumulation, metabolism, and effects of organochlorine insecticides on microorganisms. Microbiol Rev 46(1):95–127.6178010
Lambert GH, Hsu CC, Humphrey H, 1992. Cytochrome P450IA2 in vivo induction: A potential biomarker of polyhalogenated biphenyls and their related chemical’s effects on the human. Chemosphere 25(1):197–200. 10.1016/0045-6535(92)90512-P.
Larson PS, Egle JL, Hennigar GR, 1979a. Acute and subchronic toxicity of mirex in the rat, dog, and rabbit. Toxicol Appl Pharmacol 49(2):271–277. 10.1016/0041-008x(79)90251-5.494279
Larson PS, Egle JL, Hennigar GR, 1979b. Acute, subchronic, and chronic toxicity of chlordecone. Toxicol Appl Pharmacol 48(1 Pt 1):29–41. 10.1016/s0041-008x(79)80005-8.88086
Lawrence LJ, Casida JE. 1984. Interactions of lindane, toxaphene and cyclodienes with brain-specific t-butylbicyclophosphorothionate receptor. Life Sci 35(2):171–178. 10.1016/0024-3205(84)90136-x.6204183
Lebel G, Dodin S, Ayotte P, 1998. Organochlorine exposure and the risk of endometriosis. Fertil Steril 69(2):221–228.9496332
Legoff L, Dali O, D’Cruz SC, 2019. Ovarian dysfunction following prenatal exposure to an insecticide, chlordecone, associates with altered epigenetic features. Epigenetics Chromatin 12(1):29. 10.1186/s13072-019-0276-7.31084621
Lewis RG, Lee RE. 1976. Air pollution from pesticides: Sources, occurrence, and dispersion. In: Lee RE, ed. Air pollution from pesticides and agricultural processes. Cleveland, OH: CRC Press, Inc., 5–50.
Lewis T, Makarewicz JC. 1988. Exchange of mirex between Lake Ontario and its tributaries. J Great Lakes Res 14 10.1016/S0380-1330(88)71571-3.
Lewis RG, Brown AR, Jackson MD. 1977. Evaluation of polyurethane foam for sampling of pesticides, polychlorinated biphenyls and polychlorinated naphthalenes in ambient air. Anal Chem 49(12):1668–1672. 10.1021/ac50020a014.409309
Linder RE, Scotti TM, McElroy WK, 1983. Spermotoxicity and tissue accumulation of chlordecone (Kepone) in male rats. J Toxicol Environ Health 12(2–3):183–192. 10.1080/15287398309530417.6197529
Lloyd FA, Cain CE, Mast J, 1974. Results of pesticide analysis of human maternal blood. J Miss Acad Sci 17:79–84.
Lockard VG, Mehendale HM, O’Neal RM. 1983a. Chlordecone-induced potentiation of carbon tetrachloride hepatotoxicity: a light and electron microscopic study. Exp Mol Pathol 39(2):230–245. 10.1016/0014-4800(83)90054-0.6194012
Lockard VG, Mehendale HM, O’Neal RM. 1983b. Chlordecone-induced potentiation of carbon tetrachloride hepatotoxicity: a morphometric and biochemical study. Exp Mol Pathol 39(2):246–255. 10.1016/0014-4800(83)90055-2.6194013
Lopez-Espinosa MJ, Granada A, Carreno J, 2007. Organochlorine pesticides in placentas from southern Spain and some related factors. Placenta 28(7):631–638. 10.1016/j.placenta.2006.09.009.17109956
Lum KR, Kaiser KL, Comba ME. 1987. Export of mirex from Lake Ontario to the St. Lawrence Estuary. Sci Total Environ 67(1):41–51. 10.1016/0048-9697(87)90064-7.3423787
Lunsford CA, Weinstein MP, Scott L. 1987. Uptake of Kepone^®^ by the estuarine bivalve Rangia cuneata, during the dredging of contaminated sediments in the James river, Virginia. Water Res 21(4):411–416. 10.1016/0043-1354(87)90188-6.
Mactutus CF, Tilson HA. 1984. Neonatal chlordecone exposure impairs early learning and retention of active avoidance in the rat. Neurobehav Toxicol Teratol 6(1):75–83.6201755
Maier WE, Costa LG. 1990. Na+/K(+)-ATPase in rat brain and erythrocytes as a possible target and marker, respectively, for neurotoxicity: studies with chlordecone, organotins and mercury compounds. Toxicol Lett 51(2):175–188. 10.1016/0378-4274(90)90209-5.1691869
Marsalek J, Schroeter H. 1988. Annual loadings of toxic contaminants in urban runoff from the Canadian Great Lakes Basin. Water Pollut Res J Can 23(3):360–378.
Martinez AJ, Taylor JR, Dyck PJ, 1978. Chlordecone intoxication in man. II. Ultrastructure of peripheral nerves and skeletal muscle. Neurology 28(7):631–635.79156
Maslansky CJ, Williams GM. 1981. Evidence for an epigenetic mode of action in organochlorine pesticide hepatocarcinogenicity: a lack of genotoxicity in rat, mouse, and hamster hepatocytes. J Toxicol Environ Health 8(1–2):121–130. 10.1080/15287398109530056.7328699
Matsumura F. 1985. Involvement of picrotoxinin receptor in the action of cyclodiene insecticides. Neurotoxicology 6(2):139–163.
Mehendale HM. 1976. Mirex-induced suppression of biliary excretion of polychlorinated biphenyl compounds. Toxicol Appl Pharmacol 36(2):369–381. 10.1016/0041-008x(76)90015-6.818744
Mehendale HM. 1977a. Mirex-induced impairment of hepatobiliary function. Suppressed biliary excretion of imipramine and sulfobromophthalein. Drug Metab Dispos 5(1):56–62.13976
Mehendale HM. 1977b. Effect of preexposure to Kepone on the biliary excretion of imipramine and sulfobromophthalein. Toxicol Appl Pharmacol 40(2):247–259. 10.1016/0041-008X(77)90095-3.69337
Mehendale HM. 1979. Modification of hepatobiliary function by toxic chemicals. Fed Proc 38(8):2240–2245.87349
Mehendale HM. 1981. Onset and recovery from chlordecone- and mirex-induced hepatobiliary dysfunction. Toxicol Appl Pharmacol 58(1):132–139. 10.1016/0041-008X(81)90123-X.6165098
Mehendale HM. 1990. Assessment of hepatobiliary function with phenolphthalein and phenolphthalein glucuronide. Clin Chem Enzymol Commun 2:195–204.
Mehendale HM. 1992. Biochemical mechanisms of biphasic dose-response relationships: Role of hormesis. In: Calabrese E, ed. Biological effects of low level exposures to chemicals and radiation. Chelsea, MI: Lewis Publishers, Inc., 59–94.
Mehendale HM. 1994. Cellular and molecular foundations of hermetic mechanisms. In: Calabrese E, ed. Biological effects of low level exposures: Dose-response relationships. Chelsea, MI: Lewis Publishers, 111–142.
Mehendale HM, Klingensmith JS. 1988. In vivo metabolism of CCl4 by rats pretreated with chlordecone, mirex, or phenobarbital. Toxicol Appl Pharmacol 93(2):247–256. 10.1016/0041-008x(88)90124-x.2451866
Mehendale HM, Purushotham KR, Lockard VG. 1989. The time course of liver injury and [3H]thymidine incorporation in chlordecone-potentiated CHCl3 hepatotoxicity. Exp Mol Pathol 51(1):31–47. 10.1016/0014-4800(89)90005-1.2475365
Mehendale HM, Ray SD, Cai Z. 1991. Paradoxical toxicity of carbon tetrachloride in isolated hepatocytes from chlordecone, phenobarbital and mirex pretreated rats. In Vitro Toxicology 4(3):187–196. (English)
Mehendale HM, Fishbein L, Fields M, 1972. Fate of mirex-14C in the rat and plants. Bull Environ Contam Toxicol 8(4):200–207. 10.1007/bf01839512.4669492
Mehendale HM, Chen PR, Fishbein L, 1973. Effect of mirex on the activities of various rat hepatic mixed-function oxidases. Arch Environ Contam Toxicol 1(3):245–254. 10.1007/bf01985747.4204629
Mehendale HM, Takanaka A, Desaiah D, 1977. Kepone induction of hepatic mixed function oxidases in the male rat. Life Sci 20(6):991–997. 10.1016/0024-3205(77)90286-7.66622
Mehendale HM, Takanaka A, Desaiah D, 1978. Effect of preexposure to Kepone on hepatic mixed-function oxidases in the female rat. Toxicol Appl Pharmacol 44(1):171–180. 10.1016/0041-008x(78)90296-x.79240
Mes J. 1992. Organochlorine residues in human blood and biopsy fat and their relationship. Bull Environ Contam Toxicol 48(6):815–820. 10.1007/bf00201140.1568057
Mes J, Davies DJ, Miles W. 1978. Traces of mirex in some Canadian human milk samples. Bull Environ Contam Toxicol 19(5):564–570. 10.1007/bf01685842.667386
Mes J, Marchand L, Davies DJ. 1990. Organochlorine residues in adipose tissue of Canadians. Bull Environ Contam Toxicol 45(5):681–688. 10.1007/bf01700986.2124937
Mes J, Davies DJ, Turton D, 1986. Levels and trends of chlorinated hydrocarbon contaminants in the breast milk of Canadian women. Food Addit Contam 3(4):313–322. 10.1080/02652038609373598.3803638
Mes J, Davies DJ, Doucet J, 1993. Levels of chlorinated hydrocarbon residues in Canadian human breast milk and their relationship to some characteristics of the donors. Food Addit Contam 10(4):429–441. 10.1080/02652039309374166.8405582
Metcalf RL, Kapoor IP, Lu PY, 1973. Model ecosystem studies of the environmental fate of six organochlorine pesticides. Environ Health Perspect 4:35–44. 10.1289/ehp.730435.4124493
Metcalfe JL, Charlton MN. 1990. Freshwater mussels as biomonitors for organic industrial contaminants and pesticides in the St. Lawrence River. Sci Total Environ 97–98:595–615. 10.1016/0048-9697(90)90264-U.
Meyer SA, Moser GJ, Monteiro-Riviere NA, 1993. Minimal role of enhanced cell proliferation in skin tumor promotion by mirex: a nonphorbol ester-type promoter. Environ Health Perspect 101 Suppl 5:265–269.8013418
Meyer SA, Kim TW, Moser GJ, 1994. Synergistic interaction between the non-phorbol ester-type promoter mirex and 12-O-tetradecanoylphorbol-13-acetate in mouse skin tumor promotion. Carcinogenesis 15(1):47–52. 10.1093/carcin/15.1.47.8293547
Minyard JP, Roberts WE. 1991. State findings on pesticide residues in food - 1988 and 1989. J AOAC Int 74(3):438–452.
Mishra SK, Koury M, Desaiah D. 1980. Inhibition of calcium ATPase activity in rat brain and muscle by chlordecone. Bull Environ Contam Toxicol 25(2):262–268. 10.1007/bf01985522.6159026
Mitra A, Richards I, Kitchin K, 1990. Mirex induces ornithine decarboxylase in female rat liver. J Biochem Toxicol 5(2):119–124. 10.1002/jbt.2570050207.2283661
Miyagawa M, Takasawa H, Sugiyama A, 1995. The in vivo-in vitro replicative DNA synthesis (RDS) test with hepatocytes prepared from male B6C3F1 mice as an early prediction assay for putative nongenotoxic (Ames-negative) mouse hepatocarcinogens. Mutat Res 343(2–3):157–183.7791810
Molowa DT, Wrighton SA, Blanke RV, 1986. Characterization of a unique aldo-keto reductase responsible for the reduction of chlordecone in the liver of the gerbil and man. J Toxicol Environ Health 17(4):375–384. 10.1080/15287398609530832.2420999
Morgan DP, Roan CC. 1974. Liver function in workers having high tissue stores of chlorinated hydrocarbon pesticides. Arch Environ Health 29(1):14–17. 10.1080/00039896.1974.10666519.4842619
Morgan DP, Sandifier SH, Hetzler HL, 1979. Test for in vivo conversion of mirex to Kepone. Bull Environ Contam Toxicol 22(1–2):238–244. 10.1007/bf02026936.88976
Mortelmans K, Haworth S, Lawlor T, 1986. Salmonella mutagenicity tests: II. Results from the testing of 270 chemicals. Environ Mutagen 8(S6):1–52. 10.1002/em.2860080702.
Moser GJ, Meyer SA, Smart RC. 1992. The chlorinated pesticide mirex is a novel nonphorbol ester-type tumor promoter in mouse skin. Cancer Res 52(3):631–636.1732051
Moser GJ, Robinette CL, Smart RC. 1993. Characterization of skin tumor promotion by mirex: structure-activity relationships, sexual dimorphism and presence of Ha-ras mutation. Carcinogenesis 14(6):1155–1160. 10.1093/carcin/14.6.1155.8508502
Moysich KB, Ambrosone CB, Vena JE, 1998. Environmental organochlorine exposure and postmenopausal breast cancer risk. Cancer Epidemiol Biomarkers Prev 7(3):181–188.9521429
Mudambi AR, Hassett JP. 1988. Photochemical activity of mirex associated with dissolved organic matter. Chemosphere 17(6):1133–1146. 10.1016/0045-6535(88)90179-8.
Mudambi AR, Hassett JP, McDowell WH, 1992. Mirex-photomirex relationships in Lake Ontario. J Great Lakes Res 18(3):405–414. 10.1016/s0380-1330(92)71307-0.
Mudroch A, Williams D. 1989. Suspended sediments and the distribution of bottom sediments in the Niagara River. J Great Lakes Res 15(3):427–436. 10.1016/s0380-1330(89)71498-2.
Muir DC, Ford CA, Grift NP, 1990. Geographic variation of chlorinated hydrocarbons in burbot (Lota lota) from remote lakes and rivers in Canada. Arch Environ Contam Toxicol 19(4):530–542. 10.1007/bf01059072.2386409
Multigner L, Ndong JR, Giusti A, 2010. Chlordecone exposure and risk of prostate cancer. J Clin Oncol 28(21):3457–3462. 10.1200/jco.2009.27.2153.20566993
Murali B, Korrapati MC, Warbritton A, 2004. Tolerance of aged Fischer 344 rats against chlordecone-amplified carbon tetrachloride toxicity. Mech Ageing Dev 125(6):421–435. 10.1016/j.mad.2004.03.005.15178132
Naqvi SM, de la Cruz AA. 1973. Mirex incorporation in the environment: toxicity in selected freshwater organisms. Bull Environ Contam Toxicol 10(5):305–308. 10.1007/BF01684821.4766134
NAS/NRC. 1989. Report of the oversight committee. Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences. National Research Council. 15–35.
NCI. 1976. Report on carcinogenesis bioassay of technical grade chlordecone (Kepone). Washington, D.C.: National Cancer Institute. https://ntp.niehs.nih.gov/ntp/htdocs/lt_rpts/trchlordecone(kepone).pdf. April 6, 2020.
Newsome WH, Andrews P. 1993. Organochlorine pesticides and polychlorinated biphenyl congeners in commercial fish from the Great Lakes. J AOAC Int 76(4):707–710.8374320
Newsome WH, Ryan JJ. 1999. Toxaphene and other chlorinated compounds in human milk from northern and southern Canada: A comparison. Chemosphere 39(3):519–526.10399849
Newsome WH, Davies D, Doucet J. 1995. PCB and organochlorine pesticides in Canadian human milk - 1992. Chemosphere 30(11):2143–2153.7620848
Nichols MM. 1990. Sedimentologic fate and cycling of Kepone in an estuarine system: Example from the James river estuary. Sci Total Environ 97–98:407–440. 10.1016/0048-9697(90)90254-R.
Niethammer KR, White DH, Baskett TS, 1984. Presence and biomagnification of organochlorine chemical residues in oxbow lakes of northeastern Louisiana. Arch Environ Contam Toxicol 13(1):63–74. 10.1007/bf01055647.6703785
Niimi AJ. 1991. Solubility of organic chemicals in octanol, triolein and cod liver oil and relationships between solubility and partition coefficients. Water Res 25(12):1515–1521. 10.1016/0043-1354(91)90182-p.
NIOSH. 1984. NIOSH manual of analytical methods. Method 5508, 1–4. Cincinnati, OH: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/docs/2003-154/pdfs/5508.pdf. April 5, 2020.
NIOSH. 2016. Kepone. Immediately Dangerous to Life or Health Concentrations (IDLH). Atlanta, GA: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgd0365.html. October 18, 2017.
NLM. 2020. Mirex. National Library of Medicine.
NTP. 1990. Toxicology and carcinogenesis studies of mirex (1,1a,2,2,3,3a,4,5,5,5a,5b,6-dodecachlorooctahydro-1,3,4-metheno-1H-cyclouta[cd]pentalene) (CAS No. 2385–85-5) in F344/N rats (feed studies). National Toxicology Program. TR313.
NTP. 2016a. Kepone. Report on carcinogens, Fourteenth edition. Research Triangle Park, NC: National Toxicology Program. https://ntp.niehs.nih.gov/ntp/roc/content/profiles/kepone.pdf. October 18, 2017.
NTP. 2016b. Mirex. Report on carcinogens, Fourteenth edition. Research Triangle Park, NC: National Toxicology Program. https://ntp.niehs.nih.gov/ntp/roc/content/profiles/mirex.pdf. October 18, 2017.
NYS. 2019. New York State health advice on eating fish you catch. New York State Department of Health. https://www.health.ny.gov/environmental/outdoors/fish/health_advisories/. September 1, 2020.
Oliver BG, Charlton MN. 1984. Chlorinated organic contaminants on settling particulates in the Niagara River vicinity of Lake Ontario [Canada]. Environ Sci Technol 18(12):903–908. 10.1021/es00130a003.
Oliver BG, Nicol KD. 1984. Chlorinated contaminants in the Niagara river, 1981–1983. Sci Total Environ 39(1):57–70. 10.1016/0048-9697(84)90024-X.
Oliver BG, Niimi AJ. 1985. Bioconcentration factors of some halogenated organics for rainbow trout: limitations in their use for prediction of environmental residues. Environ Sci Technol 19(9):842–849. 10.1021/es00139a013.22196610
Oliver BG, Niimi AJ. 1988. Trophodynamic analysis of polychlorinated biphenyl congeners and other chlorinated hydrocarbons in the Lake Ontario ecosystem. Environ Sci Technol 22(4):388–397. 10.1021/es00169a005.
Oliver BG, Charlton MN, Durham RW. 1989. Distribution, redistribution, and geochronology of polychlorinated biphenyl congeners and other chlorinated hydrocarbons in Lake Ontario sediments. Environ Sci Technol 23(2):200–208. 10.1021/es00179a011.
Orndorff SA, Colwell RR. 1980. Microbial transformation of Kepone. Appl Environ Microbiol 39(2):398–406.6155103
OSHA. 2016a. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55. https://www.gpo.gov/fdsys/pkg/CFR-2016-title29-vol8/pdf/CFR-2016-title29-vol8-sec1926-55.pdf. March 6, 2017.
OSHA. 2016b. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. https://www.gpo.gov/fdsys/pkg/CFR-2016-title29-vol6/pdf/CFR-2016-title29-vol6-sec1910-1000.pdf. March 6, 2017.
OSHA. 2017. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. https://www.gpo.gov/fdsys/pkg/CFR-2017-title29-vol7/pdf/CFR-2017-title29-vol7-sec1915-1000.pdf. September 7, 2017.
Peppriell J. 1981. The induction of hepatic microsomal mixed-function oxidase activities in the mouse by mirex, 3,4,5,3′,4′,5′-hexachlorobiphenyl, and equimolar dosages of both. Environ Res 26(2):402–408. 10.1016/0013-9351(81)90216-4.6797821
Phillips LJ, Birchard GF. 1991. Regional variations in human toxics exposure in the USA: an analysis based on the National Human Adipose Tissue Survey. Arch Environ Contam Toxicol 21(2):159–168. 10.1007/bf01055332.1958071
Pinkston G, Uphouse L. 1988. Postovulatory reduction of fertility in chlordecone treated female rats. Reprod Toxicol 1(2):105–109. 10.1016/0890-6238(87)90004-9.
Pittman KA, Wiener M, Treble DH. 1976. Mirex kinetics in the rhesus monkey. II. Pharmacokinetic model. Drug Metab Dispos 4(3):288–295.6235
Pittz EP, Rourke D, Abraham R, 1979. Alterations in hepatic microsomal proteins of mice administered mirex orally. Bull Environ Contam Toxicol 21(3):344–351. 10.1007/bf01685434.444726
Plaa GL, Caille G, Vezina M, 1987. Chloroform interaction with chlordecone and mirex: Correlation between biochemical and histological indices of toxicity and quantitative tissue levels. Fundam Appl Toxicol 9(2):198–207. 10.1093/toxsci/9.2.198.2443411
Pore RS. 1984. Detoxification of chlordecone poisoned rats with chlorella and chlorella derived sporopollenin. Drug Chem Toxicol 7(1):57–71. 10.3109/01480548409014173.6202479
Porter KL, Chanda S, Wang HQ, 2002. 17beta-estradiol is a hormonal regulator of mirex tumor promotion sensitivity in mice. Toxicol Sci 69(1):42–48.12215659
Probst GS, McMahon RE, Hill LE, 1981. Chemically-induced unscheduled DNA synthesis in primary rat hepatocyte cultures: a comparison with bacterial mutagenicity using 218 compounds. Environ Mutagen 3(1):11–32. 10.1002/em.2860030103.7021142
Pryor GT, Uyeno ET, Tilson HA, 1983. Assessment of chemicals using a battery of neurobehavioral tests: a comparative study. Neurobehav Toxicol Teratol 5(1):91–117.6190097
Puertas R, Lopez-Espinosa MJ, Cruz F, 2010. Prenatal exposure to mirex impairs neurodevelopment at age of 4 years. Neurotoxicology 31(1):154–160. 10.1016/j.neuro.2009.09.009.19818364
Purushotham KR, Lockard VG, Mehendale HM. 1988. Amplification of chloroform hepatotoxicity and lethality by dietary chlordecone (Kepone) in mice. Toxicol Pathol 16(1):27–34. 10.1177/019262338801600104.2453913
Rao SB, Young RA, Mehendale HM. 1989. Hepatic polyamines and related enzymes following chlordecone-potentiated carbon tetrachloride toxicity in rats. J Biochem Toxicol 4(1):55–63. 10.1002/jbt.2570040110.2475629
Reimers RS, Akers TG, White L. 1989. Use of applied fields in biological treatment of toxic substances wastewater and sludges. In: Mizrahi A, ed. Advances in biotechnological processes: Vol. 12. Biological waste treatment. New York, NY: Alan R Liss, Inc., 235–272.
Reiter L. 1977. Behavioral toxicology: effects of early postnatal exposure to neurotoxins on development of locomotor activity in the rat. J Occup Med 19(3):200–204.839292
Richter E, Lay JP, Klein W, 1979. Enhanced elimination of Kepone-14C in rats fed liquid paraffin. J Agric Food Chem 27(1):187–189. 10.1021/jf60221a005.84006
Ritchie GP, Ho IK. 1982. Effects of chlordecone and mirex on amino acids incorporation into brain and liver proteins in the mouse. Neurotoxicology 3(4):243–247.6190114
Robacker KM, Kulkarni A, Hodgson E. 1981. Pesticide induced changes in the mouse hepatic microsomal cytochrome P-450-dependent monooxygenase system and other enzymes. J Environ Sci Health B 16(5 Pt B):529–545. 10.1080/03601238109372277.7299069
Roberts MH, Fisher DJ. 1985. Uptake and clearance rates for Kepone in two marine fish species. Arch Environ Contam Toxicol 14(1):1–6. 10.1007/bf01055754.2579612
Robinson KM, Yarbrough JD. 1978a. A study of liver function in rats with mirex-induced enlarged livers. Pestic Biochem Physiol 9(1):61–64. 10.1016/0048-3575(78)90065-2.
Rochelle LG, Miller TL, Curtis LR. 1990. Chlordecone impairs Na+-stimulated l-[3H]glutamate transport and mobility of 16-doxyl stearate in rat liver plasma membrane vesicles. Toxicol Appl Pharmacol 105(2):234–242. 10.1016/0041-008X(90)90185-W.1699298
Rogers JM, Grabowski CT. 1983. Mirex-induced fetal cataracts: lens growth, histology and cation balance, and relationship to edema. Teratology 27(3):343–349. 10.1002/tera.1420270308.6879457
Rogers JM, Grabowski CT. 1984. Postnatal mirex cataractogenesis in rats: lens cation balance, growth and histology. Exp Eye Res 39(5):563–573. 10.1016/0014-4835(84)90056-3.6519195
Rogers JM, Morelli L, Grabowski CT. 1984. Plasma glucose and protein concentrations in rat fetuses and neonates exposed to cataractogenic doses of mirex. Environ Res 34(1):155–161. 10.1016/0013-9351(84)90084-7.6723604
Rosecrans JA, Hong JS, Squibb RE, 1982. Effects of perinatal exposure to chlordecone (Kepone) on neuroendocrine and neurochemical responsiveness of rats to environmental challenges. Neurotoxicology 3(2):131–142.6186958
Rosenbaum DP, Charles AK. 1986. In vitro binding of mirex by mouse hepatocytes. J Toxicol Environ Health 17(4):385–393. 10.1080/15287398609530833.3959119
Rosenbaum PF, Weinstock RS, Silverstone AE, 2017. Metabolic syndrome is associated with exposure to organochlorine pesticides in Anniston, AL, United States. Environ Int 108:11–21.28779625
Rouget F, Kadhel P, Monfort C, 2019. Chlordecone exposure and risk of congenital anomalies: the Timoun Mother-Child Cohort Study in Guadeloupe (French West Indies). Environ Sci Pollut Res Int 10.1007/s11356-019-06031-y.
Saleh FY, Lee GF. 1978. Analytical methodology for Kepone in water and sediment. Environ Sci Technol 12(3):297–301. 10.1021/es60139a013.
Sanborn GE, Selhorst JB, Calabrese VP, 1979. Pseudotumor cerebri and insecticide intoxication. Neurology 29(9 Pt 1):1222–1227.90347
Sandhu SS, Warren WJ, Nelson P. 1978. Pesticidal residue in rural potable water. J Am Water Works Assoc 70:41–45.
Saunders L, Kadhel P, Costet N, 2014. Hypertensive disorders of pregnancy and gestational diabetes mellitus among French Caribbean women chronically exposed to chlordecone. Environ Int 68:171–176. 10.1016/j.envint.2014.03.024.24727072
Savage EP, Keefe TJ, Tessari JD, 1981. National study of chlorinated hydrocarbon insecticide residues in human milk, USA. I. Geographic distribution of dieldrin, heptachlor, heptachlor epoxide, chlordane, oxychlordane, and mirex. Am J Epidemiol 113(4):413–422. 10.1093/oxfordjournals.aje.a113109.7211826
Sawada N, Iwasaki M, Inoue M, 2010. Plasma organochlorines and subsequent risk of prostate cancer in Japanese men: a nested case-control study. Environ Health Perspect 118(5):659–665. 10.1289/ehp.0901214.20435560
Schell LM, Hubicki LA, DeCaprio AP, 2003. Organochlorines, lead, and mercury in Akwesasne Mohawk youth. Environ Health Perspect 111(7):954–961.12782498
Scheunert I, Vockel D, Schmitzer J, 1983. Fate of chemicals in plant-soil systems: comparison of laboratory test data with results of open air long-term experiments. Ecotoxicol Environ Saf 7(4):390–399. 10.1016/0147-6513(83)90004-0.6617565
Schmitt CJ, Zajicek JL, Peterman PH. 1990. National contaminant biomonitoring program: Residues of organochlorine chemicals in U.S. freshwater fish, 1976–1984. Arch Environ Contam Toxicol 19(5):748–781. 10.1007/BF01183992.21318506
Schoeny RS, Smith CC, Loper JC. 1979. Non-mutagenicity for Salmonella of the chlorinated hydrocarbons Aroclor 1254, 1,2,4-trichlorobenzene, mirex and Kepone. Mutat Res 68(2):125–132. 10.1016/0165-1218(79)90140-x.
Schrader TJ, Cooke GM. 2000. Examination of selected food additives and organochlorine food contaminants for androgenic activity in vitro. Toxicol Sci 53(2):278–288.10696776
Scippo ML, Argiris C, Van De Weerdt C, 2004. Recombinant human estrogen, androgen and progesterone receptors for detection of potential endocrine disruptors. Anal Bioanal Chem 378(3):664–669. 10.1007/s00216-003-2251-0.14579009
Scotti TM, Chernoff N, Linder R, 1981. Histopathologic lens changes in mirex-exposed rats. Toxicol Lett 9(3):289–294. 10.1016/0378-4274(81)90163-6.7198310
Seidel V, Lindner W. 1993. Universal sample enrichment technique for organochlorine pesticides in environmental and biological samples using a redesigned simultaneous steam distillation-solvent extraction apparatus. Anal Chem 65(24):3677–3683. 10.1021/ac00072a022.
Seidenberg JM, Becker RA. 1987. A summary of the results of 55 chemicals screened for developmental toxicity in mice. Teratog Carcinog Mutagen 7(1):17–28. 10.1002/tcm.1770070105.2884740
Seidenberg JM, Anderson DG, Becker RA. 1986. Validation of an in vivo developmental toxicity screen in the mouse. Teratog Carcinog Mutagen 6(5):361–374. 10.1002/tcm.1770060503.2878502
Sergeant DB, Munawar M, Hodson PV, 1993. Mirex in the North American Great Lakes: New detections and their confirmation. J Great Lakes Res 19(1):145–157. 10.1016/S0380-1330(93)71205-8.
Sericano J, Atlas EL, Wade TL, 1990. NOAA’s status and trends mussel watch program: Chlorinated pesticides and PCBs in oysters (Crassostrea virginica) and sediments from the Gulf of Mexico, 1986–1987. Mar Environ Res 29(3):161–203. 10.1016/0141-1136(90)90033-K.
Seth PK, Agrawal AK, Bondy SC. 1981. Biochemical changes in the brain consequent to dietary exposure of developing and mature rats to chlordecone (Kepone). Toxicol Appl Pharmacol 59(2):262–267. 10.1016/0041-008x(81)90197-6.6167024
Shah PV, Fisher HL, Sumler MR, 1987. Comparison of the penetration of 14 pesticides through the skin of young and adult rats. J Toxicol Environ Health 21(3):353–366. 10.1080/15287398709531024.3586065
Sierra V, Uphouse L. 1986. Long-term consequences of neonatal exposure to chlordecone. Neurotoxicology 7(2):609–621.2431366
Simmons JE, Berman E, Jackson MB, 1987. In vitro and in vivo toxicity: A comparison of acrylamide, cyclophosphamide, chloroecone, and diethylstilbestrol. J Environ Sci Health A 22(7):639–664. 10.1080/10934528709375377.
Simon GS, Egle JL, Dougherty RW, 1986. Dominant lethal assay of chlordecone and its distribution in the male reproductive tissues of the rat. Toxicol Lett 30(3):237–245. 10.1016/0378-4274(86)90161-x.2422791
Singh AP, Shanker K, Parvez SH. 1984. Effect of Kepone on catecholamine-stimulated sodium, potassium-ATPase of rat brain. Biog Amines 1(4):313–318.
Singh A, Villeneuve DC, Bhatnagar MK, 1982. Ultrastructure of the thyroid glands of rats fed photomirex: an 18-month recovery study. Toxicology 23(4):309–319. 10.1016/0300-483x(82)90069-5.7123565
Singh A, Bhatnagar MK, Villeneuve DC, 1985. Ultrastructure of the thyroid glands of rats fed photomirex: a 48-week recovery study. J Environ Path Toxicol 6(1):115–126.
Sittig M. 1980. Chlordecone & mirex. In: Pesticide manufacturing and toxic materials control encyclopedia. Noyes Data Corporation, 171–173, 533–535.
Skalsky HL, Wrenn JM, Borzelleca JF. 1980. In vitro and in vivo evaluation of the movement of Kepone in the rat submaxillary gland. J Environ Pathol Toxicol 3(5–6):529–536.6160189
Sloterdijk HH. 1991. Mercury and organochlorinated hydrocarbons in surficial sediments of the St. Francis. Water Pollut Res J Can 26(1):41–60. 10.2166/wqrj.1991.004.
Smialowicz RJ, Luebke RW, Riddle MM, 1985. Evaluation of the immunotoxic potential of chlordecone with comparison to cyclophosphamide. J Toxicol Environ Health 15(5):561–574. 10.1080/15287398509530686.2413222
Smith JA, Harte PT, Hardy MA. 1987. Trace-metal and organochlorine residues in sediments of the Upper Rockaway River, New Jersey. Bull Environ Contam Toxicol 39(3):465–473. 10.1007/bf01688312.3117146
Smrek AL, Adams SR, Liddle JA, 1977. Pharmacokinetics of mirex in goats. 1. Effect on reproduction and lactation. J Agric Food Chem 25(6):1321–1325. 10.1021/jf60214a011.915131
Smuckler EA, Koplitz M, Smuckler DE. 1976. Isolation of animal cell nuclei. In: Bimie GD, ed. Subnuclear components: Preparation and fractionation. Boston, MA: Butterworths Publishing Co., 1–37.
Sobel ES, Gianini J, Butfiloski EJ, 2005. Acceleration of autoimmunity by organochlorine pesticides in (NZB x NZW)F1 mice. Environ Health Perspect 113(3):323–328.15743722
Sobel ES, Wang F, Butfiloski E, 2006. Comparison of chlordecone effects on autoimmunity in (NZBxNZW) F1 and BALB/c mice. Toxicology 218(2–3):81–89. 10.1016/j.tox.2005.03.018.16309813
Soine PJ, Blanke RV, Schwartz CC. 1983. Chlordecone metabolism in the pig. Toxicol Lett 17(1–2):35–41. 10.1016/0378-4274(83)90032-2.6194575
Soine PJ, Blanke RV, Guzelian PS, 1982. Preferential binding of chlordecone to the protein and high density lipoprotein fractions of plasma from humans and other species. J Toxicol Environ Health 9(1):107–118. 10.1080/15287398209530146.6174734
Son HK, Kim SA, Kang JH, 2010. Strong associations between low-dose organochlorine pesticides and type 2 diabetes in Korea. Environ Int 36(5):410–414. 10.1016/j.envint.2010.02.012.20381150
Soni MG, Mehendale HM. 1993. Hepatic failure leads to lethality of chlordecone-amplified hepatotoxicity of carbon tetrachloride. Fundam Appl Toxicol 21(4):442–450. 10.1006/faat.1993.1120.7504640
Soni MG, Mehendale HM. 1994. Adenosine triphosphate protection of chlordecone-amplified CCl4 hepatotoxicity and lethality. J Hepatol 20(2):267–274. 10.1016/s0168-8278(05)80068-6.7516359
Spence JH, Markin GP. 1974. Mirex residues in the physical environment following a single bait application, 1971–72. Pestic Monit J 8(2):135–139.4444929
Spinelli JJ, Ng CH, Weber JP, 2007. Organochlorines and risk of non-Hodgkin lymphoma. Int J Cancer 121(12):2767–2775. 10.1002/ijc.23005.17722095
Squibb RE, Tilson HA. 1982a. Neurobehavioral changes in adult Fischer 344 rats exposed to dietary levels of chlordecone (Kepone): a 90-day chronic dosing study. Neurotoxicology 3(2):59–65.6186965
Squibb RE, Tilson HA. 1982b. Effects of gestational and perinatal exposure to chlordecone (Kepone) on the neurobehavioral development of Fischer-344 rats. Neurotoxicology 3(2):17–26.6186962
Starcevic SL, Bortolin S, Woodcroft KJ, 2001. Kepone (chlordecone) disrupts adherens junctions in human breast epithelial cells cultured on matrigel. In Vivo 15(4):289–294.11695219
Stehr-Green PA. 1989. Demographic and seasonal influences on human serum pesticide residue levels. J Toxicol Environ Health 27(4):405–421. 10.1080/15287398909531312.2760935
Stein VB, Pittman KA. 1977. Identification of a mirex metabolite from monkeys. Bull Environ Contam Toxicol 18(4):425–427. 10.1007/bf01683711.411530
Stein VB, Pittman KA, Kennedy MW. 1976. Characterization of a mirex metabolite from monkeys. Bull Environ Contam Toxicol 15(2):140–146. 10.1007/bf01685152.814939
Sterrett FS, Boss CA. 1977. Careless Kepone. Environ Sci Policy Sustain Dev 19(2):30–37. 10.1080/00139157.1977.9928594.
Stevens RJJ, Neilson MA, Stevens RJJ. 1989. Inter- and intralake distributions of trace organic contaminants in surface waters of the Great Lakes. J Great Lakes Res 15(3):377–393.
Stevens JT, Chernoff N, Farmer JD, 1979. Perinatal toxicology of mirex administered in the diet: II. Relationship of hepatic mirex levels to induction of microsomal benzphetamine N-demethylase activity. Toxicol Lett 4(4):269–274. 10.1016/0378-4274(79)90064-X.
Strachan WM. 1990. Atmospheric deposition of selected organochlorine compounds in Canada. In: Kurtz DA, ed. Long range transport of pesticides. Chelsea, Michigan: Lewis Publishers, Inc., 233–240.
Sullivan JB, Krieger GR. 1992. Chlordecone, kelevan, and mirex. In: Hazardous materials toxicology: Clinical principals of environmental health. Philadelphia, PA: Wilkins & Wilkins, 1048–1049.
Sunahara GI, Chiesa A. 1992. Phorone (diisopropylidene acetone), a glutathione depletor, decreases rat glucocorticoid receptor binding in vivo. Carcinogenesis 13(7):1083–1089. 10.1093/carcin/13.7.1083.
Suns KR, Hitchin GG, Toner D. 1993. Spatial and temporal trends of organochlorine contaminants in spottail shiners from selected sites in the Great Lakes (1975–1990). J Great Lakes Res 19(4):703–714. 10.1016/s0380-1330(93)71258-7.
Swanson KL, Woolley DE. 1982. Comparison of the neurotoxic effects of chlordecone and dieldrin in the rat. Neurotoxicology 3(2):81–102.6186967
Swartz WJ, Schutzmann RL. 1986. Reaction of the mouse liver to Kepone exposure. Bull Environ Contam Toxicol 37(2):169–174. 10.1007/bf01607745.2427140
Swartz WJ, Schutzmann RL. 1987. Liver weight response to extended chlordecone exposure. Bull Environ Contam Toxicol 39(4):615–621. 10.1007/BF01698453.2446683
Swartz WJ, Mall GM. 1989. Chlordecone-induced follicular toxicity in mouse ovaries. Reprod Toxicol 3(3):203–206. 10.1016/0890-6238(89)90008-7.2485205
Swartz WJ, Eroschenko VP, Schutzmann RL. 1988. Ovulatory response of chlordecone (Kepone)-exposed mice to exogenous gonadotropins. Toxicology 51(2–3):147–153. 10.1016/0300-483x(88)90145-x.2459805
Swift BL, Foley RE, Batcheller GR. 1993. Organochlorines in Common Goldeneyes wintering in New York. Wild Soc Bull 21(1):52–56. 10.2307/3783361.
Tabaei SH, Pittman CU, Mead KT. 1991. Dehalogenation of organic compounds-2: the metal catalyzed sodium borohydride or sodium alkoxyborohydride/tetraethylene glycol/KOH dechlorination of mirex. Tetrahedron Lett 32(24):2727–2730. 10.1016/0040-4039(91)85069-H.
Tabet E, Genet V, Tiaho F, 2016. Chlordecone potentiates hepatic fibrosis in chronic liver injury induced by carbon tetrachloride in mice. Toxicol Lett 255:1–10. 10.1016/j.toxlet.2016.02.005.26853152
Taylor JR. 1982. Neurological manifestations in humans exposed to chlordecone and follow-up results. Neurotoxicology 3(2):9–16.6186968
Taylor JR. 1985. Neurological manifestations in humans exposed to chlordecone: follow-up results. Neurotoxicology 6(1):231–236.2581197
Taylor JR, Selhorst JB, Houff SA, 1978. Chlordecone intoxication in man: 1. Clinical observations. Neurology 28(7):626–630.79155
Teo S, Vore M. 1990. Mirex exposure inhibits the uptake of estradiol-17 b(b-D-glucuronide), taurocholate, and L-alanine into isolated rat hepatocytes. Toxicol Appl Pharmacol 104(3):411–420. 10.1016/0041-008x(90)90163-o.1696754
Teo S, Vore M. 1991. Mirex inhibits bile acid secretory function in vivo and in the isolated perfused rat liver. Toxicol Appl Pharmacol 109(1):161–170. 10.1016/0041-008x(91)90199-o.1710079
Teschke K, Kelly SJ, Wiens M, 1993. Concentrations of organochlorine pesticides in the adipose tissue of British Columbia residents. Can J Public Health 84(3):192–196.8358696
Thomann RV. 1989. Bioaccumulation model of organic chemical distribution in aquatic food chains. Environ Sci Technol 23(6):699–707. 10.1021/es00064a008.
Thorne BM, Taylor E, Wallace T. 1978. Mirex and behavior in the Long-Evans rat. Bull Environ Contam Toxicol 19(3):351–359. 10.1007/bf01685810.647139
Thottassery JV, Yarbrough JD. 1991. Regulation of glucocorticoid receptors during adaptive liver growth. Am J Physiol 260(4 Pt 1):G603-609. 10.1152/ajpgi.1991.260.4.G603.
Tilson HA, Hong JS, Mactutus CF. 1985. Effects of 5,5-diphenylhydantoin (phenytoin) on neurobehavioral toxicity of organochlorine insecticides and permethrin. J Pharmacol Exp Ther 233(2):285–289.3999019
Tilson HA, Hudson PM, Hong JS. 1986. 5,5-Diphenylhydantoin antagonizes neurochemical and behavioral effects of p,p’-DDT but not of chlordecone. J Neurochem 47(6):1870–1878. 10.1111/j.1471-4159.1986.tb13101.x.2430063
Tong C, Fazio M, Williams GM. 1981. Rat hepatocyte-mediated mutagenesis of human cells by carcinogenic polycyclic aromatic hydrocarbons but not organochlorine pesticides. Proc Soc Exp Biol Med 167(4):572–575. 10.3181/00379727-167-41217.6269115
Topp E, Scheunert I, Attar A, 1986. Factors affecting the uptake of 14C-labeled organic chemicals by plants from soil. Ecotoxicol Environ Saf 11(2):219–228. 10.1016/0147-6513(86)90066-7.3709409
Tsushimoto G, Trosko JE, Chang CC, 1982. Inhibition of intercellular communication by chlordecone (Kepone) and mirex in Chinese hamster v79 cells in vitro. Toxicol Appl Pharmacol 64(3):550–556. 10.1016/0041-008x(82)90252-6.6182642
Tvede KG, Loft S, Poulsen HE, 1989. Methyl parathion toxicity in rats is changed by pretreatment with the pesticides chlordecone, mirex and linuron. Arch Toxicol:446–447.
Ulland BM, Page NP, Squire RA, 1977. A carcinogenicity assay of mirex in Charles River CD rats. J Natl Cancer Inst 58(1):133–140. 10.1093/jnci/58.1.133.189038
Umegaki K, Ikegami S, Ichikawa T. 1993. [Hepatic DNA damage in mice given organochlorine chemicals]. J Food Hyg Soc Jap 34(1):68–73 (Japanese)
Uphouse L, Eckols K. 1986. Serotonin receptors in striatum after chlordecone treatment of adult female rats. Neurotoxicology 7(1):25–32.
Uphouse L, Mason G, Hunter V. 1984. Persistent vaginal estrus and serum hormones after chlordecone (Kepone) treatment of adult female rats. Toxicol Appl Pharmacol 72:177–186.6198783
Uphouse L, Eckols K, Sierra V, 1986. Failure of chlordecone (Kepone) to induce behavioral estrus in adult ovariectomized rats. Neurotoxicology 7(1):127–141.2423933
Upson K, De Roos AJ, Thompson ML, 2013. Organochlorine pesticides and risk of endometriosis: findings from a population-based case-control study. Environ Health Perspect 121(11–12):1319–1324. 10.1289/ehp.1306648.24192044
Uzodinma JE, Torttman CH, Myers RE, 1984. Reproductive abnormalities in rats treated with chlordecone. J Environ Biol 5(2):81–88.
Van Hove Holdrinet M, Frank R, Thomas RL, 1978. Mirex in the sediments of Lake Ontario. J Great Lakes Res 4(1):69–74. 10.1016/s0380-1330(78)72167-2.
Van Oostdam JC, Dewailly E, Gilman A, 2004. Circumpolar maternal blood contaminant survey, 1994–1997 organochlorine compounds. Sci Total Environ 330(1–3):55–70. 10.1016/j.scitotenv.2004.02.028.15325158
Verschueren K. 1983. Mirex & Kepone. In: Handbook of environmental data on organic chemicals. 2nd ed. Van Nostrand Company,
Vig PJ, Mehrotra BD, Desaiah D. 1990. Holothurin: an activator of bovine brain 3’-5’ phosphodiesterase. Res Commun Chem Pathol Pharmacol 67(3):419–422.1693008
Vig PJS, Yallapragada PR, Trottman CH, 1991. Effect of organochlorine and organotin compounds on active conformation of calmodulin. J Environ Sci Health A 26(4):521–534. 10.1080/10934529109375651.
Villeneuve D, Yagminas A, Marino I, 1977. Effects of food deprivation in rats previously exposed to mirex. Bull Environ Contam Toxicol 18:278–284. 10.1007/BF01683419.907847
Wade TL, Atlas EL, Brooks JM, 1988. NOAA Gulf of Mexico status and trends program: Trace organic contaminant distribution in sediments and oysters. Estuaries 11(3):171–179. 10.2307/1351969.
Walker RF, Fishman B. 1991. The influence of age on neurotoxicity. In: The Johns Hopkins series in environmental toxicology: Aging and environmental toxicology: Biological and behavioral perspectives. Baltimore, MD: Johns Hopkins University Press, 211–231.
Wang TP, Ho IK, Mehendale HM. 1981. Correlation between neurotoxicity and chlordecone (Kepone) levels in brain and plasma in the mouse. Neurotoxicology 2(2):373–381.6172759
Wang F, Roberts SM, Butfiloski EJ, 2007a. Acceleration of autoimmunity by organochlorine pesticides: a comparison of splenic B-cell effects of chlordecone and estradiol in (NZBxNZW)F1 mice. Toxicol Sci 99(1):141–152. 10.1093/toxsci/kfm137.17578864
Wang F, Roberts SM, Butfiloski EJ, 2007b. Diminished prolactin from chlordecone treatment in ovariectomized (NZBxNZW)F1 mice. Int Immunopharmacol 7(13):1808–1812. 10.1016/j.intimp.2007.08.020.17996692
Wang F, Sobel ES, Butfiloski EJ, 2008. Comparison of chlordecone and estradiol effects on splenic T-cells in (NZBxNZW)F1 mice. Toxicol Lett 183(1–3):1–9. 10.1016/j.toxlet.2008.08.020.18951962
Wania F, Mackay D. 1993. Global fractionation and cold condensation of low volatility organochlorine compounds in polar regions Ambio 22(1):10–18.
Ware GW, Good EE. 1967. Effects of insecticides on reproduction in the laboratory mouse. II. Mirex, telodrin, and DDT. Toxicol Appl Pharmacol 10(1):54–61. 10.1016/0041-008x(67)90127-5.6031928
Warren RJ, Kirkpatrick RL. 1978. Barbiturate-induced sleeping times, liver weights, and reproduction of cottontail rabbits after mirex ingestion. Bull Environ Contam Toxicol 19(2):223–228. 10.1007/bf01685790.638278
Waters EM, Huff JE, Gerstner HB. 1977a. Mirex. An overview. Environ Res 14(2):212–222. 10.1016/0013-9351(77)90033-0.334527
Waters EM, Gerstner HB, Huff JE. 1977b. Mirex: A risk benefit evaluation. In: Savage EP, ed. Environmental chemicals human and animal health. Proceedings of the 5th annual conference. Colorado State University, U.S. Environmental Protection Agency, 49–77.
WHO. 1984. Environmental health criteria 44: Mirex. Geneva, Switzerland: World Health Organization. EHC 44. http://www.inchem.org/documents/ehc/ehc/ehc44.htm. April 3, 2020.
WHO. 2010. Guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. April 25, 2012.
WHO. 2017. Guidelines for drinking-water quality. Fourth edition incorporating the first addendum. Geneva, Switzerland: World Health Organization. http://apps.who.int/iris/bitstream/10665/254637/1/9789241549950-eng.pdf?ua=1. February 28, 2017.
Wielsoe M, Kern P, Bonefeld-Jorgensen EC. 2017. Supplemental data: Serum levels of environmental pollutants is a risk factor for breast cancer in Inuit: a case control study. Environ Health 16(1) 10.1186/s12940-017-0269-6.
Wiener M, Pittman KA, Stein V. 1976. Mirex kinetics in the rhesus monkey. I. Disposition and excretion. Drug Metab Dispos 4(3):281–287.6234
Williams PP. 1977. Metabolism of synthetic organic pesticides by anaerobic microorganisms. Residue Rev 66:63–135. 10.1007/978-1-4612-6352-4_3.
Williams GM. 1980. Classification of genotoxic and epigenetic hepatocarcinogens using liver culture assays. Ann N Y Acad Sci 349:273–282. 10.1111/j.1749-6632.1980.tb29532.x.6939363
Williams JD, Yarbrough JD. 1983. The relationship between mirex-induced liver enlargement and the adrenal glands. Pestic Biochem Physiol 19(1):15–22. 10.1016/0048-3575(83)90036-6.
Williams DT, LeBel GL, Junkins E. 1984. A comparison of organochlorine residues in human adipose tissue autopsy samples from two Ontario municipalities. J Toxicol Environ Health 13(1):19–29. 10.1080/15287398409530478.6716511
Williams DT, LeBel GL, Junkins E. 1988. Organohalogen residues in human adipose autopsy samples from six Ontario municipalities. J AOAC Int 71(2):410–414.
Williams GM, Mori H, McQueen CA. 1989a. Structure-activity relationships in the rat hepatocyte DNA-repair test for 300 chemicals. Mutat Res 221(3):263–286. 10.1016/0165-1110(89)90039-0.2682231
Williams J, Eckols K, Uphouse L. 1989b. Estradiol and chlordecone interactions with the estradiol receptor. Toxicol Appl Pharmacol 98(3):413–421. 10.1016/0041-008x(89)90170-1.2470164
Wilson D, Yarbrough JD. 1988. Autoradiographic analysis of hepatocytes in mirex-induced adaptive liver growth. Am J Physiol 255(1 Pt 1):G132–139. 10.1152/ajpgi.1988.255.1.G132.3389413
Winger PV, Schultz DP, Johnson WW. 1990. Environmental contaminant concentrations in biota from the lower Savannah River, Georgia and South Carolina. Arch Environ Contam Toxicol 19(1):101–117. 10.1007/bf01059818.2331144
Wolfe J, Esher R, Robinson K, 1979. Lethal and reproductive effects of dietary mirex and DDT on old-field mice, Peromyscus polionotus. Bull Environ Contam Toxicol 21:397–402. 10.1007/BF01685443.444732
Yarbrough JD, Brown LD, Grimley JM. 1984. Mirex-induced adaptive liver growth: a corticosterone-mediated response. Cell Tissue Kinet 17(5):465–473. 10.1111/j.1365-2184.1984.tb00605.x.6467331
Yarbrough JD, Grimley JM, Alley EG. 1986a. Induction of the hepatic cytochrome P-450 dependent monooxygenase system by cis- and tranas-5,10-dihydrogen mirex. Toxicol Lett 32(1):65–71. 10.1016/0378-4274(86)90050-0.3738931
Yarbrough JD, Grimley JM, Karl PI. 1986b. The relationship of ornithine decarboxylase and thymidine kinase to mirex-induced liver growth. Am J Physiol 251(6 Pt 1):G859–865. 10.1152/ajpgi.1986.251.6.G859.3789152
Yarbrough JD, Grimley JM, Thottassery JV. 1992. Mirex-induced adaptive liver growth in rats subjected to thyroidectomy. Hepatology 15(5):923–927. 10.1002/hep.1840150528.1568733
Yarbrough JD, Chambers JE, Grimley JM, 1981. Comparative study of 8-monohydromirex and mirex toxicity in male rats. Toxicol Appl Pharmacol 58(1):105–117. 10.1016/0041-008X(81)90121-6.7233432
Yess NJ. 1988. Food and Drug Administration pesticide program residues in foods 1987. J AOAC Int 71(6):156A–174A.
Yess NJ, Houston MG, Gunderson EL. 1991. Food and Drug Administration pesticide residue monitoring of foods: 1978–1982. J AOAC Int 74:265–272.
Yin C, Hassett JP. 1989. Fugacity and phase distribution of mirex in Oswego River and Lake Ontario waters. Chemosphere 19(8):1289–1296. 10.1016/0045-6535(89)90076-3.
Young RA, Mehendale HM. 1989. Carbon tetrachloride metabolism in partially hepatectomized and sham-operated rats pre-exposed to chlordecone (Kepone). J Biochem Toxicol 4(4):211–219. 10.1002/jbt.2570040403.2483848