# CONTRIBUTORS & REVIEWERS

## CHEMICAL MANAGER TEAM

- Obaid Faroon, D.V.M., Ph.D.
- ATSDR, Office of Innovation and Analytics, Toxicology Section, Atlanta, GA
- David W. Wohlers, Ph.D.
  Lisa Ingerman, Ph.D., DABT
  Laura McIlroy, B.S.
- SRC, Inc., North Syracuse, NY

## REVIEWERS

Interagency Minimal Risk Level Workgroup:

Includes ATSDR; National Center for Environmental Health (NCEH); National Institute for Occupational Safety and Health (NIOSH); U.S. Environmental Protection Agency (EPA); National Toxicology Program (NTP).

Additional reviews for science and/or policy:

ATSDR, Office of Community Health and Hazard Assessment; ATSDR, Office of Capacity Development and Applied Prevention Science; ATSDR, Office of Science; NCEH, Division of Laboratory Science; NCEH, Division of Environmental Health Science and Practice; EPA, National Center for Environmental Assessment.

## PEER REVIEWERS

1. Rogene Henderson, Ph.D., Applied Life Sciences and Toxicology, Lovelace Respiratory Research Institute, 2425 Ridgecrest Dr. SE, Albuquerque, New Mexico
2. Lucio Costa, PharmD., Department of Environmental and Occupational Health Sciences, Department of Neurological Surgery, University of Washington, Seattle, WA, USA and Department of Clinical and Experimental Medicine, University of Parma, Parma, Italy
3. Luc Multigner, M.D., Ph.D., Directeur de Recherche Inserm, Inserm U1085 – IRSET, Institut de Recherche sur la santé, l’environnement et le travail, 9 Avenue du Professeur Léon Bernard, Rennes and Faculté de Médecine, Campus de Fouillole, Pointe à Pitre Cedex, Guadeloupe

These experts collectively have knowledge of toxicology, chemistry, and/or health effects. All reviewers were selected in conformity with Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

ATSDR scientists review peer reviewers’ comments and determine whether changes will be made to the profile based on comments. The peer reviewers’ comments and responses to these comments are part of the administrative record for this compound.

The listing of peer reviewers should not be understood to imply their approval of the profile’s final content. The responsibility for the content of this profile lies with ATSDR.