# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding mirex and chlordecone in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for mirex and chlordecone.

Table 7-1 Regulations and Guidelines Applicable to Mirex and Chlordecone

Agency | Description | Information | Reference
Air
EPA | RfC | No data | IRIS 1992, 2009
WHO | Air quality guidelines | No data | WHO 2010
Water & Food
EPA | Drinking water standards and health advisories | No data | EPA 2012
| National primary drinking water regulations | No data
| RfD
| Mirex | 0.0002 mg/kg/day | IRIS 1992
| Chlordecone | 0.0003 mg/kg/day | IRIS 2009
WHO | Drinking water quality guidelines | Mirex excluded from guideline value derivation because unlikely to occur in drinking water | WHO 2017
FDA | EAFUS | No data^a^ | FDA 2013
Cancer
ACGIH | Carcinogenicity classification | No data | ACGIH 2016
HHS | Carcinogenicity classification
| Mirex | Reasonably anticipated to be a human carcinogen^b^ | NTP 2016b
| Chlordecone | Reasonably anticipated to be a human carcinogen^b^ | NTP 2016a
EPA | Carcinogenicity classification
| Mirex | No data | IRIS 1992
| Chlordecone | Likely to be carcinogenic to humans | IRIS 2009
IARC | Carcinogenicity classification
| Mirex | Group 2B^c^ | IARC 1979
| Chlordecone | Group 2B^c^ | IARC 1979
Occupational
ACGIH | TLV | No data | ACGIH 2016
OSHA | PEL (8-hour TWA) for general industry, construction, and shipyards | No data | OSHA 2016a, 2016b, 2017
NIOSH | REL (up to 10-hour TWA)
| Chlordecone | 0.001 mg/m^3^ ^d^ | NIOSH 2016
Emergency Criteria
EPA | AEGLs-air | No data | EPA 2016
DOE | PACs-air | | DOE 2016a
| Mirex
| PAC-1^e^ | 6.3 mg/m^3^
| PAC-2^e^ | 69 mg/m^3^
| PAC-3^e^ | 410 mg/m^3^
| Chlordecone
| PAC-1^e^ | 1.6 mg/m^3^
| PAC-2^e^ | 17 mg/m^3^
| PAC-3^e^ | 100 mg/m^3^

a The EAFUS list of substances contains ingredients added directly to food that FDA has either approved as food additives or listed or affirmed as GRAS.

b Based on sufficient evidence of carcinogenicity from studies in experimental animals.

c Group 2B: Possibly carcinogenic to humans.

d Potential occupational carcinogen.

e Definitions of PAC terminology are available from U.S. Department of Energy (DOE 2016b).

ACGIH = American Conference of Governmental Industrial Hygienists; AEGL = acute exposure guideline levels; DOE = Department of Energy; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; GRAS = generally recognized as safe; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IRIS = Integrated Risk Information System; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = Protective Action Criteria; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TLV = threshold limit values; TWA = time-weighted average; WHO = World Health Organization