# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information regarding the chemical identity of mirex and chlordecone is located in Table 4-1.

Table 4-1 Chemical Identity of Mirex and Chlordecone^a^

Characteristic | Information
Characteristic | Mirex | Chlordecone
Chemical name | 1,1a,2,2,3,3a,4,5,5,5a,5b,6-Dodeca-chlorooctahydro-1,3,4-metheno-1H-cyclobuta[cd]- pentalene | 1,1a,3,3a,4,5,5,5a,5b,6-Deca-chlorooctahydro-1,3,4- metheno-2H-cyclobuta[cd] pentalen-2-one
Synonym(s) and registered trade name(s) | 1,2,3,4,5,5-Hexachloro-1,3-cyclopentadiene dimer^b^; dodecachlorooctahydro-1,3,4-metheno-1H-cyclobuta[cd] pentalene^b^; CG-1283; Dechlorane; ENT 25719^d^ | Decachloroketone^c^; decachloro-octahydro-1,3,4-metheno-2H-cyclobuta[cd]pentalen-2-one^c^; GC 1189; Kepone; Merex^c^
Chemical formula | C_10_Cl_12_ | C_10_Cl_10_O
Chemical structure | [image] | [image]
CAS Registry Number | 2385-85-5 | 143-50-0

a All information obtained from Budavari et al. 1989, except where noted.

b IARC 1979.

c IARC 1979.

d NLM 2020.

CAS = Chemical Abstracts Service

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of mirex and chlordecone is located in Table 4-2.

Table 4-2 Physical and Chemical Properties of Mirex and Chlordecone

| Information
Property | Mirex | Chlordecone
Molecular weight | 545.59 | 490.68
Color | Snow-white | Tan-white^b^
Physical state | Crystalline solid | Crystalline solid
Melting point | 485°C (decomposes) | 350°C (decomposes)^b^
Boiling point | No data | No data
Density at 25°C | No data | No data
Odor | Odorless | Odorless^c^
Odor threshold | 5.0667 mg/m^3^ ^d^
Solubility:
Water | Practically insoluble; 0.60 mg/L^e^; insoluble^f^; 0.2 mg/L at 24°C (practical grade)^f^ | Slightly soluble; 3.0 mg/L^e^; practically insoluble^b^
Organic solvents | Dioxane (15.3%); xylene (14.3%); benzene (12.2%); CCl_4_ (7.2%); methyl ethyl ketone (5.6%) | Soluble in hydrocarbon solvents, alcohols, ketones
Partition coefficients:
Log K_ow_ | 5.28^g^ | 4.50^h^
Log K_oc_ | 3.763^f^ | 3.38–3.415^h^
Vapor pressure at 25°C | 3×10^−7^ mm Hg^f^ | <3×10^−7^ mm Hg^b^
Henry’s law constant:
at 20°C | 839.37 Pa m^3^/mole^i^ | 2.50×10^−8^ atm
At 22°C | 5.16×10^−4^ atm m^3^/mole^j^ | m^3^/mole^h^
Autoignition temperature | Nonflammable^b^ | Nonflammable
Flashpoint | No data | No data
Flammability limits | Nonflammable^d^; Supports combustion | Nonflammable
Conversion factors | 1 ppm=0.041 mg/m^3^ | 1 ppm=0.046 mg/m^3^
Explosive limits | No data | No data

a All information obtained from Budavari et al. 1989, except where noted.

b IARC 1979.

c Verschueren 1983.

d NLM 2020.

e Kenaga 1980.

f IARC 1979.

g Niimi 1991.

h Howard 1991.

i Domine et al. 1992.

j Yin and Hassett 1986.

CCl_4_ = carbon tetrachloride