# APPENDIX B LITERATURE SEARCH FRAMEWORK FOR MIREX AND CHLORDECONE

The objective of the toxicological profile is to evaluate the potential for human exposure and the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to mirex and chlordecone.

## B.1 LITERATURE SEARCH AND SCREEN

A literature search and screen was conducted to identify studies examining health effects, toxicokinetics, mechanisms of action, susceptible populations, biomarkers, and chemical interactions data for mirex and chlordecone. ATSDR primarily focused on peer-reviewed articles without publication date or language restrictions. Non-peer-reviewed studies that were considered relevant to the assessment of the health effects of mirex and chlordecone have undergone peer review by at least three ATSDR-selected experts who have been screened for conflict of interest. The inclusion criteria used to identify relevant studies examining the health effects of mirex and chlordecone are presented in Table B-1.

Table B-1 Inclusion Criteria for the Literature Search and Screen

Health Effects
Species
Human
Laboratory mammals
Route of exposure
Inhalation
Oral
Dermal (or ocular)
Parenteral (these studies will be considered supporting data)
Health outcome
Death
Systemic effects
Body weight effects
Respiratory effects
Cardiovascular effects
Gastrointestinal effects
Hematological effects
Musculoskeletal effects
Hepatic effects
Renal effects
Dermal effects
Ocular effects
Endocrine effects
Immunological effects
Neurological effects
Reproductive effects
Developmental effects
Other noncancer effects
Cancer
Toxicokinetics
Absorption
Distribution
Metabolism
Excretion
PBPK models
Biomarkers
Biomarkers of exposure
Biomarkers of effect
Interactions with other chemicals

### B.1.1 Literature Search

The current literature search was intended to update the draft toxicological profile for mirex and chlordecone released for public comment in May 2019. The following main databases were searched in October 2019:

- PubMed
- National Library of Medicine’s TOXLINE
- Scientific and Technical Information Network’s TOXCENTER

The search strategy used the chemical names, Chemical Abstracts Service (CAS) numbers, synonyms, and Medical Subject Headings (MeSH) terms for mirex and chlordecone. The query strings used for the literature search are presented in Table B-2.

The search was augmented by searching the Toxic Substances Control Act Test Submissions (TSCATS), NTP website, and National Institute of Health Research Portfolio Online Reporting Tools Expenditures and Results (NIH RePORTER) databases using the queries presented in Table B-3. Additional databases were searched in the creation of various tables and figures, such as the TRI Explorer, the Substance priority list (SPL) resource page, and other items as needed. Regulations applicable to mirex and chlordecone were identified by searching international and U.S. agency websites and documents.

Review articles were identified and used for the purpose of providing background information and identifying additional references. ATSDR also identified reports from the grey literature, which included unpublished research reports, technical reports from government agencies, conference proceedings and abstracts, and theses and dissertations.

Table B-2 Database Query Strings

Database search date | Query string
| OR “1,3,4-Metheno-1H-cyclobuta(cd)pentalene, 1,1a,2,2,3,3a,4,5,5,5a,5b,6-dodecachlorooctahydro-”[tw] OR “1,3,4-Metheno-1H-cyclobuta(cd)pentalene, dodecachlorooctahydro-”[tw] OR “1,3-Cyclopentadiene, 1,2,3,4,5,5-hexachloro-, dimer”[tw] OR “Bichlorendo”[tw] OR “CG-1283”[tw] OR “Cyclopentadiene, hexachloro-, dimer”[tw] OR “Dechlorane”[tw] OR “Dodecachlorooctahydro-1,3,4-metheno-1H-cyclobuta(cd)pentalene”[tw] OR “Dodecachloropentacyclo(3.2.2.0(sup 2,6),0(sup 3,9),0(sup 5,10))decane”[tw] OR “Dodecachloropentacyclo(5.2.1.0(2,6).0(3,9).0(5,8))decane”[tw] OR “Dodecachloropentacyclo(5.2.1.02,6.03,9.05,8)decane”[tw] OR “Dodecachloropentacyclodecane”[tw] OR “Dodecaclor”[tw] OR “Ferriamicide”[tw] OR “Fire Ant Bait”[tw] OR “GC 1283”[tw] OR “Hexachlorocyclopentadiene dimer”[tw] OR “HRS 1276”[tw] OR “HRS l276”[tw] OR “Mirex”[tw] OR “Paramex”[tw] OR “Pentacyclodecane, dodecachloro-”[tw] OR “Perchlordecone”[tw] OR “Perchlorodihomocubane”[tw] OR “Perchloropentacyclo(5.2.1.0(2,6).0(3,9).0(5,8))decane”[tw] OR “Perchloropentacyclo(5.2.1.0(sup 2,6).0(sup 3,9).0(sup 5,8))decane”[tw] OR “Perchloropentacyclo(5.3.0.0(2,6).0(3,9).0(4,8))decane”[tw] OR “Perchloropentacyclodecane”[tw] OR “1,1 a,3,3a,4,5,5,5a,5b,6-Decachlorooctahydro-1,3,4-metheno-2H-cyclobuta(cd)pentalen-2-one”[tw] OR “1,2,3,4,5,5,6,7,8,9,10,10-Dodecachlorooctahydro-1,3,4-metheno-2-cyclobuta(c,d)pentalone”[tw] OR “1,3,4-Metheno-2H-cyclobuta(cd)pentalen-2-one, 1,1a,3,3a,4,5,5,5a,5b,6-decachlorooctahydro-”[tw] OR “2,3,3a,4,5,6,7,7a,8,8a-Decachloro-3a,4,7,7a-tetrahydro-4,7-methanoinden-1-one”[tw] OR “Chlordecone”[tw] OR “Ciba 8514”[tw] OR “Clordecone”[tw] OR “Compound 1189”[tw] OR “Decachloro-1,3,4-metheno-2H-cyclobuta(cd)pentalen-2-one”[tw] OR “Decachloroketone”[tw] OR “Decachlorooctahydro-1,3,4-methano-2H-cyclobuta(cd)pentalen-2-one”[tw] OR “Decachlorooctahydro-1,3,4-metheno-2H-cyclobuta(cd)pentalen-2-one”[tw] OR “Decachlorotetracyclodecanone”[tw] OR “Decachlorotetrahydro-4,7-methanoindeneone”[tw] OR “GC 1189”[tw] OR “General chemicals 1189”[tw] OR “Kepone”[tw] OR “Kepone-2-one, decachlorooctahydro-”[tw] OR “Merex”[tw] OR “1,2,3,5,6,7,8,9,10,10-Decachloro(5.2.1.0(sup 2,6).0(sup 3,9).0(sup 5,8))decano-4-one”[tw] OR “Decachloropentacyclo(5.2.1.0(2,6).0(3,9).0(5),(8))decan-4-one”[tw] OR “Decachloropentacyclo(5.2.1.0(sup 2,6).0(sup 3,9).0(sup 5,8))decan-4-one”[tw] OR “Decachloropentacyclo(5.3.0.0(sup 2,6).0(sup 4,10).0(sup 5,9))decan-3-one”[tw] OR “Perchloropentacyclo(5.3.0.0(2,6).0(3,9).0(4,8))decan-5-one”[tw]) AND (2017/04/01:3000[mhda] OR 2017/04/01:3000[crdt] OR 2017/04/01:3000[edat] OR 2016/04/01:3000[dp]); (“1,1a,2,2,3,3a,4,5,5,5a,5b,6-Dodecachloroactahydro-1,3,4-metheno-1H-cyclobuta[cd]pentalene”[tw] OR “Dodecachlor”[tw] OR “Dodecachlorooctahydro-1,3,4-metheno-2H-cyclobuta(cd)pentalene”[tw] OR “Dodecachloropentacyclo[5.3.0.0(2.6).0(3.9).0(4.8)]decane”[tw] OR “Perchloropentacyclo[5.2.1.02,6.03,9.05,8]decane”[tw] OR “Perchloropentacyclo[5.3.0.02,6.03,9.04,8]decane”[tw] OR “1,1a,3,3a,4,5,5,5a,5b,6-Decachloro-octahydro-1,3,4-metheno-2H-cyclobuta(cd)pentalen-2-one”[tw] OR “1,1a,3,3a,4,5,5a,5b,6-Decachlorooctahydro-1,3,4-metheno-2H-cyclobuta [cd]pentalen-2-one”[tw] OR “1,3,4-Metheno-2H-cyclobuta[cd]pentalen-2-one, 1,1a,3,3a,4,5,5,5a,5b,6-decachlorooctahydro-”[tw] OR “1,3,4-Metheno-2H-cyclobuta[cd]pentalen-2-one, 1,1a,3,3a,4,5,5a,5b,6-decachlorooctahydro-”[tw] OR “1,3,4-Metheno-2H-cyclobuta[cd]pentalen-2-one, decachlorooctahydro-”[tw] OR “1,3,4-Metheno-2H-cyclobutal [cd]pentalen-2-one, 1,1a,3,3a,4,5,5,5a,5b,6-decachloro-octahydro-”[tw] OR “1,3,4-Metheno-2H-cyclobutal[cd]pentalen-2-one, 1,1a,3,3a,4,5,5,5a,5b,6-decachloroctahydro-”[tw] OR “Decachloroctalhydro-1,3,4-metheno-2H-cyclobuta(cd)pentalen-2-one”[tw] OR “Decachloropentacyclo[5.2.1.02,6.03,9.05,8]decan-4-one”[tw]) AND (1993:3000[dp] OR 1993:3000[mhda] OR 1993:3000[edat] OR 1993:3000[crdat]))
Toxline
10/2019 | “Mirex” OR 2385-85-5[rn] OR “Chlordecone” OR 143-50-0[rn]; Year of Publication 2016 through 2019; “1,1a,2,2,3,3a,4,5,5,5a,5b,6-Dodecachlorooctahydro-1,3,4-metheno-1H-cyclobuta(cd)pentalene” OR “1,2,3,4,5,5-Hexachloro-1,3-cyclopentadiene dimer” OR “1,3,4-Metheno-1H-cyclobuta(cd)pentalene, 1,1a,2,2,3,3a,4,5,5,5a,5b,6-dodecachlorooctahydro-” OR “1,3,4-Metheno-1H-cyclobuta(cd)pentalene, dodecachlorooctahydro-” OR “1,3-Cyclopentadiene, 1,2,3,4,5,5-hexachloro-, dimer” OR “Bichlorendo” OR “CG-1283” OR “Cyclopentadiene, hexachloro-, dimer” OR “Dechlorane” OR “Dodecachlorooctahydro-1,3,4-metheno-1H-cyclobuta(cd)pentalene”; Year of Publication 2016 through 2019; “Dodecachloropentacyclo(3.2.2.0(sup 2,6),0(sup 3,9),0(sup 5,10))decane” OR “Dodecachloropentacyclo(5.2.1.0(2,6).0(3,9).0(5,8))decane” OR “Dodecachloropentacyclo(5.2.1.02,6.03,9.05,8)decane” OR “Dodecachloropentacyclodecane” OR “Dodecaclor” OR “Ferriamicide” OR “Fire Ant Bait” OR “GC 1283” OR “Hexachlorocyclopentadiene dimer” OR “HRS 1276” OR “HRS l276” OR “Mirex” OR “Paramex” OR “Pentacyclodecane, dodecachloro-”; Year of Publication 2016 through 2019; “Perchlordecone” OR “Perchlorodihomocubane” OR “Perchloropentacyclo(5.2.1.0(2,6).0(3,9).0(5,8))decane” OR “Perchloropentacyclo(5.2.1.0(sup 2,6).0(sup 3,9).0(sup 5,8))decane” OR “Perchloropentacyclo(5.3.0.0(2,6).0(3,9).0(4,8))decane” OR “Perchloropentacyclodecane” OR “1,1a,3,3a,4,5,5,5a,5b,6-Decachlorooctahydro-1,3,4-metheno-2H-cyclobuta(cd)pentalen-2-one” OR “1,2,3,4,5,5,6,7,8,9,10,10-Dodecachlorooctahydro-1,3,4-metheno-2-cyclobuta(c,d)pentalone” OR “1,3,4-Metheno-2H-cyclobuta(cd)pentalen-2-one, 1,1a,3,3a,4,5,5,5a,5b,6-decachlorooctahydro-”; Year of Publication 2016 through 2019; “2,3,3a,4,5,6,7,7a,8,8a-Decachloro-3a,4,7,7a-tetrahydro-4,7-methanoinden-1-one” OR “Chlordecone” OR “Ciba 8514” OR “Clordecone” OR “Compound 1189” OR “Decachloro-1,3,4-metheno-2H-cyclobuta(cd)pentalen-2-one” OR “Decachloroketone” OR “Decachlorooctahydro-1,3,4-methano-2H-cyclobuta(cd)pentalen-2-one” OR “Decachlorooctahydro-1,3,4-metheno-2H-cyclobuta(cd)pentalen-2-one” OR “Decachlorotetracyclodecanone” OR “Decachlorotetrahydro-4,7-methanoindeneone” OR “GC 1189” OR “General chemicals 1189”; Year of Publication 2016 through 2019; “Kepone” OR “Kepone-2-one, decachlorooctahydro-” OR “Merex” OR “1,2,3,5,6,7,8,9,10,10-Decachloro(5.2.1.0(sup 2,6).0(sup 3,9).0(sup 5,8))decano-4-one” OR “Decachloropentacyclo(5.2.1.0(2,6).0(3,9).0(5),(8))decan-4-one” OR “Decachloropentacyclo(5.2.1.0(sup 2,6).0(sup 3,9).0(sup 5,8))decan-4-one” OR “Decachloropentacyclo(5.3.0.0(sup 2,6).0(sup 4,10).0(sup 5,9))decan-3-one” OR “Perchloropentacyclo(5.3.0.0(2,6).0(3,9).0(4,8))decan-5-one”; Year of Publication 2016 through 2019; “1,1a,2,2,3,3a,4,5,5,5a,5b,6-Dodecachloroactahydro-1,3,4-metheno-1H-cyclobuta(cd)pentalene” OR “Dodecachlor” OR “Dodecachlorooctahydro-1,3,4-metheno-2H-cyclobuta(cd)pentalene” OR “Dodecachloropentacyclo(5.3.0.0(2.6).0(3.9).0(4.8))decane” OR “Perchloropentacyclo(5.2.1.02,6.03,9.05,8)decane” OR “Perchloropentacyclo(5.3.0.02,6.03,9.04,8)decane”; Year of Publication 1993 through 2019; “1,1a,3,3a,4,5,5,5a,5b,6-Decachloro-octahydro-1,3,4-metheno-2H-cyclobuta(cd)pentalen-2-one” OR “1,1a,3,3a,4,5,5a,5b,6-Decachlorooctahydro-1,3,4-metheno-2H-cyclobuta (cd)pentalen-2-one” OR “1,3,4-Metheno-2H-cyclobuta(cd)pentalen-2-one, 1,1a,3,3a,4,5,5,5a,5b,6-decachlorooctahydro-” OR “1,3,4-Metheno-2H-cyclobuta(cd)pentalen-2-one, 1,1a,3,3a,4,5,5a,5b,6-decachlorooctahydro-” OR “1,3,4-Metheno-2H-cyclobuta(cd)pentalen-2-one, decachlorooctahydro-”; Year of Publication 1993 through 2019; “1,3,4-Metheno-2H-cyclobutal(cd)pentalen-2-one, 1,1 a,3,3a,4,5,5,5a,5b,6-decachloro-octahydro-” OR “1,3,4-Metheno-2H-cyclobutal(cd)pentalen-2-one, 1,1a,3,3a,4,5,5,5a,5b,6-decachloroctahydro-” OR “Decachloroctalhydro-1,3,4-metheno-2H-cyclobuta(cd)pentalen-2-one” OR “Decachloropentacyclo(5.2.1.02,6.03,9.05,8)decan-4-one”; Year of Publication 1993 through 2019
Toxcenter
10/2019 | FILE ‘TOXCENTER’ ENTERED AT 11:37:01 ON 08 OCT 2019; CHARGED TO COST=EH038.06.01 .LB.02; L1 6689 SEA FILE=TOXCENTER 2385-85-5 OR 143-50-0; L2 6678 SEA FILE=TOXCENTER L1 NOT TSCATS/FS; L3 6545 SEA FILE=TOXCENTER L2 NOT PATENT/DT; L4 206 SEA FILE=TOXCENTER L3 AND ED>=20170401; L48 36 SEA FILE=TOXCENTER L4 AND MEDLINE/FS; L49 170 SEA FILE=TOXCENTER L4 NOT MEDLINE/FS; L50 179 DUP REM L48 L49 (27 DUPLICATES REMOVED) ANSWERS ‘1-179’ FROM FILE TOXCENTER; L*** DEL 36 S L4 AND MEDLINE/FS; L*** DEL 36 S L4 AND MEDLINE/FS; L51 36 SEA FILE=TOXCENTER L50; L*** DEL 170 S L4 NOT MEDLINE/FS; L*** DEL 170 S L4 NOT MEDLINE/FS; L52 143 SEA FILE=TOXCENTER L50; L53 143 SEA FILE=TOXCENTER (L51 OR L52) NOT MEDLINE/FS D SCAN L53

Table B-3 Strategies to Augment the Literature Search

Source | Query and number screened when available
TSCATS via ChemView
10/2019 | Compounds searched: 2385-85-5, 143-50-0
NTP
10/2019 | “2385-85-5” “143-50-0” “Mirex” “Chlordecone”; “Dechlorane” “Dodecachloropentacyclodecane” “Dodecaclor” “Kepone”; “Fire Ant Bait” “Paramex” “Perchloropentacyclodecane” “Decachloroketone”; “Decachlorooctahydro-1,3,4-metheno-2H-cyclobuta(cd)pentalen-2-one”; “Perchlordecone” “Clordecone” “Ferriamicide”; “Dodecachlor”
Regulations.gov
10/2019 | Compounds searched: 2385-85-5, 143-50-0
Other | Identified throughout the assessment process

The 2019 results were:

- Number of records identified from PubMed, TOXLINE, and TOXCENTER (after duplicate removal): 331
- Number of records identified from other strategies: 10
- Total number of records to undergo literature screening: 431

### B.1.2 Literature Screening

A two-step process was used to screen the literature search to identify relevant studies on mirex and chlordecone:

- Title and abstract screen
- Full text screen

Title and Abstract Screen. Within the reference library, titles and abstracts were screened manually for relevance. Studies that were considered relevant (see Table B-1 for inclusion criteria) were moved to the second step of the literature screening process. Studies were excluded when the title and abstract clearly indicated that the study was not relevant to the toxicological profile.

- Number of titles and abstracts screened: 431
- Number of studies considered relevant and moved to the next step: 75

Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the title and abstract screen step. Each study was reviewed to determine whether it was relevant for inclusion in the toxicological profile.

- Number of studies undergoing full text review: 75
- Number of studies cited in the pre-public draft of the toxicological profile: 602
- Total number of studies cited in the profile: 584

A summary of the results of the literature search and screening is presented in Figure B-1.

Figure B-1 October 2019 Literature Search Results and Screen for Mirex and Chlordecone

Figure B-1 description