# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Office of Innovation and Analytics, Toxicology Section, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Office of Innovation and Analytics, Toxicology Section, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S102-1, Atlanta, Georgia 30329-4027.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Mirex
CAS Numbers: | 2385-85-5
Date: | October 2020
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL.

Rationale for Not Deriving an MRL: No acute-duration inhalation studies were identified for mirex.

Agency Contact (Chemical Manager): Obaid Faroon, D.V.M., Ph.D.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Mirex
CAS Numbers: | 2385-85-5
Date: | October 2020
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL.

Rationale for Not Deriving an MRL: No intermediate-duration inhalation studies were identified for mirex.

Agency Contact (Chemical Manager): Obaid Faroon, D.V.M., Ph.D.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Mirex
CAS Numbers: | 2385-85-5
Date: | October 2020
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL.

Rationale for Not Deriving an MRL: No chronic-duration inhalation studies were identified for mirex.

Agency Contact (Chemical Manager): Obaid Faroon, D.V.M., Ph.D.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Mirex
CAS Numbers: | 2385-85-5
Date: | October 2020
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL.

Rationale for Not Deriving an MRL: No acute-duration oral MRL was derived for mirex because serious effects (arrhythmias in neonatal pups from maternal exposure during gestation) were observed at the lowest dose tested (0.1 mg/kg/day) (Grabowski 1983). ATSDR does not derive MRLs based on serious effects in the absence of identified NOAEL values.

Agency Contact (Chemical Manager): Obaid Faroon, D.V.M., Ph.D.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Mirex
CAS Numbers: | 2385-85-5
Date: | October 2020
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration oral MRL.

Rationale for Not Deriving an MRL: Intermediate-duration oral studies in humans are lacking for mirex. The most suitable animal study provides a LOAEL of 0.67 mg/kg/day for endocrine effects (dilation of rough endoplasmic reticulum cisternae of the thyroid) in weanling Sprague-Dawley rats (Singh et al. 1985). Application of a total uncertainty factor of 1,000 (10 for extrapolation from a NOAEL to a LOAEL, 10 for animal to human extrapolation, and 10 for human variability)and a modifying factor of 3 to be protective of mirex-induced developmental toxicity, including arrhythmias in neonatal pups following maternal exposure during gestation at a dose level as low as 0.1 mg/kg/day in the absence of an identified NOAEL (Grabowski 1983) would yield an intermediate-duration oral MRL of 0.0001 mg/kg/day. This potential MRL is lower than the chronic-duration oral MRL of 0.0003 mg/kg/day derived from an NTP (1990) study in rats (see chronic-duration oral MRL). Another candidate study for derivation of an intermediate-duration oral MRL for mirex identifies a LOAEL of 0.49 mg/kg/day for cataracts in female rat pups (4/10 versus 0/14 controls) (Chu et al. 1981b). The parental rats had been administered mirex in the diet for 91 days prior to mating and during mating (males and females) and throughout gestation and lactation (females). This LOAEL of 0.49 mg/kg/day is considered a serious LOAEL and the study did not identify a NOAEL. Therefore, no intermediate-duration oral MRL was developed for mirex.

Agency Contact (Chemical Manager): Obaid Faroon, D.V.M., Ph.D.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Mirex
CAS Numbers: | 2385-85-5
Date: | October 2020
Profile Status: | Final
Route: | Oral
aDuration: | Chronic
MRL | 0.0003 mg/kg/day
Critical Effect: | Histopathologic liver lesions
Reference: | NTP 1990
Point of Departure: | NOAEL of 0.075 mg/kg/day
Uncertainty Factor: | 100
Modifying Factor: | 3
LSE Graph Key: | 79
Species: | Rat

MRL Summary: An MRL of 0.0003 mg/kg/day has been derived for chronic-duration oral exposure to mirex based on dose-related hepatic changes from a 2-year oral study of male and female F344/N rats (NTP 1990). The NOAEL of 0.075 mg/kg/day was divided by a total uncertainty factor of 100 (10 for animal to human extrapolation and 10 for human variability) and a modifying factor of 3 (to protect for developmental toxicity).

Selection of the Critical Effect: Available animal data identify the liver and kidney as critical targets of mirex toxicity following chronic-duration oral exposure. Potential candidate studies for deriving a chronic-duration oral MRL for mirex are summarized in Table A-1; the lowest LOAEL is 0.75 mg/kg/day for hepatic effects and the corresponding NOAEL is 0.075 mg/kg/day.

Table A-1 NOAELs and LOAELs Identified in Chronic-Duration Oral Studies of Mirex

Endpoint | Effect | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Reference
Body weight | 11% lower mean body weight in female rats treated for 2 years | 1.95 | 3.85 | NTP 1990
Body weight | No effect in rats treated for 21 months | 0.37 | | Chu et al. 1981c
Hepatic | No effect in rats treated for 21 months | 0.37 | | Chu et al. 1981c
Hepatic | Focal and centrilobular necrosis; fatty metamorphosis; dilation of sinusoids in rats treated for 2 years | 0.075 | 0.75 | NTP 1990
Hepatic | Megalocytosis in rats treated for 18 months followed by 6 months of recovery | | 3.6 | Ulland et al. 1977
Renal | Increased severity of nephrotoxicity in rats treated for 2 years | 0.75 | 1.95 | NTP 1990
Renal | Increased incidence of epithelial hyperplasia of the renal pelvis in rats treated for 2 years | 0.075 | 0.75 | NTP 1990

LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level

Selection of the Principal Study: NTP (1990) was selected as the principal study for deriving a chronic-duration oral MRL for mirex because it identified the lowest reliable LOAEL for liver effects, a clearly sensitive effect of mirex toxicity.

Summary of the Principal Study:

NTP. 1990. Toxicology and carcinogenesis studies of mirex (CAS No. 2385-85-5) in F344/N rats (feed studies). Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health, National Toxicology Program. NTP TR 313.

Groups of male and female F344/N rats (52/sex/group; approximately 7–8 weeks of age) were administered mirex (95% purity) in the diet at 0, 0.1, 1.0, 10, 25, or 50 ppm for 104 weeks (first study). During the first 6 months of the study, additional groups of groups of female rats were started on 0, 50, or 100 ppm mirex in the diet (second study), based on the lack of observable toxic effects in the initial groups of female rats. Based on body weight and food consumption data, the study authors estimated average mirex doses to 0.1, 1, 10, 25, and 50 ppm groups from the first study at 0.007, 0.07, 0.7, 1.8, and 3.8 mg/kg/day, respectively, for the males and 0.007, 0.08, 0.7, 2.0, and 3.9 mg/kg/day, respectively, for the females (for the combined sexes, the author estimated doses at 0.007, 0.075, 0.75, 1.95, and 3.85 mg/kg/day, respectively). Estimated doses to the 50 and 100 ppm groups of females from the second study were 3.9 and 7.7 mg/kg/day, respectively. Animals were monitored for survival, clinical signs, body weight, and food intake. All rats were subjected to gross pathologic examination and all major organs and tissues were processed for histopathologic examination.

Survival of 1.95 and 3.85 mg/kg/day male rats was significantly less than that of controls (19/52 and 15/52, respectively, compared to 44/52 controls), most deaths occurred after treatment weeks 86–87. Survival was not affected in mirex-dosed females. By week 100, mean body weights of 1.95 and 3.85 mg/kg/day surviving males were 11–18% less than that of controls and mean body weights of 3.9 and 7.7 mg/kg/day females were 12–18% less than that of controls. The most notable compound-related histopathologic lesions were observed in the liver of male and female rats and included dose-related increased incidence of fatty metamorphosis, cytomegaly, angiectasis (males only), and necrosis. The NOAEL for liver effects was 0.075 mg/kg/day and the LOAEL was 0.75 mg/kg/day for focal and centrilobular necrosis, fatty metamorphosis, and dilation of sinusoids. Incidences of nephropathy occurred at similar frequency in controls and mirex-dosed groups; however, the severity was judged to be greater in the 1.95, 3.9, and 7.7 mg/kg/day groups. Hyperplasia of the renal pelvis epithelium occurred at significantly increased incidence in male rats of the 10, 25, and 50 ppm groups (5/52, 14/51, and 9/52, respectively, versus 0/51 among controls). Incidences of neoplastic nodules in the liver were significantly greater in 0.75, 1.95, and 3.85 mg/kg/day groups of males than controls (14/52, 15/52, and 26/52, respectively, versus 3/52 in control males). Incidences of neoplastic liver nodules in the female rats of the first study were not significantly different from that of controls. However, the incidence among control females (10/52 or 19%) was significantly greater than the historical control incidence (2.8%). In the second study that included 0, 3.9, and 7.7 mg/kg/day groups of female rats, incidences of neoplastic liver nodules (usually consisting of enlarged hepatocytes with eosinophilic or clear cytoplasm arranged in irregular distorted cords one or two cell layers thick, but some consisting of cells with basophilic cytoplasm) were 23/52 (44%), and 30/52 (58%), respectively, versus 2/52 (4%) within a concurrent control group. Incidences of transitional cell papillomas of the renal pelvis of male rats occurred with a positive trend (p<0.02). The incidence in the 3.85 mg/kg/day males was 3/52 (6%) compared to 0/51 (0%) among controls and was noted to be higher than the highest incidence previously observed in controls (1/48 or 2%). Incidences of pheochromocytomas of the adrenal gland occurred with a positive trend and the incidences in 1.95 and 3.85 mg/kg/day male rats were significantly greater than that of controls. Incidences of mononuclear cell leukemia in analysis of all female rats in the first and second studies (combined) were significantly increased in the 0.75, 1.95, 3.9, and 7.7 mg/kg/day groups (14/52 or 27%, 18/52 or 35%, 27/104 or 26%, and 14/52 or 27%) versus 14/104 (13%) among controls.

Selection of the Point of Departure: The treatment-related increased incidence of renal pelvis hyperplasia identified in the 2-year dietary study of rats (NTP 1990) was not considered an appropriate basis for deriving a chronic-duration oral MRL for mirex because the hyperplasia was observed in areas of the kidney that also exhibited tumors. Therefore, the hyperplasia may represent a preneoplastic lesion. However, the liver lesions (focal and centrilobular necrosis, fatty metamorphosis, dilation of sinusoids) identified in the same study (NTP 1990) are nonneoplastic effects that were selected as the critical effects for deriving a chronic-duration oral MRL. The NOAEL of 0.075 mg/kg/day for liver effects was selected as the point of departure for deriving a chronic-duration oral MRL for mirex.

Uncertainty Factor: The NOAEL of 0.075 mg/kg/day was divided by a total uncertainty factor of 100:

- 10 for animal to human extrapolation
- 10 for human variability

Modifying Factor: A modifying factor of 3 was applied to be protective of mirex-induced developmental toxicity (see Section 2.17), including arrhythmias in neonatal pups following maternal exposure during gestation at a dose level as low as 0.1 mg/kg/day in the absence of an identified NOAEL (Grabowski 1983).

Other Additional Studies or Pertinent Information that Lend Support: Adverse hepatic effects were reported in a number of intermediate- or chronic-duration animal studies that employed oral exposure to mirex (Bell and Mehendale 1985; Chu et al. 1980c, 1981a, 1981b; Curtis and Hoyt 1984; Dai et al. 2001; Davison et al. 1976; Gaines and Kimbrough 1970; Larson et al. 1979a; Mehendale 1981; Ulland et al. 1977).

Agency Contacts (Chemical Managers): Obaid Faroon, D.V.M., Ph.D.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Chlordecone
CAS Numbers: | 143-50-0
Date: | October 2020
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration inhalation MRL.

Rationale for Not Deriving an MRL: No acute-duration inhalation studies were identified for chlordecone.

Agency Contact (Chemical Manager): Obaid Faroon, D.V.M., Ph.D.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Chlordecone
CAS Numbers: | 143-50-0
Date: | October 2020
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL.

Rationale for Not Deriving an MRL: No intermediate-duration inhalation studies were identified for chlordecone.

Agency Contact (Chemical Manager): Obaid Faroon, D.V.M., Ph.D.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Chlordecone
CAS Numbers: | 143-50-0
Date: | October 2020
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration inhalation MRL.

Rationale for Not Deriving an MRL: No chronic-duration inhalation studies were identified for chlordecone.

Agency Contact (Chemical Manager): Obaid Faroon, D.V.M., Ph.D.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Chlordecone
CAS Numbers: | 143-50-0
Date: | October 2020
Profile Status: | Final
Route: | Oral
Duration: | Acute
MRL | 0.01 mg/kg/day
Critical Effect: | Neurological effects
Reference: | EPA 1986a
Point of Departure: | NOAEL of 1.25 mg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 12
Species: | Rat

MRL Summary: An acute-duration oral MRL of 0.01 mg/kg/day was derived for chlordecone based on neurological effects (increased startle response) observed in young adult male Fischer 344 rats in a 10-day gavage study conducted by EPA (1986a). The MRL is based on a NOAEL of 1.25 mg/kg/day and a total uncertainty factor of 100 (10 for animal to human extrapolation and 10 for human variability).

Selection of the Critical Effect: Numerous studies have evaluated the toxicity of chlordecone following acute-duration oral exposure. Many studies reported treatment-related neurological effects or developmental effects. Other studies collectively identified the following targets: body weight, cardiovascular system, hematological system, musculoskeletal system, liver, renal system, endocrine system, immunological system, and female reproductive system.

Recent reports evaluated development of the reproductive system following gavage treatment of pregnant mice with chlordecone at 0.1 mg/kg/day during gestation days 6.5–15.5. Gely-Pernot et al. (2018) reported significantly decreased numbers of spermatozoa in adult F1 and F3 mice (note only the parental [F0] dams were administered chlordecone). Legoff et al. (2019) reported delayed vaginal opening and adverse ovarian follicular effects in F1 mice. Both studies only tested a single dose; thus, dose-response relationships cannot be evaluated. The lack of dose-response data along with weaknesses in the reporting of the study design and results preclude using either study as the basis of an MRL. Study weaknesses include the lack of examination for potential maternal toxicity, although the study authors stated that the selected dose level (0.1 mg/kg/day) “has no effect on murine health;” lack of information regarding numbers of pregnant mice/group, numbers of litters produced, numbers of litters contributing to the quantitative data reported; and use of only four progeny/group in some of the analyses.

A summary of the lowest reliable LOAELs for each endpoint is presented in Table A-2. A comparison of the LOAEL values across endpoints supports the identification of the nervous system as the most sensitive target of toxicity.

Table A-2 Lowest LOAELs Identified in Acute-Duration Oral Studies of Chlordecone

Endpoint | Effect | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Reference
Body weight | 15% depressed maternal body weight gain in rats gavaged daily on gestation days 7–16 | | 2 | Chernoff and Rogers 1976
Hematological | Decreased neutrophils in rats exposed for 10 days | 5 | 10 | Smialowicz et al. 1985
Hepatic | Increased serum alkaline phosphatase, ALT, gamma-glutamyl transferase in rats gavaged daily for 10 days | 5 | 10 | EPA 1986a
Renal | Increased blood urea nitrogen in rats gavaged daily for 10 days | 5 | 10 | EPA 1986a
Endocrine | Depletion of epinephrine in adrenal medulla of rats treated for 8 days in diet | | 17 | Baggett et al. 1980
Immunological | Decreases in spleen and thymus weights, leukocyte counts, natural killer cell activity, Concanavalin A responsiveness in rats gavaged daily for 10 days | 5 | 10 | EPA 1986a
Neurological | Increased startle response in young adult male rats gavaged daily for 10 days | 1.25 | 2.5 | EPA 1986a
Reproductive | Persistent estrus in rats gavaged once | | 35 | Swanson and Woolley 1982
Reproductive | Induction of persistent vaginal estrus in mice repeatedly gavaged for 4 or 6 weeks | | 2 | Swartz et al. 1988
Developmental | 86% decreased postnatal day 3 pup survival following daily gavage treatment of maternal rats during gestation days 7–16 | | 10 | EPA 1986a

ALT = alanine aminotransferase; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level

Selection of the Principal Study: The lowest reliable LOAEL values were identified for body weight, neurological effects, and effects on the female reproductive system. Chernoff and Rogers (1976) reported decreases in maternal body weight gain in rat dams administered 2 mg/kg/day chlordecone on gestation days 7–16. Swartz et al. (1988) reported the induction of persistent vaginal estrus in sexually mature mice administered chlordecone by gavage at 2 mg/kg/day, 5 days/week for 2 weeks. EPA (1986a) reported increased startle response in young adult male rats administered 2.5 mg/kg/day chlordecone for 10 days. These comparable LOAELs are at least 4 times lower than the LOAELs for hematological, hepatic, renal, immunological, and developmental effects. The EPA (1986a) study was selected as the principal study for deriving an acute-duration oral MRL for chlordecone because it identified a NOAEL (1.25 mg/kg/day).

Summary of the Principal Study:

EPA. 1986a. Final report on the evaluation of four toxic chemicals in an ‘in vivo/in vitro’ toxicological screen: Acrylamide, chlordecone, cyclophosphamide, and diethylstilbestrol. Research Triangle Park, NC: U.S. Environmental Protection Agency, Health Effects Research Laboratory. EPA600186002.

Groups of young adult male Fischer 344 rats (10/group) were administered chlordecone (in corn oil vehicle) by gavage for 10 days at 0, 0.625, 1.25, 2.5, 5.0, or 10.0 mg/kg/day. Animals were monitored for survival and body weight. Motor activity (performance in a figure 8 maze) and acoustic startle response were evaluated at 1 day following the final dose treatment. Urine was collected for urinalysis and blood was drawn for serum chemistry. At sacrifice, selected organ weights were determined. At ≥2.5 mg/kg/day, the amplitude of the acoustic startle response was significantly increased. At the other two doses, the amplitude was increased with all decibel stimuli. Motor activity in a figure-8 maze was decreased at the highest dose tested. Terminal body weight was depressed by 12% at 10 mg/kg/day. Relative liver weight was significantly increased at 5 and 10 mg/kg/day (15–16% higher than controls). Selected serum chemistry parameters were statistically significantly different from controls only in the high-dose group.

Selection of the Point of Departure: The NOAEL of 1.25 mg/kg/day was selected as the point of departure for deriving an acute-duration oral MRL for chlordecone.

Uncertainty Factor: The NOAEL of 1.25 mg/kg/day was divided by a total uncertainty factor of 100:

- 10 for animal to human extrapolation
- 10 for human variability

Other Additional Studies or Pertinent Information that Lend Support: As stated above, numerous animal studies reported neurological effects associated with acute-duration oral exposure to chlordecone (Albertson et al. 1985; Aldous et al. 1984; Baggett et al. 1980; Chang-Tsui and Ho 1979; Desaiah et al. 1980a; Egle et al. 1979; End et al. 1981; Fujimori et al. 1982a; Hoskins and Ho 1982; Huang et al. 1980; Jordan et al. 1981; Klingensmith and Mehendale 1982a; Mactutus et al. 1984; Mishra et al. 1980; Smialowicz et al. 1985; Swanson and Wooley 1982; Tilson et al. 1985).

Agency Contacts (Chemical Managers): Obaid Faroon, D.V.M., Ph.D.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Chlordecone
CAS Numbers: | 143-50-0
Date: | October 2020
Profile Status: | Final
Route: | Oral
Duration: | Intermediate
MRL | 0.003 mg/kg/day
Critical Effect: | Neurological and male reproductive effects
Reference: | Linder et al. 1983
Point of Departure: | NOAEL of 0.26 mg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 57
Species: | Rat

MRL Summary: An MRL of 0.003 mg/kg/day has been derived for intermediate-duration oral exposure to chlordecone based on neurological and male reproductive effects from a 90-day oral study of male Sprague-Dawley rats (Linder et al. 1983). The NOAEL of 0.26 mg/kg/day was divided by a total uncertainty factor of 100 (10 for animal to human extrapolation and 10 for human variability).

Selection of the Critical Effect: Studies that evaluated chlordecone toxicity in humans did not include dose-response data; therefore, human data were not considered for MRL derivation. Treatment-related effects on the liver, nervous system, body weight, cardiovascular system, endocrine system, reproductive system, and development have been consistently associated with intermediate-duration oral exposure of laboratory animals to chlordecone. A summary of the lowest LOAELs for each endpoint is presented in Table A-3.

Table A-3 Lowest LOAELs Identified in Intermediate-Duration Oral Studies of Chlordecone

Endpoint | Effect | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Reference
Body weight | 13% decreased body weight gain in rats treated for 3 months in diet | | 1.17 | Cannon and Kimbrough 1979
Hepatic | Focal necrosis in rats treated for 3 months in diet | | 1.17 | Cannon and Kimbrough 1979
Endocrine | Reversible hyperplasia of adrenal cortex in rats treated for 3 months in diet | | 1.17 | Cannon and Kimbrough 1979
Neurological | Hyperexcitability, mild tremors in rats treated for 90 days in diet | 0.26 | 0.83 | Linder et al. 1983
Reproductive | 46–48% decreased sperm motility and viability; 19% decreased epididymal sperm concentration in rats treated for 90 days in diet | 0.26 | 0.83 | Linder et al. 1983
Developmental | Decreased postnatal survival in pups from parental mice treated for up to 130 days in diet | 1.9 | 7 | Huber 1965

LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level

A comparison of the LOAEL values across endpoints supports the identification of the nervous system and male reproductive system as the most sensitive targets of toxicity. The identification of the neurotoxicity and reproductive toxicity as sensitive endpoints for chlordecone is supported by several other intermediate-duration studies, which are summarized in Tables A-4 and A-5, respectively.

Table A-4 Selected LOAELs for Neurological Effects Identified in Intermediate-Duration Oral Studies of Chlordecone

Species (strain) | Effect | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Reference
Rat (Sprague-Dawley) | Tremors in rats treated for 15 days in diet | | 4.7 | Agarwal and Mehendale 1984a
Rat (Sherman) | Tremors, hyperexcitability, exaggerated startle response in rats treated for 3 months in diet | | 1.17 M; 1.62 F | Cannon and Kimbrough 1979
Rat (Zivac-Miller) | Tremors, decreased operant behavior in rats repeatedly gavaged for 90 days | | 1 | Dietz and McMillan 1979
Rat (Wistar) | Tremors (dose-related earlier onset and increased severity) in rats treated for up to 6 months in diet | | 2.1 M; 2.4 F | Larson et all 1979b
Rat (Sprague-Dawley) | Hyperexcitability, mild tremors in rats treated for 90 days in diet | 0.26 | 0.83 | Linder et al. 1983
Rat (Sprague-Dawley) | Tremors, hypersensitivity to noise and stress in rats treated for 16 days in diet | | 3.95 | Mehendale et al. 1978
Rat (Fischer 344) | Increased startle response in rats repeatedly gavaged for 15 weeks | 2.8 | 4.1 | Pryor et al. 1983
Rat (Fischer 344) | Exaggerated startle response in rats treated for 90 days in diet | | 1.0 | Squibb and Tilson 1982a
Mouse (BALB/c) | Tremor in mice treated for 2–12 months in diet | 1.9 | 5.6 | Huber 1965

LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level

Table A-5 Lowest LOAELs for Reproductive Effects Identified in Intermediate-Duration Oral Studies of Chlordecone

Species (strain) | Effect | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Reference
Rat (Sherman) | Decreased number of litters born to control males mated to females treated for 3 months in diet | | 1.62 | Cannon and Kimbrough 1979
Rat (Wistar) | Testicular atrophy in 4/5 males treated for 3 months in diet | | 2.1 | Larson et al. 1979b
Rat (Sprague-Dawley) | 46–48% decreased sperm motility and viability; 19% decreased epididymal sperm concentration in rats treated for 90 days in diet | 0.26 | 0.83 | Linder et al. 1983
Mouse (BALB/c) | 36% decrease in second litters in mice treated for 5 months (including 1 month premating) in diet | | 0.94 | Good et al. 1965
Mouse (BALB/c) | 8% decrease in litter size and 19% increase in pair-days to litter among mice treated for 130 days (1 month premating) in diet | | 1.9 | Huber 1965
Mouse (CD-1) | Increased ovulation, persistent vaginal estrus in mice gavaged for 4 or 6 weeks (5 days/week) | | 2 | Swartz et al. 1988

LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level

Selection of the Principal Study: The study of Linder et al. (1983) identified the lowest LOAEL (0.83 mg/kg/day) for both tremors and impaired sperm parameters; the NOAEL was 0.26 mg/kg/day. This multiple dose study was selected as the principal study for derivation of an intermediate-duration oral MRL for chlordecone.

Summary of the Principal Study:

Linder RE, Scotti TM, McElroy WK, 1983. Spermotoxicity and tissue accumulation of chlordecone (Kepone) in male rats. J Toxicol Environ Health 12:183–192.6197529

Groups of 20 adult male Sprague-Dawley rats were administered technical grade chlordecone (purity not specified) in the diet at 0, 5, 15, or 30 ppm for 90 days. Rats were monitored for clinical signs, body weight, and food intake. The study authors estimated chlordecone doses to the 5, 15, and 30 ppm groups to have been 0.26, 0.83, and 1.67 mg/kg/day, respectively. After the 90-day treatment period, 10 rats/group were sacrificed; testes, epididymides, prostate, and seminal vesicles were weighed; epididymal fluid was extracted for evaluation of spermatozoal motility and viability. Reproductive tissues were then processed for histologic examination. The other 10 rats/group were returned to normal diet and each bred to two untreated virgin females during a 14-day posttreatment period. Mated females were sacrificed on gestation day 20 and fetal weights, fetal viability, and total implants were determined. Male rats used for breeding were sacrificed at 4.5 months after cessation of treatment for evaluation of recovery from chlordecone treatment.

One 0.83 mg/kg/day rat died on treatment day 84; one rat each in the 0.26 and 1.67 mg/kg/day groups died during the recovery period (recovery days 64 and 30, respectively). Clinical signs of neurotoxicity, including hyperexcitability and mild tremors, were observed in rats of the 0.83 and 1.67 mg/kg/day groups (incidences not included in the study report). The 1.67 mg/kg/day group sacrificed at 90 days exhibited approximately 7% lower mean final body weight than controls (not considered an adverse effect because the decrease was <10%). The 1.67 mg/kg/day group of rats exhibited significantly lower absolute weights of seminal vesicles and prostate (12 and 24%, respectively, less than controls). Sperm concentration (sperm count) and incidences and type of morphologically abnormal spermatozoa were similar between controls and all chlordecone-treated groups. However, within the 0.83 and 1.67 mg/kg/day groups, decreases in sperm motility (48 and 39%, respectively, less than controls), sperm viability (46 and 33%, respectively, less than controls), and epididymal concentration (19% less than controls for both 0.83 and 1.67 mg/kg/day groups) were observed. There were no chlordecone treatment-related effects on reproductive performance (number of males siring litters, live litters, average litter size, average number of implants, percent resorptions, or fetal weight). At the end of the recovery period, sperm parameters and reproductive organ weights were similar to those of controls. The study identified a NOAEL of 0.26 mg/kg/day and a LOAEL of 0.83 mg/kg/day for clinical signs of neurotoxicity (tremors) and effects on sperm parameters. The LOAEL for effects on sperm parameters is not considered a serious LOAEL due to the lack of effects on reproductive performance.

Selection of the Point of Departure: The NOAEL of 0.26 mg/kg/day was selected as the point of departure for deriving an intermediate-duration oral MRL for chlordecone.

Benchmark dose (BMD) analysis of the neurological effects in the principal study (Linder et al. 1983) was precluded by lack of incidence data for the treatment-related tremors. BMD analysis was conducted on the datasets for sperm motility and sperm viability (Table A-6) to identify potential points of departure for deriving an intermediate-duration oral MRL for chlordecone.

Table A-6 Sperm Motility and Viability Data for Sprague-Dawley rats Administered Chlordecone in the Diet for 90 Days

Dose (mg/kg/day) | 0 | 0.26 | 0.83 | 1.67
Number of rats | 10 | 10 | 10 | 10
Percent motile sperm^a^ | 37.0±3.9 | 33.2±3.8 | 19.2±4.4^b^ | 22.6±5.5^b^
Percent live sperm^a^ | 46.0±4.7 | 36.2±3.3 | 25.0±3.3^b^ | 30.9±4.8^b^

a Mean ± standard error of the mean (SEM).

b Significantly different from control (p<0.05).

Source: Linder et al. 1983

The data for sperm motility and for sperm viability were fit to all available continuous models in EPA’s Benchmark Dose Software (BMDS, version 3.1.2). The following procedure for fitting continuous data was used: the simplest model (linear) was first applied to the data while assuming constant variance; if the data were consistent with the assumption of constant variance (p≥0.1), then the fit of the linear model to the means was evaluated and the polynomial, power, and Hill models were fit to the data while assuming constant variance. Adequate model fit was judged by four criteria: goodness-of-fit p-value (p>0.1), visual inspection of the dose-response curve, scaled residual at the data point (except the control) closest to the predefined benchmark response (BMR), and BMDL that was not 10 times lower than the lowest non-zero dose. Among all models providing adequate fit to the data, the lowest BMDL (the lower limit of a one-sided 95% confidence interval [CI] on the BMD) was selected as a reasonably conservative point of departure when differences between the BMDLs estimated from these models are >3-fold; otherwise, the BMDL from the model with the lowest Akaike’s information criterion (AIC) was chosen. For both datasets, a BMR of 1 standard deviation (SD) change from the control was used.

Table A-7 presents the results of the BMD modeling with constant variance of the sperm motility data. Although most models provided adequate statistical fit, visual inspection of the plotted data indicated a poor fit of the estimated mean values to the measured mean values for the two dose levels closest to the BMD and BMDL.

Table A-7 Results of BMD Analysis (with Constant Variance) of Percent Motile Sperm in Rats Exposed to Chlordecone in the Diet for 90 Days (Linder et al. 1983)

Model | BMD_1SD_^a^ (mg/kg) | BMDL_1SD_^a^ (mg/kg) | Test 4 p-Value^b^ | AIC | Scaled residuals^c^
Model | BMD_1SD_^a^ (mg/kg) | BMDL_1SD_^a^ (mg/kg) | Test 4 p-Value^b^ | AIC | Dose near BMD | Control group
Exponential 2^d^ | 1.27 | 0.63 | 0.185 | 330.23 | 0.95 | 0.34
Exponential 3^d^ | 1.27 | 0.63 | 0.185 | 330.23 | 0.94 | 0.34
Exponential 4^d^ | 0.65 | 0.20 | 0.209 | 330.44 | −0.90 | −0.25
Exponential 5 | | | NA | 331.19 | 0.00 | 0.00
Hill^d,e^ | | | 0.564 | 329.19 | 0.00 | 0.01
Polynomial Degree 3^d^ | 1.55 | 0.93 | 0.124 | 331.03 | 0.80 | 0.61
Polynomial Degree 2^d^ | 1.55 | 0.93 | 0.124 | 331.03 | 0.80 | 0.61
Power^d^ | 1.55 | 0.93 | 0.124 | 331.03 | 0.80 | 0.61
Linear | 1.55 | 0.93 | 0.124 | 331.03 | 0.80 | 0.61

a BMD and BMDL values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet adequate fit.

c [underlined: Scal]ed residuals at doses immediately below and above the BMD.

d Restricted model.

e The Hill model was not considered adequate since less than five dose groups were used.

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _1SD_ = exposure dose associated with a 10% relative deviation from control)

The results of BMD analysis of sperm viability are presented in Table A-8. For the sperm viability data, the Exponential Model 4 was the only model to provide adequate statistical fit to the mean data. However, visual inspection of the plotted data from Exponential Model 4 indicated a poor fit of the estimated mean values to the measured mean values for sperm viability. Therefore, the BMDL estimated from this model was not considered suitable as the basis of the MRL.

Table A-8 Results of BMD Analysis (with Constant Variance) of Percent Sperm Viability in Rats Exposed to Chlordecone in the Diet for 90 Days (Linder et al. 1983)

Model | BMD_1SD_^a^ (mg/kg) | BMDL_1SD_^a^ (mg/kg) | Test 4 p-Value^b^ | AIC | Scaled residuals^c^
Model | BMD_1SD_^a^ (mg/kg) | BMDL_1SD_^a^ (mg/kg) | Test 4 p-Value^b^ | AIC | Dose near BMD | Control group
Exponential 2^d^ | | | 0.0331 | 326.91 | 1.25 | 1.11
Exponential 3^d^ | | | 0.0331 | 326.91 | 1.25 | 1.11
Exponential 4^d^ | | | 0.2064 | 323.68 | 0.33 | -0.08
Exponential 5 | 0.32 | 0.10 | NA | 325.23 | 0.00 | 0.05
Hill^d^ | | | 0.2857 | 323.23 | 0.00 | 0.00
Polynomial Degree 3^d^ | | | 0.0218 | 327.73 | 1.04 | 1.36
Polynomial Degree 2^d^ | | | 0.0218 | 327.73 | 1.04 | 1.36
Power^d^ | | | 0.0218 | 327.73 | 1.04 | 1.36
Linear | | | 0.0218 | 327.73 | 1.04 | 1.36

a BMD and BMDL values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet adequate fit.

c [underlined: Scal]ed residuals at doses immediately below and above the BMD.

d Restricted model.

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _1SD_ = exposure dose associated with a 10% relative deviation from control)

A NOAEL/LOAEL approach to deriving an intermediate-duration oral MRL for chlordecone was applied because a BMD approach was precluded by lack of adequate modeling results.

Uncertainty Factor: The NOAEL of 0.26 mg/kg/day was divided by a total uncertainty factor of 100:

- 10 for animal to human extrapolation
- 10 for human variability

Other Additional Studies or Pertinent Information that Lend Support: Squibb and Tilson (1982a) reported chlordecone-induced exaggerated startle response in male rats administered chlordecone in the diet for 90 days at 1.0 mg/kg/day). Cannon and Kimbrough (1979) reported tremors, hyperactivity, and exaggerated startle response among male and female rats receiving chlordecone from the diet for 3 months at 1.17 and 1.62 mg/kg/day, respectively (lowest exposure level tested). Good et al. (1965) reported decreased numbers of second litters produced by mice at a chlordecone dose level as low as 0.94 mg/kg/day. Cannon and Kimbrough (1979) reported decreased number of litters born to control males mated to chlordecone-treated females dosed at 1.62 mg/kg/day. Larson et al. (1979b) reported testicular atrophy in male rats administered chlordecone for 3 months at 2.1 mg/kg/day.

Agency Contacts (Chemical Managers): Obaid Faroon, D.V.M., Ph.D.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Chlordecone
CAS Numbers: | 143-50-0
Date: | October 2020
Profile Status: | Final
Route: | Oral
Duration: | Chronic
MRL | 0.009 mg/kg/day
Critical Effect: | Renal effects
Reference: | Larson et al. 1979b
Point of Departure: | NOAEL of 0.089 mg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 75
Species: | Rat

MRL Summary: An MRL of 0.0009 mg/kg/day was derived for chronic-duration oral exposure to chlordecone based on renal effects in rats administered chlordecone in the diet for up to 2 years (Larson et al. 1979b). The NOAEL of 0.089 mg/kg/day was divided by a total uncertainty factor of 100 (10 for animal to human extrapolation and 10 for human variability).

Selection of the Critical Effect: Treatment-related effects on body weight, hematological system, liver, renal system, and nervous system, and dermal irritation have been associated with chronic-duration oral exposure of laboratory animals to chlordecone. A summary of the lowest LOAELs for each endpoint is presented in Table A-9. A comparison of the LOAEL values across endpoints supports the identification of the renal system as the most sensitive target of toxicity.

Table A-9 Lowest LOAELs Identified in Chronic-Duration Oral Studies of Chlordecone

Endpoint | Effect | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Reference
Body weight | >10% depressed body weight in rats treated for 1 or 2 years in diet | 0.89 | 2.2 | Larson et al. 1979b
Hematological | Anemia in male rats treated for 80 weeks in diet | | 0.56 | NCI 1976
Hepatic | Fatty infiltration and degeneration in male rats treated for 80 weeks in diet | | 0.56 | NCI 1976
Renal | Proteinuria and increased severity of glomerulosclerosis in rats treated for up to 2 years in diet | 0.089 | 0.45 | Larson et al. 1979b
Dermal | Dermatitis in rats treated for 80 weeks in diet | | 0.56 | NCI 1976
Neurological | Tremors in rats treated for 80 weeks in diet | | 0.56 | NCI 1976

LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level

Results from several studies were considered in the selection of the critical effect for derivation of a chronic-duration oral MRL for chlordecone. Larson et al. (1979b) administered chlordecone in the diet to rats for up to 2 years and reported depressed body weight gain, decreased hematocrit levels, and tremors at 2.2 mg/kg/day; fatty changes in the liver at 0.89 mg/kg/day; and proteinuria and increased severity of glomerulosclerosis in the kidney at 0.45 mg/kg/day. In an 80-week study of rats administered chlordecone in the diet (NCI 1976), adverse dermal, hepatic, hematological, and neurological effects were observed at the lowest dose tested (0.56 and 1.4 mg/kg/day for males and females, respectively). Similarly-treated mice exhibited adverse hepatic and neurological effects at the lowest dose tested (3.4 and 3.5 mg/kg/day for males and females, respectively). Larson et al. (1979b) also treated dogs for up to 128 weeks at doses up to 1.2 mg/kg/day and observed no neurological effects. Chu et al. (1981c) reported histopathological thyroid lesions in male Sprague-Dawley rats treated with chlordecone in the diet for 21 months at 0.07 mg/kg/day. However, the study report indicated that 4/10 control rats exhibited thyroid lesions (mild degenerative and proliferative changes in follicular epithelium without alteration in colloid density) and that 4/6 chlordecone-treated rats exhibited mild histological changes that may have included decreased colloid density. Thus, it is not clear whether a significant difference existed between controls and chlordecone-treated rats regarding thyroid lesions. Therefore, the thyroid lesion data were not considered for MRL derivation.

Selection of the Principal Study: Larson et al. (1979b) was selected as the principal study for deriving a chronic-duration oral MRL for chlordecone because it identified a NOAEL (0.089 mg/kg/day) associated with the lowest LOAEL (0.45 mg/kg/day for renal effects). The kidney effect observed in rats treated for up to 2 years represents the lowest reliable LOAEL (0.45 mg/kg/day) among the candidate treatment-related adverse effects from chronic-duration oral exposure to chlordecone, and was therefore selected as the critical effect for deriving a chronic-duration oral MRL for chlordecone.

Summary of the Principal Study:

Larson PS, Egle JL Jr, Hennigar CR, 1979b. Acute, subchronic, and chronic toxicity of chlordecone. Toxicol Appl Pharmacol 48:29–41.88086

Groups of Wistar rats (40/sex/group) were administered chlordecone in the diet for up to 2 years at 0, 5, 10, 25, 50, or 80 ppm. Other groups of male and female Wistar rats (40/sex/group) were administered chlordecone in the diet for up to 2 years at 0 or 1 ppm (estimated chlordecone doses of 0 and 0.089 mg/kg/day, respectively) and similarly evaluated. Estimated chlordecone doses of 0, 0.089, 0.45, 0.89, 2.2, 4.5, and 7.1 mg/kg/day were calculated for the 1, 5, 10, 25, 50, and 80 ppm dietary concentrations, respectively, using a time-weighted average (TWA) of reported body weights (0.254 kg) and a food consumption rate (0.0226 kg/day) calculated using EPA’s (1988) allometric equation. After 1 year, five rats/sex/dose group were sacrificed. All rats in the 4.5 and 7.1 mg/kg/day groups died by week 25. Proteinuria was noted in all 0.45, 0.89, and 2.2 mg/kg/day groups at all intervals after 3 months except in males at 21 and 24 months when control levels were elevated, and in females at 24 months when the levels in only the 0.89 and 2.2 mg/kg/day were elevated. There was no indication of proteinuria in the 0.089 mg/kg/day of male or female rats. The severity of observed glomerulosclerosis was increased in both males and females at ≥0.45 mg/kg/day. Non-statistically significantly increased kidney weight relative to body weight was reported. The NOAEL for kidney effects was 0.089 mg/kg/day. At 1- and 2-year sacrifice, NOAELs of 0.45 and 0.89 mg/kg/day and their respective LOAELs (0.89 mg/kg/day for fatty changes in the liver and 2.2 mg/kg/day for depressed hematocrit levels) were identified.

Selection of the Point of Departure for the MRL: The NOAEL of 0.089 mg/kg/day was selected as the point of departure for deriving a chronic-duration oral MRL for chlordecone. The proteinuria and glomerulosclerosis severity data were not amenable to BMD modeling because standard deviations were not reported.

Uncertainty Factor: The NOAEL of 0.089 mg/kg/day was divided by a total uncertainty factor of 100:

- 10 for animal to human extrapolation
- 10 for human variability

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Although other available chronic-duration oral studies did not identify renal effects in chlordecone-treated animals, adverse dermal, hepatic, hematological, and/or neurological effects were observed at doses in the range of 0.4–2.6 mg/kg/day.

Agency Contacts (Chemical Managers): Obaid Faroon, D.V.M., Ph.D.